# Patient Flow Through Trials

## A Schizophrenia and Related Psychoses

Table 56 Patient flow through trials–chlorpromazine versus clozapine

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Chiu et al. 1976 152 | Classification | FGA | SGA
Chiu et al. 1976 152 | Medication | Chlorpromazine | Clozapine
Chiu et al. 1976 152 | Dosage | 50–300mg/d | 50–300mg/d
Chiu et al. 1976 152 | No screened: | NR
Chiu et al. 1976 152 | No randomized: | 33 | 31
Chiu et al. 1976 152 | No completed: | 14 | 22
Chiu et al. 1976 152 | No analyzed (E): | NR | NR
Chiu et al. 1976 152 | No analyzed (S): | 14 | 22
Claghorn et al. 1987 63 | Classification | FGA | SGA
Claghorn et al. 1987 63 | Medication | Chlorpromazine | Clozapine
Claghorn et al. 1987 63 | Dosage | 50mg–1800mg/d | 25mg–900mg/d
Claghorn et al. 1987 63 | No screened: | NR
Claghorn et al. 1987 63 | No randomized: | 76 | 75
Claghorn et al. 1987 63 | No completed: | 40 | 48
Claghorn et al. 1987 63 | No analyzed (E): | 76 | 75
Claghorn et al. 1987 63 | No analyzed (S): | 76 | 75
Ekblom et al. 1974 153 | Classification | FGA | SGA
Ekblom et al. 1974 153 | Medication | Chlorpromazine | Clozapine
Ekblom et al. 1974 153 | Dosage | 65–700mg/d | 65–600mg/d
Ekblom et al. 1974 153 | No screened: | NR
Ekblom et al. 1974 153 | No randomized: | 21 | 20
Ekblom et al. 1974 153 | No completed: | 19 | 17
Ekblom et al. 1974 153 | No analyzed (E): | 21 | 20
Ekblom et al. 1974 153 | No analyzed (S): | 21 | 20
Gelenberg et al. 1979 154 | Classification | FGA | SGA
Gelenberg et al. 1979 154 | Medication | Chlorpromazine | Clozapine
Gelenberg et al. 1979 154 | Dosage | 50–1800mg/d | 25–900mg/d
Gelenberg et al. 1979 154 | No screened: | NR
Gelenberg et al. 1979 154 | No randomized: | 8 | 7
Gelenberg et al. 1979 154 | No completed: | NR | NR
Gelenberg et al. 1979 154 | No analyzed (E): | 8 | 7
Gelenberg et al. 1979 154 | No analyzed (S): | NR | 6
Guirguis et al. 1977 160 | Classification | FGA | SGA
Guirguis et al. 1977 160 | Medication | chlorpromazine | Clozapine
Guirguis et al. 1977 160 | Dosage | 150–900mg/d | 75–450mg/d
Guirguis et al. 1977 160 | No screened: | NR
Guirguis et al. 1977 160 | No randomized: | 28 | 22
Guirguis et al. 1977 160 | No completed: | 19 | 16
Guirguis et al. 1977 160 | No analyzed (E): | 19 | 16
Guirguis et al. 1977 160 | No analyzed (S): | 19 | 16
Hong et al. 1997 87 | Classification | FGA | SGA
Hong et al. 1997 87 | Medication | Chlorpromazine | Clozapine
Hong et al. 1997 87 | Dosage | 50–1800mg/d | 25–900mg/d
Hong et al. 1997 87 | No screened: | NR
Hong et al. 1997 87 | No randomized: | 19 | 21
Hong et al. 1997 87 | No completed: | 17 | 19
Hong et al. 1997 87 | No analyzed (E): | 19 | 21
Hong et al. 1997 87 | No analyzed (S): | 19 | 21
Kane et al. 1988 94 | Classification | FGA | SGA
Kane et al. 1988 94 | Medication | Chlorpromazine | Clozapine
Kane et al. 1988 94 | Dosage | 1000–1800mg/d | 500–900mg/d
Kane et al. 1988 94 | No screened: | NR
Kane et al. 1988 94 | No randomized: | 142 | 126
Kane et al. 1988 94 | No completed: | 124 | 111
Kane et al. 1988 94 | No analyzed (E): | 139 | 126
Kane et al. 1988 94 | No analyzed (S): | 142 | 126
Leon et al. 1979 156 | Classification | FGA | SGA
Leon et al. 1979 156 | Medication | Chlorpromazine | Clozapine
Leon et al. 1979 156 | Dosage | 100–1600mg/d | 100–1600mg/d
Leon et al. 1979 156 | No screened: | NR
Leon et al. 1979 156 | No randomized: | 25 | 25
Leon et al. 1979 156 | No completed: | 17 | 14
Leon et al. 1979 156 | No analyzed (E): | 25 | 25
Leon et al. 1979 156 | No analyzed (S): | 25 | 25
Lieberman et al. 2003 109 | Classification | FGA | SGA
Lieberman et al. 2003 109 | Medication | Chlorpromazine | Clozapine
Lieberman et al. 2003 109 | Dosage | max of 600 mg/d | max of 400 mg/d
Lieberman et al. 2003 109 | No screened: | 2708
Lieberman et al. 2003 109 | No randomized: | 83 | 81
Lieberman et al. 2003 109 | No completed: | 62 | 68
Lieberman et al. 2003 109 | No analyzed (E): | 80 | 80
Lieberman et al. 2003 109 | No analyzed (S): | 80 | 80
Rinieris et al. 1980 157 | Classification | FGA | FGA | SGA
Rinieris et al. 1980 157 | Medication | Chlorpromazine | Trifluoperazine | Clozapine
Rinieris et al. 1980 157 | Dosage | 50–100mg | 2.5–5mg | 50–100mg
Rinieris et al. 1980 157 | No screened: | NR
Rinieris et al. 1980 157 | No randomized: | 16 | 20 | 5
Rinieris et al. 1980 157 | No completed: | 10 | 9 | 5
Rinieris et al. 1980 157 | No analyzed (E): | 10 | 9 | 5
Rinieris et al. 1980 157 | No analyzed (S): | 10 | 9 | 5
Shopsin et al. 1979 158 | Classification | FGA | SGA
Shopsin et al. 1979 158 | Medication | Chlorpromazine | Clozapine
Shopsin et al. 1979 158 | Dosage | 50–1600mg/d | 25–900mg/d
Shopsin et al. 1979 158 | No screened: | 50
Shopsin et al. 1979 158 | No randomized: | 12 | 13
Shopsin et al. 1979 158 | No completed: | 12 | 13
Shopsin et al. 1979 158 | No analyzed (E): | 12 | 13
Shopsin et al. 1979 158 | No analyzed (S): | 12 | 13
Singer et al. 1974 161 | Classification | FGA | SGA
Singer et al. 1974 161 | Medication | chlorpromazine | Clozapine
Singer et al. 1974 161 | Dosage | 50–600mg/d | 50–600mg/d
Singer et al. 1974 161 | No screened: | NR
Singer et al. 1974 161 | No randomized: | 20 | 20
Singer et al. 1974 161 | No completed: | 19 | 19
Singer et al. 1974 161 | No analyzed (E): | 19 | 19
Singer et al. 1974 161 | No analyzed (S): | 19 | 19

d = day; E = efficacy; FGA = first-generation antipsychotic; max = maximum; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 57 Patient flow through trials–chlorpromazine versus olanzapine

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Conley et al. 1998 66 | Classification | FGA | SGA
Conley et al. 1998 66 | Medication | Chlorpromazine | Olanzapine
Conley et al. 1998 66 | Dosage | 600–1200mg/d | 12.5–25mg/d
Conley et al. 1998 66 | No screened: | 103
Conley et al. 1998 66 | No randomized: | 42 | 42
Conley et al. 1998 66 | No completed: | 29 | 30
Conley et al. 1998 66 | No analyzed (E): | 42 | 42
Conley et al. 1998 66 | No analyzed (S): | 42 | 42

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 58 Patient flow through trials–chlorpromazine versus quetiapine

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Peuskens et al. 1997 121 | Classification | FGA | SGA
Peuskens et al. 1997 121 | Medication | Chlorpromazine | Quetiapine
Peuskens et al. 1997 121 | Dosage | 75–750mg/d | 75–750mg/d
Peuskens et al. 1997 121 | No screened: | NR
Peuskens et al. 1997 121 | No randomized: | 100 | 101
Peuskens et al. 1997 121 | No completed: | 64 | 70
Peuskens et al. 1997 121 | No analyzed (E): | 100 | 101
Peuskens et al. 1997 121 | No analyzed (S): | 100 | 101

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 59 Patient flow through trials–chlorpromazine versus ziprasidone

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Kane et al. 2006 96 | Classification | FGA | SGA
Kane et al. 2006 96 | Medication | Chlorpromazine | Ziprasidone
Kane et al. 2006 96 | Dosage | 100–1200mg/d | 40–160mg/d
Kane et al. 2006 96 | No screened: | NR
Kane et al. 2006 96 | No randomized: | 489 | 154 | 152
Kane et al. 2006 96 | No completed: | 135 | 136
Kane et al. 2006 96 | No analyzed (E): | 154 | 152
Kane et al. 2006 96 | No analyzed (S): | 154 | 152

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 60 Patient flow through trials–fluphenazine versus olanzapine

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Jakovljevic et al. 1999 89 | Classification | FGA | SGA
Jakovljevic et al. 1999 89 | Medication | Fluphenazine | Olanzapine
Jakovljevic et al. 1999 89 | Dosage | 6–21mg/d | 5–20mg/d
Jakovljevic et al. 1999 89 | No screened: | 64
Jakovljevic et al. 1999 89 | No randomized: | 30 | 30
Jakovljevic et al. 1999 89 | No completed: | 22 | 29
Jakovljevic et al. 1999 89 | No analyzed (E): | 28 | 27
Jakovljevic et al. 1999 89 | No analyzed (S): | 30 | 30
Ljubin et al. 2000 112 | Classification | FGA | SGA
Ljubin et al. 2000 112 | Medication | Fluphenazine | Olanzapine
Ljubin et al. 2000 112 | Dosage | 6–21mg/d | 5–20mg/d
Ljubin et al. 2000 112 | No screened: | NR
Ljubin et al. 2000 112 | No randomized: | 30 | 30
Ljubin et al. 2000 112 | No completed: | 8 | 10
Ljubin et al. 2000 112 | No analyzed (E): | 8 | 10
Ljubin et al. 2000 112 | No analyzed (S): | NR | NR

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 61 Patient flow through trials – fluphenazine versus quetiapine

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Conley et al. 2005 67 | Classification | FGA | SGA | SGA
Conley et al. 2005 67 | Medication | Fluphenazine | Quetiapine | Risperidone
Conley et al. 2005 67 | Dosage | 10–15mg/d | 300–500mg/d | 3–5mg/d
Conley et al. 2005 67 | No screened: | 52
Conley et al. 2005 67 | No randomized: | 13 | 12 | 13
Conley et al. 2005 67 | No completed: | 4 | 8 | 8
Conley et al. 2005 67 | No analyzed (E): | 13 | 12 | 13
Conley et al. 2005 67 | No analyzed (S): | 12 | 12 | 13

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 62 Patient flow through trials – fluphenazine versus risperidone

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Conley et al. 2005 67 | Classification | FGA | SGA | SGA
Conley et al. 2005 67 | Medication | Fluphenazine | Quetiapine | Risperidone
Conley et al. 2005 67 | Dosage | 10–15mg/d | 300–500mg/d | 3–5mg/d
Conley et al. 2005 67 | No screened: | 52
Conley et al. 2005 67 | No randomized: | 13 | 12 | 13
Conley et al. 2005 67 | No completed: | 4 | 8 | 8
Conley et al. 2005 67 | No analyzed (E): | 13 | 12 | 13
Conley et al. 2005 67 | No analyzed (S): | 12 | 12 | 13

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 63 Patient flow through trials–haloperidol versus aripiprazole

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Andrezina et al. 2006 44 | Classification | FGA | SGA
Andrezina et al. 2006 44 | Medication | Haloperidol | Aripiprazole
Andrezina et al. 2006 44 | Dosage | 6.5mg | 9.75mg
Andrezina et al. 2006 44 | No screened: | 448
Andrezina et al. 2006 44 | No randomized: | 185 | 175
Andrezina et al. 2006 44 | No completed: | 185 | 175
Andrezina et al. 2006 44 | No analyzed (E): | 185 | 175
Andrezina et al. 2006 44 | No analyzed (S): | 183 | 175
Daniel et al. 2007 74 | Classification | FGA | SGA
Daniel et al. 2007 74 | Medication | Haloperidol | Aripiprazole
Daniel et al. 2007 74 | Dosage | 6.5mg/d | 9.75mg/d
Daniel et al. 2007 74 | No screened: | NR
Daniel et al. 2007 74 | No randomized: | 185 | 175
Daniel et al. 2007 74 | No completed: | 136 | 140
Daniel et al. 2007 74 | No analyzed (E): | 151 | 153
Daniel et al. 2007 74 | No analyzed (S): | 150 | 155
de Oliveira et al. 2009 76 | Classification | FGA | SGA
de Oliveira et al. 2009 76 | Medication | Haloperidol | Aripiprazole
de Oliveira et al. 2009 76 | Dosage | 10–15mg/d | 15–30mg/d
de Oliveira et al. 2009 76 | No screened: | NR
de Oliveira et al. 2009 76 | No randomized: | 33 | 66
de Oliveira et al. 2009 76 | No completed: | 21 | 53
de Oliveira et al. 2009 76 | No analyzed (E): | 31 | 66
de Oliveira et al. 2009 76 | No analyzed (S): | 31 | 66
Kane et al. 2002 92 | Classification | FGA | SGA | SGA
Kane et al. 2002 92 | Medication | Haloperidol | Aripiprazole | Aripiprazole
Kane et al. 2002 92 | Dosage | 10mg/d | 15mg/d | 30mg/d
Kane et al. 2002 92 | No screened: | 502
Kane et al. 2002 92 | No randomized: | 104 | 102 | 102
Kane et al. 2002 92 | No completed: | 62 | 68 | 60
Kane et al. 2002 92 | No analyzed (E): | 104 | 102 | 102
Kane et al. 2002 92 | No analyzed (S): | 103 | 102 | 101
Kasper et al. 2003 98 | Classification | FGA | SGA
Kasper et al. 2003 98 | Medication | Haloperidol | Aripiprazole
Kasper et al. 2003 98 | Dosage | 5–10mg/d | 20–30mg/d
Kasper et al. 2003 98 | No screened: | 1294
Kasper et al. 2003 98 | No randomized: | 433 | 861
Kasper et al. 2003 98 | No completed: | 128 | 367
Kasper et al. 2003 98 | No analyzed (E): | 428 | 851
Kasper et al. 2003 98 | No analyzed (S): | 428 | 851
Kim et al. 2010 102 | Classification | FGA | SGA | SGA | SGA
Kim et al. 2010 102 | Medication | Haloperidol | Aripiprazole | Olanzapine | Risperidone
Kim et al. 2010 102 | Dosage | 15.9+/−7.1mg/d | 21.7+/−5.5mg/d | 15.9+/−4.3mg/d | 4.8+/−2.9mg/d
Kim et al. 2010 102 | No screened: | NR
Kim et al. 2010 102 | No randomized: | 35 | 31 | 32 | 41
Kim et al. 2010 102 | No completed: | NR | NR | NR | NR
Kim et al. 2010 102 | No analyzed (E): | NR | NR | NR | NR
Kim et al. 2010 102 | No analyzed (S): | NR | NR | NR | NR
McCue et al. 2006 73 | Classification | FGA | SGA | SGA | SGA | SGA | SGA
McCue et al. 2006 73 | Medication | Haloperidol | Aripiprazole | Olanzapine | Quetiapine | Risperidone | Ziprasidone
McCue et al. 2006 73 | Dosage | 4–30mg | 10–45mg | 5–40mg | 50–1200mg | 2–9mg | 40–240mg
McCue et al. 2006 73 | No screened: | 584
McCue et al. 2006 73 | No randomized: | 61 | 63 | 62 | 58 | 65 | 59
McCue et al. 2006 73 | No completed: | 53 | 49 | 50 | 50 | 55 | 45
McCue et al. 2006 73 | No analyzed (E): | 57 | 53 | 50 | 52 | 57 | 50
McCue et al. 2006 73 | No analyzed (S): | 57 | 53 | 50 | 52 | 57 | 50
Tran–Johnson et al. 2007 31 | Classification | FGA | SGA | SGA | SGA | SGA
Tran–Johnson et al. 2007 31 | Medication | Haloperidol | Aripiprazole | Aripiprazole | Aripiprazole | Aripiprazole
Tran–Johnson et al. 2007 31 | Dosage | 7.5mg/d | 1mg/d | 5.25mg/d | 9.75mg/d | 15mg/d
Tran–Johnson et al. 2007 31 | No screened: | NR
Tran–Johnson et al. 2007 31 | No randomized: | 60 | 57 | 63 | 57 | 58
Tran–Johnson et al. 2007 31 | No completed: | NR | NR | NR | NR | NR
Tran–Johnson et al. 2007 31 | No analyzed (E): | 57 | 56 | 62 | 56 | 58
Tran–Johnson et al. 2007 31 | No analyzed (S): | 57 | 56 | 62 | 56 | 58

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 64 Patient flow through trials–haloperidol versus asenapine

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Kane et al. 2010 97 | Classification | FGA | SGA | SGA
Kane et al. 2010 97 | Medication | Haloperidol | Asenapine | Asenapine
Kane et al. 2010 97 | Dosage | 4mg/d | 5mg/d | 10mg/d
Kane et al. 2010 97 | No screened: | 513
Kane et al. 2010 97 | No randomized: | 115 | 114 | 106
Kane et al. 2010 97 | No completed: | 65 | 68 | 70
Kane et al. 2010 97 | No analyzed (E): | 112 | 109 | 105
Kane et al. 2010 97 | No analyzed (S): | 115 | 111 | 106

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 65 Patient flow through trials–haloperidol versus clozapine

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Breier et al. 1994 55 | Classification | FGA | SGA
Breier et al. 1994 55 | Medication | Haloperidol | Clozapine
Breier et al. 1994 55 | Dosage | 10–30mg/d | 200–600mg/d
Breier et al. 1994 55 | No screened: | NR
Breier et al. 1994 55 | No randomized: | NR | NR
Breier et al. 1994 55 | No completed: | 20 | 19
Breier et al. 1994 55 | No analyzed (E): | 20 | 19
Breier et al. 1994 55 | No analyzed (S): | 20 | 19
Citrome et al. 2001 62 | Classification | FGA | SGA | SGA | SGA
Citrome et al. 2001 62 | Medication | Haloperidol | Clozapine | Olanzapine | Risperidone
Citrome et al. 2001 62 | Dosage | 10–30mg/d | 200–800mg/d | 10–40mg/d | 4–16mg/d
Citrome et al. 2001 62 | No screened: | NR
Citrome et al. 2001 62 | No randomized: | 37 | 40 | 39 | 41
Citrome et al. 2001 62 | No completed: | 27 | 32 | 30 | 28
Citrome et al. 2001 62 | No analyzed (E): | 37 | 40 | 39 | 41
Citrome et al. 2001 62 | No analyzed (S): | 37 | 40 | 39 | 41
Covington et al. 2000 70 | Classification | FGA | SGA
Covington et al. 2000 70 | Medication | Haloperidol | Clozapine
Covington et al. 2000 70 | Dosage | NR | NR
Covington et al. 2000 70 | Patient flow through trial
Covington et al. 2000 70 | No screened: | NR
Covington et al. 2000 70 | No randomized: | 42 | 40
Covington et al. 2000 70 | No completed: | NR | NR
Covington et al. 2000 70 | No analyzed (E): | 42 | 40
Covington et al. 2000 70 | No analyzed (S): | 42 | 40
Itoh et al. 1977 155 | Classification | FGA | SGA
Itoh et al. 1977 155 | Medication | Haloperidol | Clozapine
Itoh et al. 1977 155 | Dosage | 2.25–15mg/d | 75–500mg/d
Itoh et al. 1977 155 | No screened: | NR
Itoh et al. 1977 155 | No randomized: | 41 | 47
Itoh et al. 1977 155 | No completed: | NR | NR
Itoh et al. 1977 155 | No analyzed (E): | NR | NR
Itoh et al. 1977 155 | No analyzed (S): | NR | NR
Kane et al. 2001 95 | Classification | FGA | SGA
Kane et al. 2001 95 | Medication | Haloperidol | Clozapine
Kane et al. 2001 95 | Dosage | 5–16mg/d | 12.5–800mg/d
Kane et al. 2001 95 | No screened: | NR
Kane et al. 2001 95 | No randomized: | 34 | 37
Kane et al. 2001 95 | No completed: | 12 | 24
Kane et al. 2001 95 | No analyzed (E): | 11 | 23
Kane et al. 2001 95 | No analyzed (S): | 34 | 37
Kleiser et al. 1994 103 | Classification | FGA | SGA
Kleiser et al. 1994 103 | Medication | Haloperidol | Clozapine
Kleiser et al. 1994 103 | Dosage | 16mg/d | 350mg/d
Kleiser et al. 1994 103 | No screened: | NR
Kleiser et al. 1994 103 | No randomized: | 18 | 18
Kleiser et al. 1994 103 | No completed: | 17 | 17
Kleiser et al. 1994 103 | No analyzed (E): | 17 | 17
Kleiser et al. 1994 103 | No analyzed (S): | 17 | 17
Krakowski et al. 2006 105 | Classification | FGA | SGA | SGA
Krakowski et al. 2006 105 | Medication | Haloperidol | Clozapine | Olanzapine
Krakowski et al. 2006 105 | Dosage | 10–30mg/d | 200–800mg/d | 10–35mg/d
Krakowski et al. 2006 105 | No screened: | 134
Krakowski et al. 2006 105 | No randomized: | 36 | 37 | 37
Krakowski et al. 2006 105 | No completed: | 20 | 24 | 26
Krakowski et al. 2006 105 | No analyzed (E): | 36 | 37 | 37
Krakowski et al. 2006 105 | No analyzed (S): | 36 | 37 | 37
Rosenheck et al. 1997 126 | Classification | FGA | SGA
Rosenheck et al. 1997 126 | Medication | Haloperidol | Clozapine
Rosenheck et al. 1997 126 | Dosage | 5–30mg/d | 100–900mg/d
Rosenheck et al. 1997 126 | No screened: | 423
Rosenheck et al. 1997 126 | No randomized: | 218 | 205
Rosenheck et al. 1997 126 | No completed: | 61 | 117
Rosenheck et al. 1997 126 | No analyzed (E): | 218 | 205
Rosenheck et al. 1997 126 | No analyzed (S): | 218 | 205
Volakva et al. 2002 145 | Classification | FGA | SGA | SGA | SGA
Volakva et al. 2002 145 | Medication | Haloperidol | Clozapine | Olanzapine | Risperidone
Volakva et al. 2002 145 | Dosage | 10–30mg/d | 200–800mg/d | 10–40mg/d | 4–16mg/d
Volakva et al. 2002 145 | No screened: | NR
Volakva et al. 2002 145 | No randomized: | 37 | 40 | 39 | 41
Volakva et al. 2002 145 | No completed: | 21 | 22 | 26 | 22
Volakva et al. 2002 145 | No analyzed (E): | 37 | 40 | 39 | 41
Volakva et al. 2002 145 | No analyzed (S): | 37 | 40 | 39 | 41

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 66 Patient flow through trials–haloperidol versus olanzapine

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Altamura et al. 2002 43 | Classification | FGA | SGA
Altamura et al. 2002 43 | Medication | Haloperidol | Olanzapine
Altamura et al. 2002 43 | Dosage | 10–20mg/d | 10–20mg/d
Altamura et al. 2002 43 | No screened: | NR
Altamura et al. 2002 43 | No randomized: | 15 | 13
Altamura et al. 2002 43 | No completed: | 8 | 13
Altamura et al. 2002 43 | No analyzed (E): | 11 | 13
Altamura et al. 2002 43 | No analyzed (S): | 11 | 13
Alvarez–Jimenez et al. 2006 142 | Classification | FGA | SGA | SGA
Alvarez–Jimenez et al. 2006 142 | Medication | Haloperidol | Olanzapine | Risperidone
Alvarez–Jimenez et al. 2006 142 | Dosage | 3–9mg/d | 5–20mg/d | 3–6mg/d
Alvarez–Jimenez et al. 2006 142 | No screened: | NR
Alvarez–Jimenez et al. 2006 142 | No randomized: | 20 | 17 | 24
Alvarez–Jimenez et al. 2006 142 | No completed: | 20 | 17 | 24
Alvarez–Jimenez et al. 2006 142 | No analyzed (E): | 20 | 17 | 24
Alvarez–Jimenez et al. 2006 142 | No analyzed (S): | 20 | 17 | 24
Beasley et al. 1996 49 | Classification | FGA | SGA | SGA | SGA
Beasley et al. 1996 49 | Medication | Haloperidol | Olanzapine | Olanzapine | Olanzapine
Beasley et al. 1996 49 | Dosage | 10–20mg/d | 2.5–7.5mg/d | 7.5–12.5mg/d | 12.5–17.5mg/d
Beasley et al. 1996 49 | No screened: | 335
Beasley et al. 1996 49 | No randomized: | 69 | 65 | 64 | 69
Beasley et al. 1996 49 | No completed: | 30 | 30 | 30 | 34
Beasley et al. 1996 49 | No analyzed (E): | 18 | 16 | 19 | 27
Beasley et al. 1996 49 | No analyzed (S): | 69 | 65 | 64 | 69
Beasley et al. 1997 50 | Classification | FGA | SGA | SGA | SGA | SGA
Beasley et al. 1997 50 | Medication | Haloperidol | Olanzapine | Olanzapine | Olanzapine | Olanzapine
Beasley et al. 1997 50 | Dosage | 15±5mg/d | 1.0mg/d | 5±2.5mg/d | 10±2.5mg/d | 15±2.5mg/d
Beasley et al. 1997 50 | No screened: | NR
Beasley et al. 1997 50 | No randomized: | 81 | 88 | 87 | 86 | 89
Beasley et al. 1997 50 | No completed: | 43 | 48 | 48 | 53 | 55
Beasley et al. 1997 50 | No analyzed (E): | 79 | 83 | 85 | 83 | 85
Beasley et al. 1997 50 | No analyzed (S): | 81 | 88 | 87 | 86 | 89
Bernardo et al. 2001 51 | Classification | FGA | SGA
Bernardo et al. 2001 51 | Medication | Haloperidol | Olanzapine
Bernardo et al. 2001 51 | Dosage | 10mg/d | 10mg/d
Bernardo et al. 2001 51 | No screened: | NR
Bernardo et al. 2001 51 | No randomized: | 13 | 14
Bernardo et al. 2001 51 | No completed: | NR | NR
Bernardo et al. 2001 51 | No analyzed (E): | 13 | 14
Bernardo et al. 2001 51 | No analyzed (S): | 13 | 14
Boulay et al. 2007 54 | Classification | FGA | SGA
Boulay et al. 2007 54 | Medication | Haloperidol | Olanzapine
Boulay et al. 2007 54 | Dosage | 2.5–20mg/d | 2.5–20mg/d
Boulay et al. 2007 54 | No screened: | NR
Boulay et al. 2007 54 | No randomized: | 13 | 14
Boulay et al. 2007 54 | No completed: | 8 | 14
Boulay et al. 2007 54 | No analyzed (E): | 11 | 14
Boulay et al. 2007 54 | No analyzed (S): | 11 | 14
Breier et al. 2002 56 | Classification | FGA | SGA | SGA | SGA | SGA
Breier et al. 2002 56 | Medication | Haloperidol | Olanzapine | Olanzapine | Olanzapine | Olanzapine
Breier et al. 2002 56 | Dosage | 7.5mg | 2.5mg | 5.0mg | 7.5mg | 10.0mg
Breier et al. 2002 56 | No screened: | NR
Breier et al. 2002 56 | No randomized: | 40 | 48 | 45 | 46 | 46
Breier et al. 2002 56 | No completed: | 40 | 48 | 43 | 46 | 46
Breier et al. 2002 56 | No analyzed (E): | 40 | 48 | 43 | 46 | 46
Breier et al. 2002 56 | No analyzed (S): | 40 | 48 | 43 | 46 | 46
Buchanan et al. 2005 58 | Classification | FGA | SGA
Buchanan et al. 2005 58 | Medication | Haloperidol | Olanzapine
Buchanan et al. 2005 58 | Dosage | 10–30mg/d | 10–30mg/d
Buchanan et al. 2005 58 | No screened: | 68
Buchanan et al. 2005 58 | No randomized: | 34 | 29
Buchanan et al. 2005 58 | No completed: | 31 | 26
Buchanan et al. 2005 58 | No analyzed (E): | 34 | 29
Buchanan et al. 2005 58 | No analyzed (S): | 34 | 29
Citrome et al. 2001 62 | Classification | FGA | SGA | SGA | SGA
Citrome et al. 2001 62 | Medication | Haloperidol | Clozapine | Olanzapine | Risperidone
Citrome et al. 2001 62 | Dosage | 10–30mg/d | 200–800mg/d | 10–40mg/d | 4–16mg/d
Citrome et al. 2001 62 | No screened: | NR
Citrome et al. 2001 62 | No randomized: | 37 | 40 | 39 | 41
Citrome et al. 2001 62 | No completed: | 27 | 32 | 30 | 28
Citrome et al. 2001 62 | No analyzed (E): | 37 | 40 | 39 | 41
Citrome et al. 2001 62 | No analyzed (S): | 37 | 40 | 39 | 41
Crespo–Facorro et al. 2006 71 | Classification | FGA | SGA | SGA
Crespo–Facorro et al. 2006 71 | Medication | Haloperidol | Olanzapine | Risperidone
Crespo–Facorro et al. 2006 71 | Dosage | 3–9mg/d | 5–20mg/d | 3–6mg/d
Crespo–Facorro et al. 2006 71 | No screened: | 202
Crespo–Facorro et al. 2006 71 | No randomized: | 56 | 55 | 61
Crespo–Facorro et al. 2006 71 | No completed: | 55 | 53 | 57
Crespo–Facorro et al. 2006 71 | No analyzed (E): | 56 | 55 | 61
Crespo–Facorro et al. 2006 71 | No analyzed (S): | 56 | 55 | 61
Davidson et al. 2009 75 | Classification | FGA | SGA | SGA | SGA
Davidson et al. 2009 75 | Medication | Haloperidol | Olanzapine | Quetiapine | Ziprasidone
Davidson et al. 2009 75 | Dosage | 1–4mg/d | 5–20mg/d | 200–750mg/d | 40–160mg/d
Davidson et al. 2009 75 | No screened: | NR
Davidson et al. 2009 75 | No randomized: | 103 | 104 | 105 | 82
Davidson et al. 2009 75 | No completed: | 52 | 60 | 74 | 45
Davidson et al. 2009 75 | No analyzed (E): | 52 | 60 | 74 | 45
Davidson et al. 2009 75 | No analyzed (S): | 52 | 60 | 74 | 45
de Haan et al. 2003 78 | Classification | FGA | SGA
de Haan et al. 2003 78 | Medication | Haloperidol | Olanzapine
de Haan et al. 2003 78 | Dosage | 2.5mg/d | 7.5mg/d
de Haan et al. 2003 78 | No screened: | NR
de Haan et al. 2003 78 | No randomized: | 12 | 12
de Haan et al. 2003 78 | No completed: | 10 | 9
de Haan et al. 2003 78 | No analyzed (E): | 10 | 9
de Haan et al. 2003 78 | No analyzed (S): | 10 | 9
Goldman et al. 2004 84 | Classification | FGA | SGA
Goldman et al. 2004 84 | Medication | Haloperidol | Olanzapine
Goldman et al. 2004 84 | Dosage | 5–20mg/d | 5–20mg/d
Goldman et al. 2004 84 | No screened: | NR
Goldman et al. 2004 84 | No randomized: | 5 | 5
Goldman et al. 2004 84 | No completed: | 2 | 5
Goldman et al. 2004 84 | No analyzed (E): | 5 | 5
Goldman et al. 2004 84 | No analyzed (S): | 5 | 5
Ishigooka et al. 2001 88 | Classification | FGA | SGA
Ishigooka et al. 2001 88 | Medication | Haloperidol | Olanzapine
Ishigooka et al. 2001 88 | Dosage | 4–12mg/d | 5–15mg/d
Ishigooka et al. 2001 88 | No screened: | NR
Ishigooka et al. 2001 88 | No randomized: | 89 | 93
Ishigooka et al. 2001 88 | No completed: | 59 | 75
Ishigooka et al. 2001 88 | No analyzed (E): | 78 | 80
Ishigooka et al. 2001 88 | No analyzed (S): | 84 | 90
Kahn et al. 2008 91 | Classification | FGA | SGA | SGA | SGA
Kahn et al. 2008 91 | Medication | Haloperidol | Olanzapine | Quetiapine | Ziprasidone
Kahn et al. 2008 91 | Dosage | 1–4mg/d | 5–20mg/d | 200–750mg/d | 40–16mg/d
Kahn et al. 2008 91 | No screened: | 1047
Kahn et al. 2008 91 | No randomized: | 103 | 105 | 104 | 82
Kahn et al. 2008 91 | No completed: | 68 | 82 | 70 | 53
Kahn et al. 2008 91 | No analyzed (E): | 103 | 105 | 104 | 82
Kahn et al. 2008 91 | No analyzed (S): | 103 | 105 | 104 | 82
Keefe et al. 2006 101 | Classification | FGA | SGA | SGA
Keefe et al. 2006 101 | Medication | Haloperidol | Olanzapine | Risperidone
Keefe et al. 2006 101 | Dosage | 2–19mg/d | 5–20mg/d | 2–10mg/d
Keefe et al. 2006 101 | No screened: | 414
Keefe et al. 2006 101 | No randomized: | 97 | 159 | 158
Keefe et al. 2006 101 | No completed: | 27 | 64 | 54
Keefe et al. 2006 101 | No analyzed (E): | 94 | 153 | 148
Keefe et al. 2006 101 | No analyzed (S): | 97 | 159 | 158
Kim et al. 2010 102 | Classification | FGA | SGA | SGA | SGA
Kim et al. 2010 102 | Medication | Haloperidol | Aripiprazole | Olanzapine | Risperidone
Kim et al. 2010 102 | Dosage | 15.9+/−7.1mg/d | 21.7+/−5.5mg/d | 15.9+/−4.3mg/d | 4.8+/−2.9mg/d
Kim et al. 2010 102 | No screened: | NR
Kim et al. 2010 102 | No randomized: | 35 | 31 | 32 | 41
Kim et al. 2010 102 | No completed: | NR | NR | NR | NR
Kim et al. 2010 102 | No analyzed (E): | NR | NR | NR | NR
Kim et al. 2010 102 | No analyzed (S): | NR | NR | NR | NR
Kongsakon et al. 2006 104 | Classification | FGA | SGA
Kongsakon et al. 2006 104 | Medication | Haloperidol | Olanzapine
Kongsakon et al. 2006 104 | Dosage | 5–20mg | 5–20mg
Kongsakon et al. 2006 104 | No screened: | 440
Kongsakon et al. 2006 104 | No randomized: | 132 | 144
Kongsakon et al. 2006 104 | No completed: | 94 | 113
Kongsakon et al. 2006 104 | No analyzed (E): | 123 | 139
Kongsakon et al. 2006 104 | No analyzed (S): | 124 | 139
Krakowski et al. 2006 105 | Classification | FGA | SGA | SGA
Krakowski et al. 2006 105 | Medication | Haloperidol | Clozapine | Olanzapine
Krakowski et al. 2006 105 | Dosage | 10–30mg/d | 200–800mg/d | 10–35mg/d
Krakowski et al. 2006 105 | No screened: | 134
Krakowski et al. 2006 105 | No randomized: | 36 | 37 | 37
Krakowski et al. 2006 105 | No completed: | 20 | 24 | 26
Krakowski et al. 2006 105 | No analyzed (E): | 36 | 37 | 37
Krakowski et al. 2006 105 | No analyzed (S): | 36 | 37 | 37
Lahti et al. 2009 106 | Classification | FGA | SGA
Lahti et al. 2009 106 | Medication | Haloperidol | Olanzapine
Lahti et al. 2009 106 | Dosage | 10–20mg/d | 12.5–25mg/d
Lahti et al. 2009 106 | No screened: | 37
Lahti et al. 2009 106 | No randomized: | 14 | 18
Lahti et al. 2009 106 | No completed: | 12 | 17
Lahti et al. 2009 106 | No analyzed (E): | 12 | 17
Lahti et al. 2009 106 | No analyzed (S): | 12 | 17
Lieberman et al. 2003 108 | Classification | FGA | SGA
Lieberman et al. 2003 108 | Medication | Haloperidol | Olanzapine
Lieberman et al. 2003 108 | Dosage | 2–20mg/d | 5–20mg/d
Lieberman et al. 2003 108 | No screened: | 263
Lieberman et al. 2003 108 | No randomized: | 132 | 131
Lieberman et al. 2003 108 | No completed: | 71 | 89
Lieberman et al. 2003 108 | No analyzed (E): | 132 | 131
Lieberman et al. 2003 108 | No analyzed (S): | 132 | 131
Lindenmayer et al. 2007 110 | Classification | FGA | SGA
Lindenmayer et al. 2007 110 | Medication | Haloperidol | Olanzapine
Lindenmayer et al. 2007 110 | Dosage | 5–20mg/d | 5–20mg/d
Lindenmayer et al. 2007 110 | No screened: | 36
Lindenmayer et al. 2007 110 | No randomized: | 19 | 16
Lindenmayer et al. 2007 110 | No completed: | 19 | 16
Lindenmayer et al. 2007 110 | No analyzed (E): | 16 | 15
Lindenmayer et al. 2007 110 | No analyzed (S): | 16 | 15
McCue et al. 2006 73 | Classification | FGA | SGA | SGA | SGA | SGA | SGA
McCue et al. 2006 73 | Medication | Haloperidol | Aripiprazole | Olanzapine | Quetiapine | Risperidone | Ziprasidone
McCue et al. 2006 73 | Dosage | 4–30mg | 10–45mg | 5–40mg | 50–1200mg | 2–9mg | 40–240mg
McCue et al. 2006 73 | No screened: | 584
McCue et al. 2006 73 | No randomized: | 61 | 63 | 62 | 58 | 65 | 59
McCue et al. 2006 73 | No completed: | 53 | 49 | 50 | 50 | 55 | 45
McCue et al. 2006 73 | No analyzed (E): | 57 | 53 | 50 | 52 | 57 | 50
McCue et al. 2006 73 | No analyzed (S): | 57 | 53 | 50 | 52 | 57 | 50
Purdon et al. 2000 124 | Classification | FGA | SGA | SGA
Purdon et al. 2000 124 | Medication | Haloperidol | Olanzapine | Risperidone
Purdon et al. 2000 124 | Dosage | 5–20mg/d | 5–20mg/d | 2–6mg/d
Purdon et al. 2000 124 | No screened: | NR
Purdon et al. 2000 124 | No randomized: | 23 | 21 | 21
Purdon et al. 2000 124 | No completed: | 9 | 12 | 7
Purdon et al. 2000 124 | No analyzed (E): | 23 | 21 | 21
Purdon et al. 2000 124 | No analyzed (S): | 23 | 21 | 21
Rosenheck et al. 2003 127 | Classification | FGA | SGA
Rosenheck et al. 2003 127 | Medication | Haloperidol | Olanzapine
Rosenheck et al. 2003 127 | Dosage | 5–20mg/d | 5–20mg/d
Rosenheck et al. 2003 127 | No screened: | 4386
Rosenheck et al. 2003 127 | No randomized: | 150 | 159
Rosenheck et al. 2003 127 | No completed: | 64 | 68
Rosenheck et al. 2003 127 | No analyzed (E): | 150 | 159
Rosenheck et al. 2003 127 | No analyzed (S): | 150 | 159
Saddichha et al. 2008 129 | Classification | FGA | SGA | SGA
Saddichha et al. 2008 129 | Medication | Haloperidol | Olanzapine | Risperidone
Saddichha et al. 2008 129 | Dosage | 13.4+/−3.6mg/d | 16.5+/−4.6mg/d | 4.4+/−1.2mg/d
Saddichha et al. 2008 129 | No screened: | NR
Saddichha et al. 2008 129 | No randomized: | NR | NR | NR
Saddichha et al. 2008 129 | No completed: | 31 | 35 | 33
Saddichha et al. 2008 129 | No analyzed (E): | 31 | 35 | 33
Saddichha et al. 2008 129 | No analyzed (S): | NR | NR
Sayers et al. 2005 130 | Classification | FGA | SGA
Sayers et al. 2005 130 | Medication | Haloperidol | Olanzapine
Sayers et al. 2005 130 | Dosage | 10–20 mg/d | 10–20mg/d
Sayers et al. 2005 130 | No screened: | 170
Sayers et al. 2005 130 | No randomized: | 12 | 12
Sayers et al. 2005 130 | No completed: | 7 | 7
Sayers et al. 2005 130 | No analyzed (E): | 12 | 12
Sayers et al. 2005 130 | No analyzed (S): | 12 | 12
Sergi et al. 2007 134 | Classification | FGA | SGA | SGA
Sergi et al. 2007 134 | Medication | Haloperidol | Olanzapine | Risperidone
Sergi et al. 2007 134 | Dosage | 8mg/d | 15mg/d | 4mg/d
Sergi et al. 2007 134 | No screened: | NR
Sergi et al. 2007 134 | No randomized: | 20 | 40 | 40
Sergi et al. 2007 134 | No completed: | 12 | 22 | 25
Sergi et al. 2007 134 | No analyzed (E): | 13 | 28 | 32
Sergi et al. 2007 134 | No analyzed (S): | 13 | 28 | 32
Smelson et al. 2006 136 | Classification | FGA | SGA
Smelson et al. 2006 136 | Medication | Haloperidol | Olanzapine
Smelson et al. 2006 136 | Dosage | 5–20mg/d | 5–20mg/d
Smelson et al. 2006 136 | No screened: | NR
Smelson et al. 2006 136 | No randomized: | 15 | 16
Smelson et al. 2006 136 | No completed: | 10 | 8
Smelson et al. 2006 136 | No analyzed (E): | 15 | 16
Smelson et al. 2006 136 | No analyzed (S): | NR | NR
Smith et al. 2001 137 | Classification | FGA | SGA
Smith et al. 2001 137 | Medication | Haloperidol | Olanzapine
Smith et al. 2001 137 | Dosage | 5–40mg/d | 5–20mg/d
Smith et al. 2001 137 | No screened: | NR
Smith et al. 2001 137 | No randomized: | NR | NR
Smith et al. 2001 137 | No completed: | 13 | 16
Smith et al. 2001 137 | No analyzed (E): | 13 | 16
Smith et al. 2001 137 | No analyzed (S): | NR | NR
Tollefson et al. 1997 141 | Classification | FGA | SGA
Tollefson et al. 1997 141 | Medication | Haloperidol | Olanzapine
Tollefson et al. 1997 141 | Dosage | 5–20mg/d | 5–20mg/d
Tollefson et al. 1997 141 | No screened: | 2223
Tollefson et al. 1997 141 | No randomized: | 660 | 1336
Tollefson et al. 1997 141 | No completed: | 309 | 888
Tollefson et al. 1997 141 | No analyzed (E): | 660 | 1336
Tollefson et al. 1997 141 | No analyzed (S): | 660 | 1336
Volakva et al. 2002 145 | Classification | FGA | SGA | SGA | SGA
Volakva et al. 2002 145 | Medication | Haloperidol | Clozapine | Olanzapine | Risperidone
Volakva et al. 2002 145 | Dosage | 10–30mg/d | 200–800mg/d | 10–40mg/d | 4–16mg/d
Volakva et al. 2002 145 | No screened: | NR
Volakva et al. 2002 145 | No randomized: | 37 | 40 | 39 | 41
Volakva et al. 2002 145 | No completed: | 21 | 22 | 26 | 22
Volakva et al. 2002 145 | No analyzed (E): | 37 | 40 | 39 | 41
Volakva et al. 2002 145 | No analyzed (S): | 37 | 40 | 39 | 41
Wright et al. 2001 147 | Classification | FGA | SGA
Wright et al. 2001 147 | Medication | Haloperidol | Olanzapine
Wright et al. 2001 147 | Dosage | 7.5mg | 10mg
Wright et al. 2001 147 | No screened: | 311
Wright et al. 2001 147 | No randomized: | 126 | 131
Wright et al. 2001 147 | No completed: | 126 | 131
Wright et al. 2001 147 | No analyzed (E): | 126 | 131
Wright et al. 2001 147 | No analyzed (S): | 126 | 131
Wynn et al. 2007 148 | Classification | FGA | SGA | SGA
Wynn et al. 2007 148 | Medication | Haloperidol | Olanzapine | Risperidone
Wynn et al. 2007 148 | Dosage | 8mg/d | 15mg/d | 4mg/d
Wynn et al. 2007 148 | No screened: | 100
Wynn et al. 2007 148 | No randomized: | 11 | 21 | 19
Wynn et al. 2007 148 | No completed: | 7 | 16 | 14
Wynn et al. 2007 148 | No analyzed (E): | 11 | 21 | 19
Wynn et al. 2007 148 | No analyzed (S): | 7 | 16 | 14

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 67 Patient flow through trials–haloperidol versus quetiapine

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Arvanitis et al. 1997 46 | Classification | FGA | SGA | SGA | SGA | SGA | SGA
Arvanitis et al. 1997 46 | Medication | Haloperidol | Quetiapine | Quetiapine | Quetiapine | Quetiapine | Quetiapine
Arvanitis et al. 1997 46 | Dosage | 12mg/d | 75mg/d | 150mg/d | 300mg/d | 600mg/d | 750mg/d
Arvanitis et al. 1997 46 | No screened: | 402
Arvanitis et al. 1997 46 | No randomized: | 52 | 53 | 48 | 52 | 51 | 54
Arvanitis et al. 1997 46 | No completed: | 18 | 17 | 21 | 24 | 27 | 26
Arvanitis et al. 1997 46 | No analyzed (E): | 50 | 52 | 48 | 51 | 51 | 53
Arvanitis et al. 1997 46 | No analyzed (S): | 52 | 53 | 48 | 52 | 51 | 54
Atmaca et al. 2002 47 | Classification | FGA | SGA
Atmaca et al. 2002 47 | Medication | Haloperidol | Quetiapine
Atmaca et al. 2002 47 | Dosage | 10mg/d | 600mg/d
Atmaca et al. 2002 47 | No screened: | NR
Atmaca et al. 2002 47 | No randomized: | 17 | 18
Atmaca et al. 2002 47 | No completed: | 17 | 18
Atmaca et al. 2002 47 | No analyzed (E): | 17 | 18
Atmaca et al. 2002 47 | No analyzed (S): | 17 | 18
Copolov et al. 2000 68 | Classification | FGA | SGA
Copolov et al. 2000 68 | Medication | Haloperidol | Quetiapine
Copolov et al. 2000 68 | Dosage | 1–16mg/d | 50–800mg/d
Copolov et al. 2000 68 | No screened: | NR
Copolov et al. 2000 68 | No randomized: | 227 | 221
Copolov et al. 2000 68 | No completed: | 147 | 152
Copolov et al. 2000 68 | No analyzed (E): | 218 | 213
Copolov et al. 2000 68 | No analyzed (S): | 227 | 221
Davidson et al. 2009 75 | Classification | FGA | SGA | SGA | SGA
Davidson et al. 2009 75 | Medication | Haloperidol | Olanzapine | Quetiapine | Ziprasidone
Davidson et al. 2009 75 | Dosage | 1–4mg/d | 5–20mg/d | 200–750mg/d | 40–160mg/d
Davidson et al. 2009 75 | No screened: | NR
Davidson et al. 2009 75 | No randomized: | 103 | 104 | 105 | 82
Davidson et al. 2009 75 | No completed: | 52 | 60 | 74 | 45
Davidson et al. 2009 75 | No analyzed (E): | 52 | 60 | 74 | 45
Davidson et al. 2009 75 | No analyzed (S): | 52 | 60 | 74 | 45
Emsley et al. 2000 79 | Classification | FGA | SGA
Emsley et al. 2000 79 | Medication | Haloperidol | Quetiapine
Emsley et al. 2000 79 | Dosage | 5–20mg/d | 600mg/d
Emsley et al. 2000 79 | No screened: | 365
Emsley et al. 2000 79 | No randomized: | 145 | 143
Emsley et al. 2000 79 | No completed: | 135 | 127
Emsley et al. 2000 79 | No analyzed (E): | 141 | 140
Emsley et al. 2000 79 | No analyzed (S): | 141 | 140
Emsley et al. 2005 80 | Classification | FGA | SGA
Emsley et al. 2005 80 | Medication | Haloperidol | Quetiapine
Emsley et al. 2005 80 | Dosage | 5–20mg | 100–800mg
Emsley et al. 2005 80 | No screened: | 47
Emsley et al. 2005 80 | No randomized: | 23 | 22
Emsley et al. 2005 80 | No completed: | 15 | 12
Emsley et al. 2005 80 | No analyzed (E): | 23 | 22
Emsley et al. 2005 80 | No analyzed (S): | 23 | 22
Glick et al. 2005 65 | Classification | FGA | SGA
Glick et al. 2005 65 | Medication | Haloperidol | Quetiapine
Glick et al. 2005 65 | Dosage | 200mg/wk | 500mg/d
Glick et al. 2005 65 | No screened: | NR
Glick et al. 2005 65 | No randomized: | 14 | 21
Glick et al. 2005 65 | No completed: | 5 | 7
Glick et al. 2005 65 | No analyzed (E): | 7 | 15
Glick et al. 2005 65 | No analyzed (S): | 9 | 16
Kahn et al. 2008 91 | Classification | FGA | SGA | SGA | SGA
Kahn et al. 2008 91 | Medication | Haloperidol | Olanzapine | Quetiapine | Ziprasidone
Kahn et al. 2008 91 | Dosage | 1–4mg/d | 5–20mg/d | 200–750mg/d | 40–16mg/d
Kahn et al. 2008 91 | No screened: | 1047
Kahn et al. 2008 91 | No randomized: | 103 | 105 | 104 | 82
Kahn et al. 2008 91 | No completed: | 68 | 82 | 70 | 53
Kahn et al. 2008 91 | No analyzed (E): | 103 | 105 | 104 | 82
Kahn et al. 2008 91 | No analyzed (S): | 103 | 105 | 104 | 82
McCue et al. 2006 73 | Classification | FGA | SGA | SGA | SGA | SGA | SGA
McCue et al. 2006 73 | Medication | Haloperidol | Aripiprazole | Olanzapine | Quetiapine | Risperidone | Ziprasidone
McCue et al. 2006 73 | Dosage | 4–30mg | 10–45mg | 5–40mg | 50–1200mg | 2–9mg | 40–240mg
McCue et al. 2006 73 | No screened: | 584
McCue et al. 2006 73 | No randomized: | 61 | 63 | 62 | 58 | 65 | 59
McCue et al. 2006 73 | No completed: | 53 | 49 | 50 | 50 | 55 | 45
McCue et al. 2006 73 | No analyzed (E): | 57 | 53 | 50 | 52 | 57 | 50
McCue et al. 2006 73 | No analyzed (S): | 57 | 53 | 50 | 52 | 57 | 50
Purdon et al. 2001 123 | Classification | FGA | SGA
Purdon et al. 2001 123 | Medication | Haloperidol | Quetiapine
Purdon et al. 2001 123 | Dosage | 10–20mg/d | 300–600mg/d
Purdon et al. 2001 123 | No screened: | NR
Purdon et al. 2001 123 | No randomized: | 12 | 13
Purdon et al. 2001 123 | No completed: | 3 | 9
Purdon et al. 2001 123 | No analyzed (E): | 12 | 13
Purdon et al. 2001 123 | No analyzed (S): | 12 | 13
Velligan et al. 2002 143 | Classification | FGA | SGA | SGA
Velligan et al. 2002 143 | Medication | Haloperidol | Quetiapine | Quetiapine
Velligan et al. 2002 143 | Dosage | 12mg/d | 300mg/d | 600mg/d
Velligan et al. 2002 143 | No screened: | 301
Velligan et al. 2002 143 | No randomized: | NR | NR | NR
Velligan et al. 2002 143 | No completed: | 15 | 17 | 26
Velligan et al. 2002 143 | No analyzed (E): | 15 | 17 | 26
Velligan et al. 2002 143 | No analyzed (S): | 15 | 17 | 26

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 68 Patient flow through trials–haloperidol versus risperidone

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Apiquian et al. 2008 45 | Classification | FGA | SGA
Apiquian et al. 2008 45 | Medication | Haloperidol | Risperidone
Apiquian et al. 2008 45 | Dosage | 2mg/d | 1mg/d
Apiquian et al. 2008 45 | No screened: | NR
Apiquian et al. 2008 45 | No randomized: | 10 | 10
Apiquian et al. 2008 45 | No completed: | 6 | 9
Apiquian et al. 2008 45 | No analyzed (E): | 6 | 9
Apiquian et al. 2008 45 | No analyzed (S): | 6 | 9
Blin et al. 1996 52 | Classification | FGA | SGA
Blin et al. 1996 52 | Medication | Haloperidol | Risperidone
Blin et al. 1996 52 | Dosage | 4–12mg/d | 4–12mg/d
Blin et al. 1996 52 | No screened: | NR
Blin et al. 1996 52 | No randomized: | 20 | 21
Blin et al. 1996 52 | No completed: | 14 | 17
Blin et al. 1996 52 | No analyzed (E): | 20 | 21
Blin et al. 1996 52 | No analyzed (S): | 20 | 21
Borison et al. 1992 53 | Classification | FGA | SGA
Borison et al. 1992 53 | Medication | Haloperidol | Risperidone
Borison et al. 1992 53 | Dosage | 4–20mg/d | 2–10mg/d
Borison et al. 1992 53 | No screened: | NR
Borison et al. 1992 53 | No randomized: | 12 | 12
Borison et al. 1992 53 | No completed: | NR | NR
Borison et al. 1992 53 | No analyzed (E): | NR | NR
Borison et al. 1992 53 | No analyzed (S): | NR | NR
Cavallaro et al. 2001 59 | Classification | FGA | SGA
Cavallaro et al. 2001 59 | Medication | Haloperidol | Risperidone
Cavallaro et al. 2001 59 | Dosage | 2.5–10mg/d | 2.5–10mg/d
Cavallaro et al. 2001 59 | No screened: | NR
Cavallaro et al. 2001 59 | No randomized: | 16 | 17
Cavallaro et al. 2001 59 | No completed: | 9 | 10
Cavallaro et al. 2001 59 | No analyzed (E): | 14 | 15
Cavallaro et al. 2001 59 | No analyzed (S): | 14 | 15
Ceskova et al. 1993 60 | Classification | FGA | SGA
Ceskova et al. 1993 60 | Medication | Haloperidol | Risperidone
Ceskova et al. 1993 60 | Dosage | 2–20mg/d | 2–20mg/d
Ceskova et al. 1993 60 | No screened: | NR
Ceskova et al. 1993 60 | No randomized: | 31 | 31
Ceskova et al. 1993 60 | No completed: | 28 | 31
Ceskova et al. 1993 60 | No analyzed (E): | 28 | 31
Ceskova et al. 1993 60 | No analyzed (S): | 28 | 31
Chouinard et al. 1993 61 | Classification | FGA | SGA | SGA | SGA | SGA
Chouinard et al. 1993 61 | Medication | Haloperidol | Risperidone | Risperidone | Risperidone | Risperidone
Chouinard et al. 1993 61 | Dosage | 20mg/d | 2mg/d | 6mg/d | 10mg/d | 16mg/d
Chouinard et al. 1993 61 | No screened: | NR
Chouinard et al. 1993 61 | No randomized: | 21 | 24 | 22 | 22 | 24
Chouinard et al. 1993 61 | No completed: | 8 | 7 | 17 | 14 | 18
Chouinard et al. 1993 61 | No analyzed (E): | 21 | 24 | 22 | 22 | 24
Chouinard et al. 1993 61 | No analyzed (S): | 21 | 24 | 22 | 22 | 24
Citrome et al. 2001 62 | Classification | FGA | SGA | SGA | SGA
Citrome et al. 2001 62 | Medication | Haloperidol | Clozapine | Olanzapine | Risperidone
Citrome et al. 2001 62 | Dosage | 10–30mg/d | 200–800mg/d | 10–40mg/d | 4–16mg/d
Citrome et al. 2001 62 | No screened: | NR
Citrome et al. 2001 62 | No randomized: | 37 | 40 | 39 | 41
Citrome et al. 2001 62 | No completed: | 27 | 32 | 30 | 28
Citrome et al. 2001 62 | No analyzed (E): | 37 | 40 | 39 | 41
Citrome et al. 2001 62 | No analyzed (S): | 37 | 40 | 39 | 41
Claus et al. 1992 64 | Classification | FGA | SGA
Claus et al. 1992 64 | Medication | Haloperidol | Risperidone
Claus et al. 1992 64 | Dosage | 1–10mg/d | 1–10mg/d
Claus et al. 1992 64 | No screened: | NR
Claus et al. 1992 64 | No randomized: | 21 | 21
Claus et al. 1992 64 | No completed: | 16 | 20
Claus et al. 1992 64 | No analyzed (E): | 21 | 21
Claus et al. 1992 64 | No analyzed (S): | 21 | 21
Crespo–Facorro et al. 2006 71 | Classification | FGA | SGA | SGA
Crespo–Facorro et al. 2006 71 | Medication | Haloperidol | Olanzapine | Risperidone
Crespo–Facorro et al. 2006 71 | Dosage | 3–9mg/d | 5–20mg/d | 3–6mg/d
Crespo–Facorro et al. 2006 71 | No screened: | 202
Crespo–Facorro et al. 2006 71 | No randomized: | 56 | 55 | 61
Crespo–Facorro et al. 2006 71 | No completed: | 55 | 53 | 57
Crespo–Facorro et al. 2006 71 | No analyzed (E): | 56 | 55 | 61
Crespo–Facorro et al. 2006 71 | No analyzed (S): | 56 | 55 | 61
Csernansky et al. 2002 72 | Classification | FGA | SGA
Csernansky et al. 2002 72 | Medication | Haloperidol | Risperidone
Csernansky et al. 2002 72 | Dosage | 5–20mg/d | 2–8mg/d
Csernansky et al. 2002 72 | No screened: | NR
Csernansky et al. 2002 72 | No randomized: | 188 | 177
Csernansky et al. 2002 72 | No completed: | 89 | 99
Csernansky et al. 2002 72 | No analyzed (E): | 188 | 177
Csernansky et al. 2002 72 | No analyzed (S): | 187 | 173
de Sena et al. 2003 77 | Classification | FGA | SGA
de Sena et al. 2003 77 | Medication | Haloperidol | Risperidone
de Sena et al. 2003 77 | Dosage | 5–17mg/d | 1–6mg/d
de Sena et al. 2003 77 | No screened: | NR
de Sena et al. 2003 77 | No randomized: | 13 | 20
de Sena et al. 2003 77 | No completed: | 12 | 18
de Sena et al. 2003 77 | No analyzed (E): | 12 | 18
de Sena et al. 2003 77 | No analyzed (S): | NR | NR
Emsley et al. 1999 81 | Classification | FGA | SGA
Emsley et al. 1999 81 | Medication | Haloperidol | Risperidone
Emsley et al. 1999 81 | Dosage | 2–10mg/d | 2–10mg/d
Emsley et al. 1999 81 | No screened: | NR
Emsley et al. 1999 81 | No randomized: | 84 | 99
Emsley et al. 1999 81 | No completed: | 58 | 79
Emsley et al. 1999 81 | No analyzed (E): | 84 | 98
Emsley et al. 1999 81 | No analyzed (S): | 84 | 98
Fakra et al. 2008 82 | Classification | FGA | SGA
Fakra et al. 2008 82 | Medication | Haloperidol | Risperidone
Fakra et al. 2008 82 | Dosage | NR | NR
Fakra et al. 2008 82 | No screened: | NR
Fakra et al. 2008 82 | No randomized: | 15 | 15
Fakra et al. 2008 82 | No completed: | 14 | 11
Fakra et al. 2008 82 | No analyzed (E): | 14 | 11
Fakra et al. 2008 82 | No analyzed (S): | 14 | 11
Heck et al. 2000 85 | Classification | FGA | SGA
Heck et al. 2000 85 | Medication | Haloperidol | Risperidone
Heck et al. 2000 85 | Dosage | 3–24mg/d | 2–16mg/d
Heck et al. 2000 85 | No screened: | NR
Heck et al. 2000 85 | No randomized: | 37 | 40
Heck et al. 2000 85 | No completed: | 22 | 25
Heck et al. 2000 85 | No analyzed (E): | 37 | 40
Heck et al. 2000 85 | No analyzed (S): | 37 | 40
Kee et al. 1998 99 | Classification | FGA | SGA
Kee et al. 1998 99 | Medication | Haloperidol | Risperidone
Kee et al. 1998 99 | Dosage | 15mg/d | 6mg/d
Kee et al. 1998 99 | No screened: | NR
Kee et al. 1998 99 | No randomized: | 10 | 10
Kee et al. 1998 99 | No completed: | 9 | 9
Kee et al. 1998 99 | No analyzed (E): | 9 | 9
Kee et al. 1998 99 | No analyzed (S): | 9 | 9
Keefe et al. 2003 100 | Classification | FGA | SGA | SGA
Keefe et al. 2003 100 | Medication | Haloperidol | Olanzapine | Risperidone
Keefe et al. 2003 100 | Dosage | 2.5–10.0mg/d | 2.5–10.0mg/d | 2.0–8.0mg/d
Keefe et al. 2003 100 | No screened: | 49
Keefe et al. 2003 100 | No randomized: | 4 | 7 | 5
Keefe et al. 2003 100 | No completed: | 4 | 7 | 5
Keefe et al. 2003 100 | No analyzed (E): | 4 | 7 | 5
Keefe et al. 2003 100 | No analyzed (S): | NR | NR | NR
Keefe et al. 2006 101 | Classification | FGA | SGA | SGA
Keefe et al. 2006 101 | Medication | Haloperidol | Olanzapine | Risperidone
Keefe et al. 2006 101 | Dosage | 2–19mg/d | 5–20mg/d | 2–10mg/d
Keefe et al. 2006 101 | No screened: | 414
Keefe et al. 2006 101 | No randomized: | 97 | 159 | 158
Keefe et al. 2006 101 | No completed: | 27 | 64 | 54
Keefe et al. 2006 101 | No analyzed (E): | 94 | 153 | 148
Keefe et al. 2006 101 | No analyzed (S): | 97 | 159 | 158
Kim et al. 2010 102 | Classification | FGA | SGA | SGA | SGA
Kim et al. 2010 102 | Medication | Haloperidol | Aripiprazole | Olanzapine | Risperidone
Kim et al. 2010 102 | Dosage | 15.9+/−7.1mg/d | 21.7+/−5.5mg/d | 15.9+/−4.3mg/d | 4.8+/−2.9mg/d
Kim et al. 2010 102 | No screened: | NR
Kim et al. 2010 102 | No randomized: | 35 | 31 | 32 | 41
Kim et al. 2010 102 | No completed: | NR | NR | NR | NR
Kim et al. 2010 102 | No analyzed (E): | NR | NR | NR | NR
Kim et al. 2010 102 | No analyzed (S): | NR | NR | NR | NR
Lee et al. 2007 107 | Classification | FGA | SGA
Lee et al. 2007 107 | Medication | Haloperidol | Risperidone
Lee et al. 2007 107 | Dosage | 7.6+/−2.6mg/d | 4.1+/−0.8mg/d
Lee et al. 2007 107 | No screened: | 68
Lee et al. 2007 107 | No randomized: | 10 | 10
Lee et al. 2007 107 | No completed: | 10 | 10
Lee et al. 2007 107 | No analyzed (E): | 10 | 10
Lee et al. 2007 107 | No analyzed (S): | 10 | 10
Lim et al. 2010 151 | Classification | FGA | SGA
Lim et al. 2010 151 | Medication | Haloperidol | Risperidone
Lim et al. 2010 151 | Dosage | 5–15mg | 2–6mg
Lim et al. 2010 151 | No screened: | 144
Lim et al. 2010 151 | No randomized: | 62 | 62
Lim et al. 2010 151 | No completed: | 62 | 62
Lim et al. 2010 151 | No analyzed (E): | 62 | 62
Lim et al. 2010 151 | No analyzed (S): | 62 | 62
Liu et al. 2000 111 | Classification | FGA | SGA
Liu et al. 2000 111 | Medication | Haloperidol | Risperidone
Liu et al. 2000 111 | Dosage | NR | NR
Liu et al. 2000 111 | No screened: | 56
Liu et al. 2000 111 | No randomized: | 28 | 28
Liu et al. 2000 111 | No completed: | 19 | 21
Liu et al. 2000 111 | No analyzed (E): | 19 | 19
Liu et al. 2000 111 | No analyzed (S): | 19 | 19
Marder et al. 1994 114 | Classification | FGA | SGA | SGA | SGA | SGA
Marder et al. 1994 114 | Medication | Haloperidol | Risperidone | Risperidone | Risperidone | Risperidone
Marder et al. 1994 114 | Dosage | 20mg/d | 2mg/d | 6mg/d | 10mg/d | 16mg/d
Marder et al. 1994 114 | No screened: | 388
Marder et al. 1994 114 | No randomized: | 66 | 63 | 64 | 65 | 64
Marder et al. 1994 114 | No completed: | 28 | 29 | 35 | 34 | 36
Marder et al. 1994 114 | No analyzed (E): | 64 | 63 | 63 | 63 | 61
Marder et al. 1994 114 | No analyzed (S): | 66 | 63 | 64 | 65 | 64
Marder et al. 2003 113 | Classification | FGA | SGA
Marder et al. 2003 113 | Medication | Haloperidol | Risperidone
Marder et al. 2003 113 | Dosage | 2mg TID for the first week; then 6mg HS | 2mg TID for the first week; then 6mg HS
Marder et al. 2003 113 | No screened: | 110
Marder et al. 2003 113 | No randomized: | 30 | 33
Marder et al. 2003 113 | No completed: | 11 | 18
Marder et al. 2003 113 | No analyzed (E): | 11 | 18
Marder et al. 2003 113 | No analyzed (S): | 30 | 33
McCue et al. 2006 73 | Classification | FGA | SGA | SGA | SGA | SGA | SGA
McCue et al. 2006 73 | Medication | Haloperidol | Aripiprazole | Olanzapine | Quetiapine | Risperidone | Ziprasidone
McCue et al. 2006 73 | Dosage | 4–30mg | 10–45mg | 5–40mg | 50–1200mg | 2–9mg | 40–240mg
McCue et al. 2006 73 | No screened: | 584
McCue et al. 2006 73 | No randomized: | 61 | 63 | 62 | 58 | 65 | 59
McCue et al. 2006 73 | No completed: | 53 | 49 | 50 | 50 | 55 | 45
McCue et al. 2006 73 | No analyzed (E): | 57 | 53 | 50 | 52 | 57 | 50
McCue et al. 2006 73 | No analyzed (S): | 57 | 53 | 50 | 52 | 57 | 50
Min et al. 1993 117 | Classification | FGA | SGA
Min et al. 1993 117 | Medication | Haloperidol | Risperidone
Min et al. 1993 117 | Dosage | 2.5–5mg/d | 2.5–5mg/d
Min et al. 1993 117 | No screened: | 35
Min et al. 1993 117 | No randomized: | 19 | 16
Min et al. 1993 117 | No completed: | 19 | 13
Min et al. 1993 117 | No analyzed (E): | 19 | 16
Min et al. 1993 117 | No analyzed (S): | 19 | 16
Moller et al. 2008 118 | Classification | FGA | SGA
Moller et al. 2008 118 | Medication | Haloperidol | Risperidone
Moller et al. 2008 118 | Dosage | 2–8mg/d | 2–8mg/d
Moller et al. 2008 118 | No screened: | 1372
Moller et al. 2008 118 | No randomized: | 148 | 148
Moller et al. 2008 118 | No completed: | 67 | 88
Moller et al. 2008 118 | No analyzed (E): | 146 | 143
Moller et al. 2008 118 | No analyzed (S): | 146 | 143
Peuskens et al. 1995 120 | Classification | FGA | SGA | SGA | SGA | SGA | SGA
Peuskens et al. 1995 120 | Medication | Haloperidol | Risperidone | Risperidone | Risperidone | Risperidone | Risperidone
Peuskens et al. 1995 120 | Dosage | 10mg/d | 1mg/d | 4mg/d | 8mg/d | 12mg/d | 16mg/d
Peuskens et al. 1995 120 | No screened: | 1362
Peuskens et al. 1995 120 | No randomized: | 226 | 229 | 227 | 230 | 226 | 224
Peuskens et al. 1995 120 | No completed: | 163 | 171 | 182 | 174 | 164 | 165
Peuskens et al. 1995 120 | No analyzed (E): | 223 | 226 | 227 | 228 | 225 | 223
Peuskens et al. 1995 120 | No analyzed (S): | 225 | 226 | 227 | 228 | 225 | 224
Purdon et al. 2000 124 | Classification | FGA | SGA | SGA
Purdon et al. 2000 124 | Medication | Haloperidol | Olanzapine | Risperidone
Purdon et al. 2000 124 | Dosage | 5–20mg/d | 5–20mg/d | 2–6mg/d
Purdon et al. 2000 124 | No screened: | NR
Purdon et al. 2000 124 | No randomized: | 23 | 21 | 21
Purdon et al. 2000 124 | No completed: | 9 | 12 | 7
Purdon et al. 2000 124 | No analyzed (E): | 23 | 21 | 21
Purdon et al. 2000 124 | No analyzed (S): | 23 | 21 | 21
Remillard et al. 2008 125 | Classification | FGA | SGA
Remillard et al. 2008 125 | Medication | Haloperidol | Risperidone
Remillard et al. 2008 125 | Dosage | 2–40mg/d | 2–6mg/d
Remillard et al. 2008 125 | No screened: | NR
Remillard et al. 2008 125 | No randomized: | 14 | 14
Remillard et al. 2008 125 | No completed: | 14 | 14
Remillard et al. 2008 125 | No analyzed (E): | 14 | 14
Remillard et al. 2008 125 | No analyzed (S): | NR | NR
Schooler et al. 2005 132 | Classification | FGA | SGA
Schooler et al. 2005 132 | Medication | Haloperidol | Risperidone
Schooler et al. 2005 132 | Dosage | 1–8mg/d | 1–8mg/d
Schooler et al. 2005 132 | No screened: | NR
Schooler et al. 2005 132 | No randomized: | 277 | 278
Schooler et al. 2005 132 | No completed: | 176 | 161
Schooler et al. 2005 132 | No analyzed (E): | 267 | 266
Schooler et al. 2005 132 | No analyzed (S): | 276 | 278
Sergi et al. 2007 134 | Classification | FGA | SGA | SGA
Sergi et al. 2007 134 | Medication | Haloperidol | Olanzapine | Risperidone
Sergi et al. 2007 134 | Dosage | 8mg/d | 15mg/d | 4mg/d
Sergi et al. 2007 134 | No screened: | NR
Sergi et al. 2007 134 | No randomized: | 20 | 40 | 40
Sergi et al. 2007 134 | No completed: | 12 | 22 | 25
Sergi et al. 2007 134 | No analyzed (E): | 13 | 28 | 32
Sergi et al. 2007 134 | No analyzed (S): | 13 | 28 | 32
Shrivastava et al. 2000 135 | Classification | FGA | SGA
Shrivastava et al. 2000 135 | Medication | Haloperidol | Risperidone
Shrivastava et al. 2000 135 | Dosage | 5–15mg/d | 2mg/d
Shrivastava et al. 2000 135 | No screened: | NR
Shrivastava et al. 2000 135 | No randomized: | NR | NR
Shrivastava et al. 2000 135 | No completed: | 50 | 50
Shrivastava et al. 2000 135 | No analyzed (E): | 50 | 50
Shrivastava et al. 2000 135 | No analyzed (S): | NR | NR
Tamrakar et al. 2006 139 | Classification | FGA | SGA
Tamrakar et al. 2006 139 | Medication | Haloperidol | Risperidone
Tamrakar et al. 2006 139 | Dosage | 10–20mg/d | 4–6mg/d
Tamrakar et al. 2006 139 | No screened: | NR
Tamrakar et al. 2006 139 | No randomized: | 18 | 18
Tamrakar et al. 2006 139 | No completed: | 18 | 18
Tamrakar et al. 2006 139 | No analyzed (E): | 18 | 18
Tamrakar et al. 2006 139 | No analyzed (S): | 18 | 18
Volakva et al. 2002 145 | Classification | FGA | SGA | SGA | SGA
Volakva et al. 2002 145 | Medication | Haloperidol | Clozapine | Olanzapine | Risperidone
Volakva et al. 2002 145 | Dosage | 10–30mg/d | 200–800mg/d | 10–40mg/d | 4–16mg/d
Volakva et al. 2002 145 | No screened: | NR
Volakva et al. 2002 145 | No randomized: | 37 | 40 | 39 | 41
Volakva et al. 2002 145 | No completed: | 21 | 22 | 26 | 22
Volakva et al. 2002 145 | No analyzed (E): | 37 | 40 | 39 | 41
Volakva et al. 2002 145 | No analyzed (S): | 37 | 40 | 39 | 41
Wirshing et al. 1999 146 | Classification | FGA | SGA
Wirshing et al. 1999 146 | Medication | Haloperidol | Risperidone
Wirshing et al. 1999 146 | Dosage | 15mg/d | 6mg/d
Wirshing et al. 1999 146 | No screened: | NR
Wirshing et al. 1999 146 | No randomized: | 33 | 34
Wirshing et al. 1999 146 | No completed: | 28 | 28
Wirshing et al. 1999 146 | No analyzed (E): | 32 | 33
Wirshing et al. 1999 146 | No analyzed (S): | 32 | 33
Wynn et al. 2007 148 | Classification | FGA | SGA | SGA
Wynn et al. 2007 148 | Medication | Haloperidol | Olanzapine | Risperidone
Wynn et al. 2007 148 | Dosage | 8mg/d | 15mg/d | 4mg/d
Wynn et al. 2007 148 | No screened: | 100
Wynn et al. 2007 148 | No randomized: | 11 | 21 | 19
Wynn et al. 2007 148 | No completed: | 7 | 16 | 14
Wynn et al. 2007 148 | No analyzed (E): | 11 | 21 | 19
Wynn et al. 2007 148 | No analyzed (S): | 7 | 16 | 14
Yen et al. 2004 149 | Classification | FGA | SGA
Yen et al. 2004 149 | Medication | Haloperidol | Risperidone
Yen et al. 2004 149 | Dosage | 4–20mg/d | 2–12mg/d
Yen et al. 2004 149 | No screened: | 41
Yen et al. 2004 149 | No randomized: | 20 | 21
Yen et al. 2004 149 | No completed: | 13 | 14
Yen et al. 2004 149 | No analyzed (E): | 20 | 21
Yen et al. 2004 149 | No analyzed (S): | 20 | 21
Zhang et al. 2001 150 | Classification | FGA | SGA
Zhang et al. 2001 150 | Medication | Haloperidol | Risperidone
Zhang et al. 2001 150 | Dosage | 6mg/d | 20mg/d
Zhang et al. 2001 150 | No screened: | NR
Zhang et al. 2001 150 | No randomized: | 37 | 41
Zhang et al. 2001 150 | No completed: | 33 | 40
Zhang et al. 2001 150 | No analyzed (E): | 37 | 41
Zhang et al. 2001 150 | No analyzed (S): | 37 | 41

d = day; E = efficacy; FGA = first-generation antipsychotic; HS = half strength; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic; TID = three times daily

Table 69 Patient flow through trials–haloperidol versus ziprasidone

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Brook et al. 2005 57 | Classification | FGA | SGA
Brook et al. 2005 57 | Medication | Haloperidol | Ziprasidone
Brook et al. 2005 57 | Dosage | IM: 2.5–10mg/d; Oral: 5–20mg/d | IM: 10–40mg/d; Oral: 40–80mg/d
Brook et al. 2005 57 | No screened: | 621
Brook et al. 2005 57 | No randomized: | 138 | 429
Brook et al. 2005 57 | No completed: | 91 | 292
Brook et al. 2005 57 | No analyzed (E): | 138 | 429
Brook et al. 2005 57 | No analyzed (S): | 138 | 429
Corripio et al. 2005 69 | Classification | FGA | SGA
Corripio et al. 2005 69 | Medication | Haloperidol | Ziprasidone
Corripio et al. 2005 69 | Dosage | 5–20mg/d | 10–40mg/d
Corripio et al. 2005 69 | No screened: | NR
Corripio et al. 2005 69 | No randomized: | 10 | 10
Corripio et al. 2005 69 | No completed: | 10 | 10
Corripio et al. 2005 69 | No analyzed (E): | 10 | 10
Corripio et al. 2005 69 | No analyzed (S): | 10 | 10
Davidson et al. 2009 75 | Classification | FGA | SGA | SGA | SGA
Davidson et al. 2009 75 | Medication | Haloperidol | Olanzapine | Quetiapine | Ziprasidone
Davidson et al. 2009 75 | Dosage | 1–4mg/d | 5–20mg/d | 200–750mg/d | 40–160mg/d
Davidson et al. 2009 75 | No screened: | NR
Davidson et al. 2009 75 | No randomized: | 103 | 104 | 105 | 82
Davidson et al. 2009 75 | No completed: | 52 | 60 | 74 | 45
Davidson et al. 2009 75 | No analyzed (E): | 52 | 60 | 74 | 45
Davidson et al. 2009 75 | No analyzed (S): | 52 | 60 | 74 | 45
Goff et al. 1998 83 | Classification | FGA | SGA | SGA | SGA | SGA
Goff et al. 1998 83 | Medication | Haloperidol | Ziprasidone | Ziprasidone | Ziprasidone | Ziprasidone
Goff et al. 1998 83 | Dosage | 15mg/d | 4mg/d | 10mg/d | 40mg/d | 160mg/d
Goff et al. 1998 83 | No screened: | NR
Goff et al. 1998 83 | No randomized: | 17 | 19 | 17 | 17 | 20
Goff et al. 1998 83 | No completed: | 9 | 9 | 6 | 8 | 12
Goff et al. 1998 83 | No analyzed (E): | 17 | 19 | 17 | 17 | 20
Goff et al. 1998 83 | No analyzed (S): | 17 | 19 | 17 | 17 | 20
Hirsch et al. 2002 86 | Classification | FGA | SGA
Hirsch et al. 2002 86 | Medication | Haloperidol | Ziprasidone
Hirsch et al. 2002 86 | Dosage | 5–15mg/d | 80–160mg/d
Hirsch et al. 2002 86 | No screened: | 363
Hirsch et al. 2002 86 | No randomized: | 153 | 148
Hirsch et al. 2002 86 | No completed: | 64 | 66
Hirsch et al. 2002 86 | No analyzed (E): | 117 | 110
Hirsch et al. 2002 86 | No analyzed (S): | 117 | 110
Kahn et al. 2008 91 | Classification | FGA | SGA | SGA | SGA
Kahn et al. 2008 91 | Medication | Haloperidol | Olanzapine | Quetiapine | Ziprasidone
Kahn et al. 2008 91 | Dosage | 1–4mg/d | 5–20mg/d | 200–750mg/d | 40–16mg/d
Kahn et al. 2008 91 | No screened: | 1047
Kahn et al. 2008 91 | No randomized: | 103 | 105 | 104 | 82
Kahn et al. 2008 91 | No completed: | 68 | 82 | 70 | 53
Kahn et al. 2008 91 | No analyzed (E): | 103 | 105 | 104 | 82
Kahn et al. 2008 91 | No analyzed (S): | 103 | 105 | 104 | 82
McCue et al. 2006 73 | Classification | FGA | SGA | SGA | SGA | SGA | SGA
McCue et al. 2006 73 | Medication | Haloperidol | Aripiprazole | Olanzapine | Quetiapine | Risperidone | Ziprasidone
McCue et al. 2006 73 | Dosage | 4–30mg | 10–45mg | 5–40mg | 50–1200mg | 2–9mg | 40–240mg
McCue et al. 2006 73 | No screened: | 584
McCue et al. 2006 73 | No randomized: | 61 | 63 | 62 | 58 | 65 | 59
McCue et al. 2006 73 | No completed: | 53 | 49 | 50 | 50 | 55 | 45
McCue et al. 2006 73 | No analyzed (E): | 57 | 53 | 50 | 52 | 57 | 50
McCue et al. 2006 73 | No analyzed (S): | 57 | 53 | 50 | 52 | 57 | 50
Miceli et al. 2010 116 | Classification | FGA | SGA
Miceli et al. 2010 116 | Medication | Haloperidol | Ziprasidone
Miceli et al. 2010 116 | Dosage | 7.5–10mg | 20–30mg
Miceli et al. 2010 116 | No screened: | 87
Miceli et al. 2010 116 | No randomized: | 27 | 31
Miceli et al. 2010 116 | No completed: | 24 | 25
Miceli et al. 2010 116 | No analyzed (E): | 27 | 31
Miceli et al. 2010 116 | No analyzed (S): | 27 | 31
Potkin et al. 2009 122 | Classification | FGA | SGA | SGA
Potkin et al. 2009 122 | Medication | Haloperidol | Ziprasidone | Ziprasidone
Potkin et al. 2009 122 | Dosage | 5–20mg/d | 80–120mg/d | 80–160mg/d
Potkin et al. 2009 122 | No screened: | NR
Potkin et al. 2009 122 | No randomized: | 151 | 221 | 227
Potkin et al. 2009 122 | No completed: | 16 | 28 | 25
Potkin et al. 2009 122 | No analyzed (E): | 47 | 67 | 72
Potkin et al. 2009 122 | No analyzed (S): | 47 | 67 | 72

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 70 Patient flow through trials–perphenazine versus aripiprazole

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Kane et al. 2007 93 | Classification | FGA | SGA
Kane et al. 2007 93 | Medication | Perphenazine | Aripiprazole
Kane et al. 2007 93 | Dosage | 8–64mg/d | 15–30mg/d
Kane et al. 2007 93 | No screened: | 512
Kane et al. 2007 93 | No randomized: | 146 | 154
Kane et al. 2007 93 | No completed: | 115 | 110
Kane et al. 2007 93 | No analyzed (E): | 144 | 150
Kane et al. 2007 93 | No analyzed (S): | 144 | 150

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 71 Patient flow through trials–perphenazine versus olanzapine

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Ascher–Svanum et al. 2008 131 | Classification | FGA | SGA
Ascher–Svanum et al. 2008 131 | Medication | Perphenazine | Olanzapine
Ascher–Svanum et al. 2008 131 | Dosage | NR | NR
Ascher–Svanum et al. 2008 131 | No screened: | NR
Ascher–Svanum et al. 2008 131 | No randomized: | 48 | 229
Ascher–Svanum et al. 2008 131 | No completed: | 48 | 222
Ascher–Svanum et al. 2008 131 | No analyzed (E): | 48 | 222
Ascher–Svanum et al. 2008 131 | No analyzed (S): | NR | NR
Lieberman et al. 2005 23 | Classification | FGA | SGA | SGA | SGA | SGA
Lieberman et al. 2005 23 | Medication | Perphenazine | Olanzapine | Quetiapine | Risperidone | Ziprasidone
Lieberman et al. 2005 23 | Dosage | 8–32mg/d | 7.5–30mg/d | 200–800mg/d | 1.5–6.0mg/d | 40–160mg/d
Lieberman et al. 2005 23 | No screened: | 1894
Lieberman et al. 2005 23 | No randomized: | 261 | 336 | 337 | 341 | 185
Lieberman et al. 2005 23 | No completed: | 65 | 120 | 60 | 88 | 38
Lieberman et al. 2005 23 | No analyzed (E): | 257 | 330 | 329 | 333 | 183
Lieberman et al. 2005 23 | No analyzed (S): | 261 | 336 | 337 | 341 | 185

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 72 Patient flow through trials–perphenazine versus quetiapine

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Lieberman et al. 2005 23 | Classification | FGA | SGA | SGA | SGA | SGA
Lieberman et al. 2005 23 | Medication | Perphenazine | Olanzapine | Quetiapine | Risperidone | Ziprasidone
Lieberman et al. 2005 23 | Dosage | 8–32mg/d | 7.5–30mg/d | 200–800mg/d | 1.5–6.0mg/d | 40–160mg/d
Lieberman et al. 2005 23 | No screened: | 1894
Lieberman et al. 2005 23 | No randomized: | 261 | 336 | 337 | 341 | 185
Lieberman et al. 2005 23 | No completed: | 65 | 120 | 60 | 88 | 38
Lieberman et al. 2005 23 | No analyzed (E): | 257 | 330 | 329 | 333 | 183
Lieberman et al. 2005 23 | No analyzed (S): | 261 | 336 | 337 | 341 | 185

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 73 Patient flow through trials–perphenazine versus risperidone

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Ascher–Svanum et al. 2008 131 | Classification | FGA | SGA
Ascher–Svanum et al. 2008 131 | Medication | Perphenazine | Risperidone
Ascher–Svanum et al. 2008 131 | Dosage | NR | NR
Ascher–Svanum et al. 2008 131 | No screened: | NR
Ascher–Svanum et al. 2008 131 | No randomized: | 48 | 221
Ascher–Svanum et al. 2008 131 | No completed: | 48 | 217
Ascher–Svanum et al. 2008 131 | No analyzed (E): | 48 | 217
Ascher–Svanum et al. 2008 131 | No analyzed (S): | NR | NR
Lieberman et al. 2005 23 | Classification | FGA | SGA | SGA | SGA | SGA
Lieberman et al. 2005 23 | Medication | Perphenazine | Olanzapine | Quetiapine | Risperidone | Ziprasidone
Lieberman et al. 2005 23 | Dosage | 8–32mg/d | 7.5–30mg/d | 200–800mg/d | 1.5–6.0mg/d | 40–160mg/d
Lieberman et al. 2005 23 | No screened: | 1894
Lieberman et al. 2005 23 | No randomized: | 261 | 336 | 337 | 341 | 185
Lieberman et al. 2005 23 | No completed: | 65 | 120 | 60 | 88 | 38
Lieberman et al. 2005 23 | No analyzed (E): | 257 | 330 | 329 | 333 | 183
Lieberman et al. 2005 23 | No analyzed (S): | 261 | 336 | 337 | 341 | 185

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 74 Patient flow through trials–trifluoperazine versus clozapine

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Rinieris et al. 1980 157 | Classification | FGA | FGA | SGA
Rinieris et al. 1980 157 | Medication | Chlorpromazine | Trifluoperazine | Clozapine
Rinieris et al. 1980 157 | Dosage | 50–100mg | 2.5–5mg | 50–100mg
Rinieris et al. 1980 157 | No screened: | NR
Rinieris et al. 1980 157 | No randomized: | 16 | 20 | 5
Rinieris et al. 1980 157 | No completed: | 10 | 9 | 5
Rinieris et al. 1980 157 | No analyzed (E): | 10 | 9 | 5
Rinieris et al. 1980 157 | No analyzed (S): | 10 | 9 | 5

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

## B Bipolar Disorder

Table 75 Patient flow through trials–chlorpromazine versus clozapine

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Barbini et al. 1997 48 | Classification | FGA | FGA
Barbini et al. 1997 48 | Medication | Chlorpromazine | Clozapine
Barbini et al. 1997 48 | Dosage | 2mg/kg/d | 25mg/d
Barbini et al. 1997 48 | No screened: | NR
Barbini et al. 1997 48 | No randomized: | 15 | 15
Barbini et al. 1997 48 | No completed: | 12 | 15
Barbini et al. 1997 48 | No analyzed (E): | 12 | 15
Barbini et al. 1997 48 | No analyzed (S): | 12 | 15

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 76 Patient flow through trials–haloperidol versus aripiprazole

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Vieta et al. 2005 32 | Classification | FGA | FGA
Vieta et al. 2005 32 | Medication | Haloperidol | Aripiprazole
Vieta et al. 2005 32 | Dosage | 10–15mg/d | 15–30mg/d
Vieta et al. 2005 32 | No screened: | NR
Vieta et al. 2005 32 | No randomized: | 172 | 175
Vieta et al. 2005 32 | No completed: | 50 | 89
Vieta et al. 2005 32 | No analyzed (E): | 164 | 174
Vieta et al. 2005 32 | No analyzed (S): | 169 | 175
Young et al. 2009 33 | Classification | FGA | FGA
Young et al. 2009 33 | Medication | Haloperidol | Aripiprazole
Young et al. 2009 33 | Dosage | 5–10mg/d | 15–30mg/d
Young et al. 2009 33 | No screened: | NR
Young et al. 2009 33 | No randomized: | 165 | 167
Young et al. 2009 33 | No completed: | 95 | 95
Young et al. 2009 33 | No analyzed (E): | 161 | 166
Young et al. 2009 33 | No analyzed (S): | 165 | 166

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 77 Patient flow through trials–haloperidol versus olanzapine

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Moreno et al. 2007 119 | Classification | FGA | FGA
Moreno et al. 2007 119 | Medication | Haloperidol | Olanzapine
Moreno et al. 2007 119 | Dosage | 3–15mg/d | 5–20mg/d
Moreno et al. 2007 119 | No screened: | 19
Moreno et al. 2007 119 | No randomized: | 5 | 7
Moreno et al. 2007 119 | No completed: | 5 | 7
Moreno et al. 2007 119 | No analyzed (E): | 5 | 7
Moreno et al. 2007 119 | No analyzed (S): | 5 | 7
Tohen et al. 2003 140 | Classification | FGA | FGA
Tohen et al. 2003 140 | Medication | Haloperidol | Olanzapine
Tohen et al. 2003 140 | Dosage | 3–15mg/d | 5–20mg/d
Tohen et al. 2003 140 | No screened: | 498
Tohen et al. 2003 140 | No randomized: | 219 | 234
Tohen et al. 2003 140 | No completed: | 116 | 140
Tohen et al. 2003 140 | No analyzed (E): | 219 | 234
Tohen et al. 2003 140 | No analyzed (S): | 219 | 234

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 78 Patient flow through trials–haloperidol versus quetiapine

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
McIntyre et al. 2005 115 | Classification | FGA | FGA
McIntyre et al. 2005 115 | Medication | Haloperidol | Quetiapine
McIntyre et al. 2005 115 | Dosage | 2–8mg/d | 100–800mg/d
McIntyre et al. 2005 115 | No screened: | NR
McIntyre et al. 2005 115 | No randomized: | 99 | 102
McIntyre et al. 2005 115 | No completed: | 54 | 55
McIntyre et al. 2005 115 | No analyzed (E): | 98 | 101
McIntyre et al. 2005 115 | No analyzed (S): | 98 | 101

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 79 Patient flow through trials–haloperidol versus risperidone

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Janicak et al. 2001 90 | Classification | FGA | FGA
Janicak et al. 2001 90 | Medication | Haloperidol | Risperidone
Janicak et al. 2001 90 | Dosage | 2–10mg/d | 1–5mg/d
Janicak et al. 2001 90 | No screened: | 62
Janicak et al. 2001 90 | No randomized: | 32 | 30
Janicak et al. 2001 90 | No completed: | 13 | 12
Janicak et al. 2001 90 | No analyzed (E): | 32 | 30
Janicak et al. 2001 90 | No analyzed (S): | 32 | 30
Sachs et al. 2002 128 | Classification | FGA | FGA
Sachs et al. 2002 128 | Medication | Haloperidol | Risperidone
Sachs et al. 2002 128 | Dosage | 4–12 mg/d | 2–6 mg/d
Sachs et al. 2002 128 | No screened: | 156
Sachs et al. 2002 128 | No randomized: | 53 | 52
Sachs et al. 2002 128 | No completed: | 25 | 34
Sachs et al. 2002 128 | No analyzed (E): | 53 | 52
Sachs et al. 2002 128 | No analyzed (S): | 53 | 52
Segal et al. 1998 133 | Classification | FGA | FGA
Segal et al. 1998 133 | Medication | Haloperidol | Risperidone
Segal et al. 1998 133 | Dosage | 10mg/d | 6mg/d
Segal et al. 1998 133 | No screened: | NR
Segal et al. 1998 133 | No randomized: | 15 | 15
Segal et al. 1998 133 | No completed: | 12 | 13
Segal et al. 1998 133 | No analyzed (E): | 15 | 15
Segal et al. 1998 133 | No analyzed (S): | 15 | 15
Smulevich et al. 2005 138 | Classification | FGA | FGA
Smulevich et al. 2005 138 | Medication | Haloperidol | Risperidone
Smulevich et al. 2005 138 | Dosage | 2–12mg/d | 1–6mg/d
Smulevich et al. 2005 138 | No screened: | NR
Smulevich et al. 2005 138 | No randomized: | 144 | 154
Smulevich et al. 2005 138 | No completed: | 56 | 77
Smulevich et al. 2005 138 | No analyzed (E): | 144 | 153
Smulevich et al. 2005 138 | No analyzed (S): | 144 | 153

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic

Table 80 Patient flow through trials–haloperidol versus ziprasidone

| | Intervention #1 | Intervention #2 | Intervention #3 | Intervention #4 | Intervention #5 | Intervention #6
Vieta et al. 2010 144 | Classification | FGA | FGA
Vieta et al. 2010 144 | Medication | Haloperidol | Ziprasidone
Vieta et al. 2010 144 | Dosage | 4–30mg/d | 40–160mg/d
Vieta et al. 2010 144 | No screened: | 540
Vieta et al. 2010 144 | No randomized: | 172 | 178
Vieta et al. 2010 144 | No completed: | 78 | 73
Vieta et al. 2010 144 | No analyzed (E): | 171 | 178
Vieta et al. 2010 144 | No analyzed (S): | 171 | 178

d = day; E = efficacy; FGA = first-generation antipsychotic; mg = milligram; No = number; NR = not reported; S = safety; SGA = second-generation antipsychotic