# General Study Characteristics

## A Schizophrenia and Related Psychoses

Table 30 Patient characteristics–chlorpromazine versus clozapine

Table 31 Patient characteristics–chlorpromazine versus olanzapine

Table 32 Patient characteristics–chlorpromazine versus quetiapine

Table 33 Patient characteristics–chlorpromazine versus ziprasidone

Table 34 Patient Characteristics–fluphenazine versus olanzapine

Table 35 Patient characteristics–fluphenazine versus quetiapine

Table 36 Patient characteristics–fluphenazine versus risperidone

Table 37 Patient characteristics–haloperidol versus aripiprazole

Table 38 Patient characteristics–haloperidol versus asenapine

Table 39 Patient characteristics–haloperidol versus clozapine

Table 40 Patient characteristics–haloperidol versus olanzapine

Table 41 Patient characteristics–haloperidol versus quetiapine

Table 42 Patient characteristics–haloperidol versus risperidone

Table 43 Patient characteristics–haloperidol versus ziprasidone

Table 44 Patient characteristics–perphenazine versus aripiprazole

Table 45 Patient characteristics–perphenazine versus olanzapine

Table 46 Patient characteristics–perphenazine versus quetiapine

Table 47 Patient characteristics–perphenazine versus risperidone

Table 48 Patient characteristics–perphenazine versus ziprasidone

Table 49 Patient characteristics–trifluoperazine versus clozapine

## B Bipolar Disorder

Table 50 Patient characteristics–chlorpromazine versus clozapine

Table 51 Patient characteristics–haloperidol versus aripiprazole

Table 52 Patient characteristics–haloperidol versus olanzapine

Table 53 Patient characteristics–haloperidol versus quetiapine

Table 54 Patient characteristics–haloperidol versus risperidone

Table 55 Patient characteristics–haloperidol versus ziprasidone