# Newcastle-Ottawa Scale Assessment of Cohort Studies

Table 29 Quality assessment of cohort studies

| | | | | Selection | | Comparability | | Outcome
Author, year | Study design | Representativeness of cohort | Selection of non-exposed cohort | Ascertainment of exposure | Outcome of interest | Comparability of cohorts | Assessment of outcome | Adequate duration of followup | Adequate followup of cohort | Total score
Gaszner 2004 162 | Retrospective cohort study | A (1*) | A (1*) | A (1*) | A (1*) | A (1*) | B (1*) | A (1*) | A (1*) | 8
Hennessy 2002 163 | Retrospective cohort study | A (1*) | A (1*) | A (1*) | A (1*) | A (1*) | B (1*) | A (1*) | A (1*) | 8