# Summary Risk of Bias Assessments

Table 27 Study-level distribution

| Number of studies
Low risk of bias | 0 (0%)
Unclear risk of bias | 79 (64%)
High risk of bias | 44 (36%)

Table 28 Domain-level distribution

Domain | High | Unclear | Low
Adequate sequence generation | 3 (2.4%) | 105 (85.4%) | 15 (12.2%)
Allocation concealment | 1 (0.8%) | 116 (94.3%) | 6 (4.9%)
Blinding | 21 (17.1%) | 83 (67.5%) | 19 (15.4%)
Incomplete outcome data addressed | 24 (19.5%) | 32 (26.0%) | 67 (54.5%)
Free of selective reporting | 1 (0.8%) | 3 (2.4%) | 119 (96.7%)
Free of other bias | 0 (0.0%) | 20 (16.3%) | 103 (83.7%)