# Risk of Bias Assessment for Randomized Controlled Trials and Nonrandomized Controlled Trials

## Guidelines and Decision Rules for Risk of Bias Assessments

### Sequence generation

- If computer-generated, random number list, flipping coins, randomly picking envelopes, etc. is specified → YES
- If the description only includes “random,” “randomly generated,” “randomized,” etc, do not assume additional details → UNCLEAR
- If the description is quasi-randomized (e.g. alternate randomization, day of the year, day of the month, birth date, birth month, beginning letter of last name, availability of investigator or specialist, etc) → NO

### Allocation concealment

- If the assignment is conducted by central telephone, pharmacy, etc → YES
- If dark (or opaque), sealed, sequentially-numbered envelopes are used → YES
- If the envelopes are not stated to dark and sealed, or sequentially-numbered → UNCLEAR

Note: sequential numbering of the envelopes is only required for adequate allocation concealment if the method of randomization was anything other than randomly picking envelopes (i.e., the envelopes were only used for allocation concealment and not as part of the randomization process).

### Blinding

- Describe who is blinded: patient, clinician, outcomes assessor, etc.
- If the study was stated to be blinded (masked), and the blinding is considered to be possible and not likely to be broken → YES
- If the study is only stated to be blinded, double-blinded, double-dummy, etc. without any further details → UNCLEAR
- If the study states the use of a placebo (dummy), but with no further details → UNCLEAR
- If no mention of blinding → UNCLEAR

### Incomplete outcome data (longest time point)

- Look for intention-to-treat (ITT) analysis (all randomized patients are analyzed) → YES
- If all participants were accounted for (i.e., no dropouts or censored analysis conducted) → YES
- If the numbers and reasons for withdrawal or dropouts were described and comparable across groups (and ≤ approximately 10 percent) → YES
- If there is between 10–30 percent dropout and no ITT analysis → UNCLEAR
- If there is greater 30 percent dropout and no ITT analysis → NO

### Selective outcome reporting

- If the study protocol is available (referenced in the manuscript), compare the outcomes reported in the publication to those specified in the protocol. If they match → YES
- If the study protocol is available (referenced in the manuscript), compare the outcomes reported in the publication to those specified in the protocol. If they do not match, but there is reference to another publication with this information presented → YES
- If the study protocol is not available, compare the outcomes reported in the methods and results sections. If they match → YES
- If the study protocol is not available, compare the outcomes reported in the methods and results sections. If they do not match → NO
- If the study protocol is not available, compare the outcomes reported in the methods and results sections. If they match but not in an extractable format (e.g., stating that there was no difference between the groups regarding the outcome) → UNCLEAR

### Other sources of bias

- Assess for baseline imbalances that could have biased the results (or were not accounted for)
- Assess for appropriateness of crossover design (e.g., inadequate wash-out period).
- Note any “other” sources of bias

## Risk of Bias Assessments

### A Schizophrenia and Related Psychoses

Table 1 Risk of bias–chlorpromazine versus clozapine

Study | Item | Judgment | Description
Chiu et al. 1976 152 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details on sequence generation.
Chiu et al. 1976 152 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment.
Chiu et al. 1976 152 | Blinding? | UNCLEAR | Reported as a DB trial using identical capsules.
Chiu et al. 1976 152 | Incomplete outcome data addressed? | NO | ITT principle was not used in the analyses with 43.8% of participants being excluded from the analyses. Attrition rate was high with 43.8% of participants not completing the trial.
Chiu et al. 1976 152 | Free of selective reporting? | YES | Protocol was not available, but outcomes reported in methods and results are similar.
Chiu et al. 1976 152 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Claghorn et al. 1987 63 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Claghorn et al. 1987 63 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Claghorn et al. 1987 63 | Blinding? | YES | Reported as a DB trial, with medications that were identical in appearance and packaged uniformly.
Claghorn et al. 1987 63 | Incomplete outcome data addressed? | NO | ITT principle not utilized for analyses, and 42% of participants did not complete the study.
Claghorn et al. 1987 63 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Claghorn et al. 1987 63 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Ekblom et al. 1974 153 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details on sequence generation.
Ekblom et al. 1974 153 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment.
Ekblom et al. 1974 153 | Blinding? | YES | Reported as a DB trial using identical capsules.
Ekblom et al. 1974 153 | Incomplete outcome data addressed? | YES | ITT principle was used and attrition rate was low (9.8%).
Ekblom et al. 1974 153 | Free of selective reporting? | YES | Protocol was not available, but outcomes reported in methods and results are similar.
Ekblom et al. 1974 153 | Free of other bias? | UNCLEAR | Baseline characteristics were reported not reported. Other sources of bias were not detected.
Gelenberg et al. 1979 154 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details on sequence generation.
Gelenberg et al. 1979 154 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment.
Gelenberg et al. 1979 154 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding participant or physician blinding.
Gelenberg et al. 1979 154 | Incomplete outcome data addressed? | YES | ITT principle was used in analyses with no reports of patients lost for followup.
Gelenberg et al. 1979 154 | Free of selective reporting? | YES | Protocol was not available, but outcomes reported in methods and results are similar.
Gelenberg et al. 1979 154 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Guirguis et al. 1977 160 | Adequate sequence generation? | UNCLEAR | Reported as randomized trial, with no further details regarding sequence generation.
Guirguis et al. 1977 160 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment.
Guirguis et al. 1977 160 | Blinding? | UNCLEAR | No mention of who was blinded, but used identical capsules prepared in pharmacy.
Guirguis et al. 1977 160 | Incomplete outcome data addressed? | UNCLEAR | No ITT, 35/50 (70%) analyzed.
Guirguis et al. 1977 160 | Free of selective reporting? | YES | Protocol not available, but methods and results sections match.
Guirguis et al. 1977 160 | Free of other bias? | UNCLEAR | Baseline imbalances on age, NOSIE score, and onset of schizophrenia.
Hong et al. 1997 87 | Adequate sequence generation? | YES | Randomization was done using a table of random numbers.
Hong et al. 1997 87 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Hong et al. 1997 87 | Blinding? | UNCLEAR | Reported as a DB trial. Medications were identical in appearance and package, which ensured DB. No clear statement regarding blinding of assessors.
Hong et al. 1997 87 | Incomplete outcome data addressed? | YES | No use of ITT. 40 patients randomized, 38 patients analyzed (95%).
Hong et al. 1997 87 | Free of selective reporting? | YES | Outcomes in the method section match to the results.
Hong et al. 1997 87 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Kane et al. 1988 94 | Adequate sequence generation? | UNCLEAR | Reported patients were randomly assigned, with no further details regarding sequence generation.
Kane et al. 1988 94 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Kane et al. 1988 94 | Blinding? | YES | All medications were coded and administered under DB conditions; in addition to coded active antipsychotic medication in blue capsules, patients received either white benztropine tablets or identical white placebo tablets.
Kane et al. 1988 94 | Incomplete outcome data addressed? | UNCLEAR | No ITT. 10–30% (14%) dropouts.
Kane et al. 1988 94 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Kane et al. 1988 94 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Leon et al. 1979 156 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Leon et al. 1979 156 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Leon et al. 1979 156 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding the methods used for blinding.
Leon et al. 1979 156 | Incomplete outcome data addressed? | NO | No ITT reported; 50 randomized and 37 analyzed at 3 year followup.
Leon et al. 1979 156 | Free of selective reporting? | YES | Protocol was not available, but all main outcomes were reported.
Leon et al. 1979 156 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Lieberman et al. 2003 109 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Lieberman et al. 2003 109 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Lieberman et al. 2003 109 | Blinding? | UNCLEAR | Reported as a DB trial but only specified patients were blinded.
Lieberman et al. 2003 109 | Incomplete outcome data addressed? | YES | Use of modified ITT. Only 4 patients not considered in the analysis (2.43%).
Lieberman et al. 2003 109 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Lieberman et al. 2003 109 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Rinieris et al. 1980 157 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Rinieris et al. 1980 157 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Rinieris et al. 1980 157 | Blinding? | UNCLEAR | No information reported regarding patient or physician blinding status provided in trial report.
Rinieris et al. 1980 157 | Incomplete outcome data addressed? | NO | ITT principle was not used in analyses, with only 59% of randomized participants included in analyses.
Rinieris et al. 1980 157 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results were similar.
Rinieris et al. 1980 157 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Shopsin et al. 1979 158 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Shopsin et al. 1979 158 | Allocation concealment? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Shopsin et al. 1979 158 | Blinding? | YES | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Shopsin et al. 1979 158 | Incomplete outcome data addressed? | YES | ITT principle used during analyses, and there was no reporting of patients dropping out of the trial.
Shopsin et al. 1979 158 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results sections are similar.
Shopsin et al. 1979 158 | Free of other bias? | UNCLEAR | Baseline characteristics were reported not reported. Other sources of bias were not detected.
Singer et al. 1974 161 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Singer et al. 1974 161 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Singer et al. 1974 161 | Blinding? | UNCLEAR | Reported as a blinded trial, with no further details regarding blinding.
Singer et al. 1974 161 | Incomplete outcome data addressed? | YES | One dropout from each group.
Singer et al. 1974 161 | Free of selective reporting? | YES | No protocol available, but outcomes in methods and results match.
Singer et al. 1974 161 | Free of other bias? | NO | No mention of baseline comparisons.

DB = double-blind; ITT = intention-to-treat analysis; NOSIE = Nurses’ Observation Scale for Inpatient Evaluation

Table 2 Risk of bias–chlorpromazine versus olanzapine

Study | Item | Judgment | Description
Conley et al. 1998 66 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Conley et al. 1998 66 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Conley et al. 1998 66 | Blinding? | YES | Reported as a DB trial, using matching medication.
Conley et al. 1998 66 | Incomplete outcome data addressed? | UNCLEAR | ITT reported. 70% completion.
Conley et al. 1998 66 | Free of selective reporting? | YES | Outcomes in the method section match to the results.
Conley et al. 1998 66 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

DB = double-blind; ITT = intention-to-treat analysis

Table 3 Risk of bias–chlorpromazine versus quetiapine

Study | Item | Judgment | Description
Peuskens et al. 1997 121 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details.
Peuskens et al. 1997 121 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Peuskens et al. 1997 121 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding the methods used for blinding.
Peuskens et al. 1997 121 | Incomplete outcome data addressed? | YES | ITT performed on 196/201 (98%) of randomized patients.
Peuskens et al. 1997 121 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Peuskens et al. 1997 121 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

DB = double-blind; ITT = intention-to-treat analysis

Table 4 Risk of bias–chlorpromazine versus ziprasidone

Study | Item | Judgment | Description
Kane et al. 2006 96 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Kane et al. 2006 96 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment.
Kane et al. 2006 96 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Kane et al. 2006 96 | Incomplete outcome data addressed? | YES | ITT analysis. Response rates and safety evaluations are reported for the ITT population.
Kane et al. 2006 96 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Kane et al. 2006 96 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

DB = double-blind; ITT = intention-to-treat analysis

Table 5 Risk of bias–fluphenapine versus olanzapine

Study | Item | Judgment | Description
Jakovljevic et al. 1999 89 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Jakovljevic et al. 1999 89 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Jakovljevic et al. 1999 89 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding the methods used for blinding.
Jakovljevic et al. 1999 89 | Incomplete outcome data addressed? | YES | Modified ITT using LOCF on those who received drug and had at least one followup observation. 55/60 (92%) analyzed for efficacy, 100% for safety.
Jakovljevic et al. 1999 89 | Free of selective reporting? | YES | Protocol was not available, but all main outcomes were reported.
Jakovljevic et al. 1999 89 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Ljubin et al. 2000 112 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Ljubin et al. 2000 112 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Ljubin et al. 2000 112 | Blinding? | UNCLEAR | Physicians were blind to patient status, but no report of patients knowledge of treatment received.
Ljubin et al. 2000 112 | Incomplete outcome data addressed? | UNCLEAR | Only analyzed completers. Due to a dropout of some patients, the final olanzapine group had 10 patients, and the fluphenazine group 8 patients.
Ljubin et al. 2000 112 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Ljubin et al. 2000 112 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

DB = double-blind; ITT = intention-to-treat analysis; LOCF = last observation carried forward

Table 6 Risk of bias–fluphenapine versus quetiapine

Study | Item | Judgment | Description
Conley et al. 2005 67 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Conley et al. 2005 67 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Conley et al. 2005 67 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Conley et al. 2005 67 | Incomplete outcome data addressed? | UNCLEAR | ITT principle not used, but 71% of participants included in the analyses.
Conley et al. 2005 67 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Conley et al. 2005 67 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

DB = double-blind; ITT = intention-to-treat analysis;

Table 7 Risk of bias–fluphenapine versus risperidone

Study | Item | Judgment | Description
Conley et al. 2005 67 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Conley et al. 2005 67 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Conley et al. 2005 67 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Conley et al. 2005 67 | Incomplete outcome data addressed? | UNCLEAR | ITT principle not used, but 71% of participants included in the analyses.
Conley et al. 2005 67 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Conley et al. 2005 67 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

DB = double-blind; ITT = intention-to-treat analysis

Table 8 Risk of bias–haloperidol versus aripiprazole

Study | Item | Judgment | Description
Andrezina et al. 2006 44 | Adequate sequence generation? | YES | Reported as using permuted block randomization.
Andrezina et al. 2006 44
Andrezina et al. 2006 44 | Allocation concealment? | YES | Reported as using a centralized call-in system.
Andrezina et al. 2006 44
Andrezina et al. 2006 44 | Blinding? | UNCLEAR | Reported as a DB, placebo-controlled trial, with no further details regarding the methods used for blinding.
Andrezina et al. 2006 44
Andrezina et al. 2006 44 | Incomplete outcome data addressed? | YES | ITT analysis was not used, but 99% of randomized participants were included in the analyses.
Andrezina et al. 2006 44
Andrezina et al. 2006 44 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Andrezina et al. 2006 44
Andrezina et al. 2006 44 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Daniel et al. 2007 74 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no futher details regarding seuqence generation.
Daniel et al. 2007 74
Daniel et al. 2007 74 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Daniel et al. 2007 74
Daniel et al. 2007 74 | Blinding? | UNCLEAR | Reported as a DB trial, with no futher details regarding blinding.
Daniel et al. 2007 74
Daniel et al. 2007 74 | Incomplete outcome data addressed? | UNCLEAR | Of the 448 patients who received IM formulations, 380 (85%) were transitioned to oral formulations. However, they did not report in this study the results obtained from people switching from placebo to aripiprazole.
Daniel et al. 2007 74
Daniel et al. 2007 74 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Daniel et al. 2007 74
Daniel et al. 2007 74 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias.
de Oliveira et al. 2009 76 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
de Oliveira et al. 2009 76
de Oliveira et al. 2009 76 | Allocation concealment? | UNCLEAR | Trial reported that investigators were provided with sealed, numbered, and coded envelopes containing the description of the treatment to be administered to the subject by a person who had no contact with the patients. There is no mention if the envelopes were opaque/dark or not.
de Oliveira et al. 2009 76
de Oliveira et al. 2009 76 | Blinding? | NO | Reported as an open-label trial.
de Oliveira et al. 2009 76
de Oliveira et al. 2009 76 | Incomplete outcome data addressed? | YES | ITT priniciple not used, but 98% of participants included in analyses.
de Oliveira et al. 2009 76
de Oliveira et al. 2009 76 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
de Oliveira et al. 2009 76
de Oliveira et al. 2009 76 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias.
Kane et al. 2002 92 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Kane et al. 2002 92
Kane et al. 2002 92 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Kane et al. 2002 92
Kane et al. 2002 92 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding except that rater was blinded to treatment group.
Kane et al. 2002 92
Kane et al. 2002 92 | Incomplete outcome data addressed? | NO | ITT; reported 248/414 completed.
Kane et al. 2002 92
Kane et al. 2002 92 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Kane et al. 2002 92
Kane et al. 2002 92 | Free of other bias? | UNCLEAR | It is unclear if baseline characteristics were similar.
Kasper et al. 2003 98 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Kasper et al. 2003 98
Kasper et al. 2003 98 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Kasper et al. 2003 98
Kasper et al. 2003 98 | Blinding? | UNCLEAR | Reported as DB, with no further information.
Kasper et al. 2003 98
Kasper et al. 2003 98 | Incomplete outcome data addressed? | YES | 1294 patients randomized, 1289 analyzed; LOCF reported.
Kasper et al. 2003 98
Kasper et al. 2003 98 | Free of selective reporting? | YES | Methods match results reported.
Kasper et al. 2003 98
Kasper et al. 2003 98 | Free of other bias? | NO | No significant differences between treatment groups. Study funded by Bristol Myers Squibb.
Kim et al. 2010 102 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial with no further details regarding sequence generation.
Kim et al. 2010 102
Kim et al. 2010 102 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Kim et al. 2010 102
Kim et al. 2010 102 | Blinding? | UNCLEAR | Reported as a double blind trial. No further details regarding blinding.
Kim et al. 2010 102
Kim et al. 2010 102 | Incomplete outcome data addressed? | UNCLEAR | No ITT. No data regarding the number of dropouts.
Kim et al. 2010 102
Kim et al. 2010 102 | Free of selective reporting? | YES | Outcomes in the method section match to the results.
Kim et al. 2010 102
Kim et al. 2010 102 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
McCue et al. 2006 73 | Adequate sequence generation? | YES | Reported that randomization was performed using a website-based randomization scheme (www.randomization.com).
McCue et al. 2006 73
McCue et al. 2006 73 | Allocation concealment? | YES | Reported that the hospital staff with no clinical responsibilities and no knowledge of the patients oversaw the assignment procedure and assigned medications in sequential order, strictly following the randomized list. Also reported that the treating psychiatrist did not have access to this list.
McCue et al. 2006 73
McCue et al. 2006 73 | Blinding? | NO | Reported as an open-label study, with both the patient and the treating psychiatrist being aware of the antipsychotic being prescribed.
McCue et al. 2006 73
McCue et al. 2006 73 | Incomplete outcome data addressed? | YES | ITT principle not used during the analysis, but 98% of randomized participants analyzed.
McCue et al. 2006 73
McCue et al. 2006 73 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
McCue et al. 2006 73
McCue et al. 2006 73 | Free of other bias? | UNCLEAR | Reported that there was a significant difference in the age of participants among the 6 treatment groups and a significantly different proportion of patients received additional medications. Other sources of bias were not detected.
Tran-Johnson et al. 2007 31 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Tran-Johnson et al. 2007 31
Tran-Johnson et al. 2007 31 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Tran-Johnson et al. 2007 31
Tran-Johnson et al. 2007 31 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding patient or physician blinding.
Tran-Johnson et al. 2007 31
Tran-Johnson et al. 2007 31 | Incomplete outcome data addressed? | YES | ITT principle not used in analyses, but 95% of participants were included in the analyses.
Tran-Johnson et al. 2007 31
Tran-Johnson et al. 2007 31 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
Tran-Johnson et al. 2007 31 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

DB = double-blind; IM = intramuscular; ITT = intention-to-treat analysis

Table 9 Risk of bias–haloperidol versus asenapine

Study | Item | Judgment | Description
Kane et al. 2010 97 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details.
Kane et al. 2010 97 | Allocation concealment? | UNCLEAR | Allocation concealment was not reported.
Kane et al. 2010 97 | Blinding? | UNCLEAR | Reported as a DB, placebo-controlled trial, with no further details regarding the methods used for blinding.
Kane et al. 2010 97 | Incomplete outcome data addressed? | YES | ITT analysis was not used, but 98% of randomized participants were included in the analyses.
Kane et al. 2010 97 | Free of selective reporting? | UNCLEAR | InterSePT and RDQ are reported as trial outcomes, but no extractable data is reported (i.e., only reported that changes from baseline to endpoint were small).
Kane et al. 2010 97 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

DB = double-blind; ITT = intention-to-treat analysis; RDQ = Readiness to Discharge Questionnaire

Table 10 Risk of bias–haloperidol versus clozapine

Study | Item | Judgment | Description
Breier et al. 2002 56 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Breier et al. 2002 56 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Breier et al. 2002 56 | Blinding? | YES | Reported as a DB trial, with investigators, raters, clinical staff, and patients blinded by using identical unmarked syringes administered by trained, unblinded, third-party personnel, who played no role in evaluating patients.
Breier et al. 2002 56 | Incomplete outcome data addressed? | YES | ITT principle used in analyses. Attrition rate was low (0.7%).
Breier et al. 2002 56 | Free of selective reporting? | YES | Protocol was not available, but outcomes in methods and results are similar.
Breier et al. 2002 56 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Citrome et al. 2001 62 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no futher details regarding sequence generation.
Citrome et al. 2001 62 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Citrome et al. 2001 62 | Blinding? | UNCLEAR | Reported as a DB trial, with blinded raters performed all the clinical assessments and dosage changes requested by blinded psychiatrists, but no description of how the patients were blinded.
Citrome et al. 2001 62 | Incomplete outcome data addressed? | NO | ITT principle was used during analyses, but attrition rate was high with only 58% of participants completing the trial.
Citrome et al. 2001 62 | Free of selective reporting? | NO | Two outcomes (ESRS and NOSIE) are listed in the method section, but no results are presented.
Citrome et al. 2001 62 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Covington et al. 2000 70 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no futher details regarding sequence generation.
Covington et al. 2000 70 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Covington et al. 2000 70 | Blinding? | UNCLEAR | No reporting of trial blinding.
Covington et al. 2000 70 | Incomplete outcome data addressed? | YES | ITT principle used during analyses and no dropouts were reproted.
Covington et al. 2000 70 | Free of selective reporting? | YES | Protocol is not available, but outcomes in methods and results are similar.
Covington et al. 2000 70 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Itoh et al. 1977 155 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Itoh et al. 1977 155 | Allocation concealment? | UNCLEAR | Reported that those physicians who had conducted the trial or those who were related to the pharmaceutical company were excluded from the controllers who coded the DB trial and supervised the entire experiment.
Itoh et al. 1977 155 | Blinding? | UNCLEAR | Reported that the ‘coders’ were independent of physcians supervising the trial. So it seems that they were blinded, but no report of the subjects’ status.
Itoh et al. 1977 155 | Incomplete outcome data addressed? | YES | All patients were analyzed.
Itoh et al. 1977 155 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Itoh et al. 1977 155 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Kane et al. 2001 95 | Adequate sequence generation? | YES | Reported as a randomized trial. Computer-generated randomization schedules (blocked by site) were provided to each site.
Kane et al. 2001 95 | Allocation concealment? | UNCLEAR | Use of sealed envelopes with treatment assignment were available to clinical personnel if needed to break the blind. Unsure whether they used sequentially numbered or opaque envelopes.
Kane et al. 2001 95 | Blinding? | UNCLEAR | Reported as a DB trial: medication was administered under DB conditions. To maintain the blind, all subjects had a weekly blood draw. No further details regarding blinding.
Kane et al. 2001 95 | Incomplete outcome data addressed? | NO | More than 30% were droped out of the study, and no ITT was conducted.
Kane et al. 2001 95 | Free of selective reporting? | YES | Outcomes in the method section match to the results.
Kane et al. 2001 95 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Kleiser et al. 1994 103 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Kleiser et al. 1994 103 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment.
Kleiser et al. 1994 103 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Kleiser et al. 1994 103 | Incomplete outcome data addressed? | YES | 51 patients were randomized, 51 analyzed. No report of ITT.
Kleiser et al. 1994 103 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Kleiser et al. 1994 103 | Free of other bias? | UNCLEAR | No significant differences between treatment groups. No declaration of funding source.
Krakowski et al. 2006 105 | Adequate sequence generation? | UNCLEAR | Reported as a block randomization with no further detail.
Krakowski et al. 2006 105 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment.
Krakowski et al. 2006 105 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Krakowski et al. 2006 105 | Incomplete outcome data addressed? | YES | ITT performed on all participants.
Krakowski et al. 2006 105 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
Krakowski et al. 2006 105 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Rosenheck et al. 1997 126 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Rosenheck et al. 1997 126 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Rosenheck et al. 1997 126 | Blinding? | YES | Reported as a DB trial, with matching benztropine placebo. To maintain blinding, haloperidol-treated patients also received benztropine mesylate (2–10 mg/d) for extrapyramidal syndrome; clozapine patients received a matching benztropine placebo. Haloperidol patients participated in weekly blood counts as required for clozapine treatment.
Rosenheck et al. 1997 126 | Incomplete outcome data addressed? | UNCLEAR | ITT principle not used in analyses and attrition rate was moderate, with 346/423 participants not included in analyses.
Rosenheck et al. 1997 126 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
Rosenheck et al. 1997 126 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Volakva et al. 2002 145 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Volakva et al. 2002 145 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Volakva et al. 2002 145 | Blinding? | UNCLEAR | Reported as a DB trial; clinicians who adjusted the dosing and outcome assessors were blinded. Patients were blinded to BDZ, not to the antipsychotics.
Volakva et al. 2002 145 | Incomplete outcome data addressed? | YES | 101 patients randomized, and 101 patients analyzed. No clear description of how many randomized.
Volakva et al. 2002 145 | Free of selective reporting? | UNCLEAR | NOSIE and ESRS are in method section. But, no numeric data is reported in results, just F-values, degrees of freedom, and p-values are reported.
Volakva et al. 2002 145 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

BDZ = benzodiazepine; DB = double-blind; ESRS =Extrapyramidal Syndrome Rating Scale; ITT = intention-to-treat analysis; NOSIE = Nurses’ Observation Scale for Inpatient Evaluation

Table 11 Risk of bias–haloperidol versus olanzapine

Study | Item | Judgment | Description
Altamura et al. 2002 43 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Altamura et al. 2002 43 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Altamura et al. 2002 43 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding the methods used for blinding.
Altamura et al. 2002 43 | Incomplete outcome data addressed? | UNCLEAR | ITT principle was not used. 24/28 participants were included in the analyses using LOCF. Attrition rate was moderate (25%).
Altamura et al. 2002 43 | Free of selective reporting? | UNCLEAR | Protocol was not available, but one of the main outcomes (CGI–S) was only reported to be not significantly different between the groups, without any extractable data presented.
Altamura et al. 2002 43 | Free of other bias? | UNCLEAR | Baseline characteristics for the 2 groups was shown in tabular form, but no mention of similarity was presented.
Alvarez-Jimenez et al. 2006 142 | Adequate sequence generation? | YES | Reported as a randomized trial using computer-generated blocks of random numbers.
Alvarez-Jimenez et al. 2006 142 | Allocation concealment? | YES | Allocation concealment was done by a member of the team not involved with either the assessment or the treatments.
Alvarez-Jimenez et al. 2006 142 | Blinding? | NO | Reported as single-blind trial, with research assessors and patients intended to be blind to intervention. It was difficult to keep assessors blinded.
Alvarez-Jimenez et al. 2006 142 | Incomplete outcome data addressed? | YES | ITT performed on all randomized patients.
Alvarez-Jimenez et al. 2006 142 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Alvarez-Jimenez et al. 2006 142 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Avasthi et al. 2001 159 | Adequate sequence generation? | YES | Reported as a randomized trial, with no further details regarding sequence generation.
Avasthi et al. 2001 159 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Avasthi et al. 2001 159 | Blinding? | NO | Described as an open-label study.
Avasthi et al. 2001 159 | Incomplete outcome data addressed? | UNCLEAR | No ITT; 23/30 (76.7%) analyzed.
Avasthi et al. 2001 159 | Free of selective reporting? | YES | Study protocol not available, but outcomes reported in the methods and results sections match.
Avasthi et al. 2001 159 | Free of other bias? | UNCLEAR | No baseline comparison data reported.
Beasley et al. 1996 49 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Beasley et al. 1996 49 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Beasley et al. 1996 49 | Blinding? | UNCLEAR | Reported as a DB placebo-controlled trial, with no further details regarding blinding, except that dose ranges could be modified in a blinded manner.
Beasley et al. 1996 49 | Incomplete outcome data addressed? | YES | ITT principle not used in the analyses, but 415/431 participants were included using LOCF. Attrition rate was low (16%).
Beasley et al. 1996 49 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
Beasley et al. 1996 49 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Beasley et al. 1997 50 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Beasley et al. 1997 50 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Beasley et al. 1997 50 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding the methods used for blinding.
Beasley et al. 1997 50 | Incomplete outcome data addressed? | YES | ITT analysis using LOCF on 415/431 (96%) of patients.
Beasley et al. 1997 50 | Free of selective reporting? | YES | Protocol was not available, but all main outcomes were reported.
Beasley et al. 1997 50 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Bernardo et al. 2001 51 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Bernardo et al. 2001 51 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Bernardo et al. 2001 51 | Blinding? | UNCLEAR | Reported as a DB trial, with no further information regarding blinding.
Bernardo et al. 2001 51 | Incomplete outcome data addressed? | YES | ITT not used for analyses, with 27/28 participants included. Attrition was not reported.
Bernardo et al. 2001 51 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Bernardo et al. 2001 51 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Boulay et al. 2007 54 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Boulay et al. 2007 54 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Boulay et al. 2007 54 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Boulay et al. 2007 54 | Incomplete outcome data addressed? | UNCLEAR | ITT principle was not used, with 95% of participants included in analyses. Attrition rate was moderate (12.5%).
Boulay et al. 2007 54 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Boulay et al. 2007 54 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Breier et al. 2002 56 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Breier et al. 2002 56 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Breier et al. 2002 56 | Blinding? | YES | Reported as a DB trial, with investigators, raters, clinical staff, and patients blinded by using identical unmarked syringes administered by trained unblinded third-party personnel who played no role in evaluating patients.
Breier et al. 2002 56 | Incomplete outcome data addressed? | YES | ITT principle used in analyses. Attrition rate was low (0.7%).
Breier et al. 2002 56 | Free of selective reporting? | YES | Protocol was not available, but outcomes in methods and results are similar.
Breier et al. 2002 56 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Buchanan et al. 2005 58 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Buchanan et al. 2005 58 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Buchanan et al. 2005 58 | Blinding? | NO | Reported as a DB trial, but adverse events were rated by a nonblinded pharmacist.
Buchanan et al. 2005 58 | Incomplete outcome data addressed? | YES | ITT principle is not used in analyses. Attrition rate was low 9.5%.
Buchanan et al. 2005 58 | Free of selective reporting? | YES | Protcol was not available, but outcomes in methods and results are similar.
Buchanan et al. 2005 58 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Citrome et al. 2001 62 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no futher details regarding sequence generation.
Citrome et al. 2001 62 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Citrome et al. 2001 62 | Blinding? | UNCLEAR | Reported as a DB trial, with blinded raters performed all the clinical assessments and dosage changes requested by blinded psychiatrists, but no description of how the patients were blinded.
Citrome et al. 2001 62 | Incomplete outcome data addressed? | NO | ITT principle was used during analyses, but attrition rate was high, with only 58% of participants completing the trial.
Citrome et al. 2001 62 | Free of selective reporting? | NO | Two outcomes (ESRS and NOSIE) are listed in the method section, but no results are presented.
Citrome et al. 2001 62 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Crespo-Faccoro et al. 2006 71 | Adequate sequence generation? | YES | Reported as a randomized trial using a computer-generated randomization list.
Crespo-Faccoro et al. 2006 71 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Crespo-Faccoro et al. 2006 71 | Blinding? | NO | Reported as an open-label trial.
Crespo-Faccoro et al. 2006 71 | Incomplete outcome data addressed? | YES | ITT principle not used, but attrition rate was low, and 172/182 were included in the analyses.
Crespo-Faccoro et al. 2006 71 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
Crespo-Faccoro et al. 2006 71 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Davidson et al. 2009 75 | Adequate sequence generation? | YES | Reported the use of a centralized computerized online randomization system.
Davidson et al. 2009 75 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Davidson et al. 2009 75 | Blinding? | NO | Reported as an open-label trial.
Davidson et al. 2009 75 | Incomplete outcome data addressed? | NO | ITT principle was not used, and attrition was high with 43% of participants not completing the trial.
Davidson et al. 2009 75 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Davidson et al. 2009 75 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
de Haan et al. 2003 78 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial using a randomized block design. No more details regarding sequence generation
de Haan et al. 2003 78 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
de Haan et al. 2003 78 | Blinding? | UNCLEAR | Reported as a DB trial. All analyses were performed blind to the clinical data.
de Haan et al. 2003 78 | Incomplete outcome data addressed? | UNCLEAR | No ITT, 20% withdrawal.
de Haan et al. 2003 78 | Free of selective reporting? | YES | Outcomes in the method section match to the results.
de Haan et al. 2003 78 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Goldman et al. 2004 84 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial; no further details regarding sequence generation.
Goldman et al. 2004 84 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Goldman et al. 2004 84 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Goldman et al. 2004 84 | Incomplete outcome data addressed? | UNCLEAR | No ITT, 7/10 completed.
Goldman et al. 2004 84 | Free of selective reporting? | YES | Outcomes in the method section match to the results.
Goldman et al. 2004 84 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Ishigooka et al. 2001 88 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Ishigooka et al. 2001 88 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Ishigooka et al. 2001 88 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Ishigooka et al. 2001 88 | Incomplete outcome data addressed? | UNCLEAR | No ITT. 127/174 competed the trial.
Ishigooka et al. 2001 88 | Free of selective reporting? | YES | Outcomes in the method section match to the results.
Ishigooka et al. 2001 88 | Free of other bias? | UNCLEAR | Significant difference in BPRS scores at baseline. Other sources of bias were not detected.
Kahn et al. 2008 91 | Adequate sequence generation? | YES | Trial reported patients were randomly assigned by a dedicated web-based online system developed inhouse by the Data Management Department of the Julius Center for Health Sciences and Primary Care.
Kahn et al. 2008 91 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Kahn et al. 2008 91 | Blinding? | NO | Reported as an open-label trial. Patients and their treating psychiatrists were unmasked for the assigned treatment.
Kahn et al. 2008 91 | Incomplete outcome data addressed? | YES | 498 randomized. 498 analyzed. ITT reported. 342 completed followup.
Kahn et al. 2008 91 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Kahn et al. 2008 91 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Keefe et al. 2006 101 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Keefe et al. 2006 101 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Keefe et al. 2006 101 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Keefe et al. 2006 101 | Incomplete outcome data addressed? | YES | 414 patients randomized. ITT reported. 414 analyzed.
Keefe et al. 2006 101 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Keefe et al. 2006 101 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Kim et al. 2010 102 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Kim et al. 2010 102 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Kim et al. 2010 102 | Blinding? | UNCLEAR | Reported as a DB trial. No further details regarding blinding.
Kim et al. 2010 102 | Incomplete outcome data addressed? | UNCLEAR | No ITT. No data regarding the number of dropouts.
Kim et al. 2010 102 | Free of selective reporting? | YES | Outcomes in the method section match to the results.
Kim et al. 2010 102 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Kongsakon et al. 2006 104 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Kongsakon et al. 2006 104 | Allocation concealment? | YES | Drug kits were assigned a number according to a randomization list produced onsite, then these numbered kits were consecutively allocated to patients in blocks of four stratified by country.
Kongsakon et al. 2006 104 | Blinding? | YES | Reported as a DB trial. All study medication was identical in appearance.
Kongsakon et al. 2006 104 | Incomplete outcome data addressed? | YES | >90% (93% for PANSS and 98% for BPRS) were analyzed.
Kongsakon et al. 2006 104 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Kongsakon et al. 2006 104 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias.
Krakowski et al. 2006 105 | Adequate sequence generation? | UNCLEAR | Reported as a block randomization with no further detail.
Krakowski et al. 2006 105 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment.
Krakowski et al. 2006 105 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Krakowski et al. 2006 105 | Incomplete outcome data addressed? | YES | ITT performed on all participants.
Krakowski et al. 2006 105 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
Krakowski et al. 2006 105 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Lahti et al. 2009 106 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Lahti et al. 2009 106 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Lahti et al. 2009 106 | Blinding? | YES | Reported as a DB trial. Medications were prepared in similar-looking capsules by the hospital pharmacist.
Lahti et al. 2009 106 | Incomplete outcome data addressed? | YES | ITT principle not used, but 29/32 (91%) of participants included in the analyses.
Lahti et al. 2009 106 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Lahti et al. 2009 106 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias.
Lieberman et al. 2003 108 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Lieberman et al. 2003 108 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Lieberman et al. 2003 108 | Blinding? | UNCLEAR | Reported as a DB trial; no further details regarding the methods used for blinding.
Lieberman et al. 2003 108 | Incomplete outcome data addressed? | YES | ITT reported; 263 randomized; 262 analyzed.
Lieberman et al. 2003 108 | Free of selective reporting? | YES | Protocol was not available but all main outcomes were reported.
Lieberman et al. 2003 108 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Lindenmayer et al. 2007 110 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Lindenmayer et al. 2007 110 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Lindenmayer et al. 2007 110 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding procedure.
Lindenmayer et al. 2007 110 | Incomplete outcome data addressed? | UNCLEAR | ITT principle not used, 31/35 (89%) of participants included in the analyses.
Lindenmayer et al. 2007 110 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Lindenmayer et al. 2007 110 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
McCue et al. 2006 73 | Adequate sequence generation? | YES | Reported that randomization was performed using a website-based randomization scheme (www.randomization.com).
McCue et al. 2006 73 | Allocation concealment? | YES | Reported that the hospital staff with no clinical responsibilities and no knowledge of the patients oversaw the assignment procedure and assigned medications in sequential order, strictly following the randomized list. Also reported that the treating psychiatrist did not have access to this list.
McCue et al. 2006 73 | Blinding? | NO | Reported as an open-label study with both the patient and the treating psychiatrist being aware of the antipsychotic being prescribed.
McCue et al. 2006 73 | Incomplete outcome data addressed? | YES | ITT principle not used during the analysis, but 98% of randomized participants analyzed.
McCue et al. 2006 73 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
McCue et al. 2006 73 | Free of other bias? | UNCLEAR | Reported that there was a significant difference in the age of participants among the 6 treatment groups, and a significantly different proportion of patients received additional medications. Other sources of bias were not detected.
Purdon et al. 2000 124 | Adequate sequence generation? | YES | Reported as a randomized trial using a computer-generated random number table.
Purdon et al. 2000 124 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Purdon et al. 2000 124 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Purdon et al. 2000 124 | Incomplete outcome data addressed? | YES | 65 randomized, 55 analyzed with LOCF. ITT reported.
Purdon et al. 2000 124 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Purdon et al. 2000 124 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Rosenheck et al. 2003 127 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Rosenheck et al. 2003 127 | Allocation concealment? | YES | Assignments were made from a coordinating center via telephone.
Rosenheck et al. 2003 127 | Blinding? | YES | Reported as a DB trial using kits labelled with a random number; one group received a matching placebo (i.e. both groups took 2 drugs).
Rosenheck et al. 2003 127 | Incomplete outcome data addressed? | YES | ITT analysis on all randomized patients.
Rosenheck et al. 2003 127 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Rosenheck et al. 2003 127 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Saddichha et al. 2008 129 | Adequate sequence generation? | NO | Reported as randomized, but treatment was assigned by order in which patient arrived.
Saddichha et al. 2008 129 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Saddichha et al. 2008 129 | Blinding? | UNCLEAR | Reported as a DB trial. Assessments conducted by a single-blind investigator. No description of drug appearance to preserve the blinding.
Saddichha et al. 2008 129 | Incomplete outcome data addressed? | YES | Analyzed 99/110 (90%) enrolled patients.
Saddichha et al. 2008 129 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Saddichha et al. 2008 129 | Free of other bias? | UNCLEAR | Baseline comparability was unclear. Other sources of bias were not detected.
Sayers et al. 2005 130 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Sayers et al. 2005 130 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Sayers et al. 2005 130 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding patient or physician blinding.
Sayers et al. 2005 130 | Incomplete outcome data addressed? | NO | ITT principle not used in analyses; attrition rate was high, with 14/24 of participants not completing the trial.
Sayers et al. 2005 130 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
Sayers et al. 2005 130 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Sergi et al. 2007 134 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Sergi et al. 2007 134 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Sergi et al. 2007 134 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Sergi et al. 2007 134 | Incomplete outcome data addressed? | UNCLEAR | ITT not reported. 73/100 (73%) included in analysis.
Sergi et al. 2007 134 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Sergi et al. 2007 134 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias.
Smelson et al. 2006 136 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Smelson et al. 2006 136 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Smelson et al. 2006 136 | Blinding? | UNCLEAR | Reported as a DB trial using identical appearing capsules. No mention of who else blinded.
Smelson et al. 2006 136 | Incomplete outcome data addressed? | NO | ITT not reported. 18/31 (58%) included in analysis.
Smelson et al. 2006 136 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Smelson et al. 2006 136 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias.
Smith et al. 2001 137 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Smith et al. 2001 137 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Smith et al. 2001 137 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Smith et al. 2001 137 | Incomplete outcome data addressed? | NO | ITT not reported. 53% to 73% included in analysis.
Smith et al. 2001 137 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Smith et al. 2001 137 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Tollefson et al. 1997 141 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Tollefson et al. 1997 141 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Tollefson et al. 1997 141 | Blinding? | NO | Reported as an open-label trial.
Tollefson et al. 1997 141 | Incomplete outcome data addressed? | YES | ITT analysis on all randomized patients.
Tollefson et al. 1997 141 | Free of selective reporting? | YES | Protocol was not available, but all main outcomes were reported.
Tollefson et al. 1997 141 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Volakva et al. 2002 145 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Volakva et al. 2002 145 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Volakva et al. 2002 145 | Blinding? | UNCLEAR | Reported as a DB trial; clinicians who adjusted the dosing and outcome assessors were blinded. Patients were blinded to BDZ, not to the antipsychotics.
Volakva et al. 2002 145 | Incomplete outcome data addressed? | YES | 101 patients randomized, and 101 patients analyzed. No clear description of how many randomized.
Volakva et al. 2002 145 | Free of selective reporting? | UNCLEAR | NOSIE and ESRS are in method section. But, no numeric data is reported in results, just F-value, degrees of freedom, and p-value are reported.
Volakva et al. 2002 145 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Wright et al. 2001 147 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Wright et al. 2001 147 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Wright et al. 2001 147 | Blinding? | YES | Reported as a DB trial. Drugs and placebo administered in identical, color-blinded, translucent syringes; raters and study personnel blind to treatment assignment.
Wright et al. 2001 147 | Incomplete outcome data addressed? | YES | ITT not reported but 285/311 (92%) included in analysis.
Wright et al. 2001 147 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Wright et al. 2001 147 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Wynn et al. 2007 148 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Wynn et al. 2007 148 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Wynn et al. 2007 148 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Wynn et al. 2007 148 | Incomplete outcome data addressed? | NO | ITT not reported. 51/100 (51%) included in analysis.
Wynn et al. 2007 148 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Wynn et al. 2007 148 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

BDZ = benzodiazepine; BPRS = Brief Psychiatric Rating Scale; DB = double-blind; CGI–S = Clinical Global Impressions–Severity; ESRS = Extrapyramidal Symptom Rating Scale; ITT = intention-to-treat analysis; LOCF = last observation carried forward; NOSIE = Nurses’ Observation Scale for Inpatient Evaluation; PANSS = Positive and Negative Symptom Scale

Table 12 Risk of bias–haloperidol versus quetiapine

Study | Item | Judgment | Description
Arvantis et al. 1997 46 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Arvantis et al. 1997 46 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Arvantis et al. 1997 46 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Arvantis et al. 1997 46 | Incomplete outcome data addressed? | YES | ITT principle not used, but 99% of participants included in the analyses.
Arvantis et al. 1997 46 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Arvantis et al. 1997 46 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Atmaca et al. 2002 47 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no futher details regarding sequence generation.
Atmaca et al. 2002 47 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Atmaca et al. 2002 47 | Blinding? | UNCLEAR | This study was not reported as blinded, and there was not reporting of any blinding.
Atmaca et al. 2002 47 | Incomplete outcome data addressed? | UNCLEAR | Reported that all participants completed the study.
Atmaca et al. 2002 47 | Free of selective reporting? | YES | Protocol not available, but outcomes in methods and results match.
Atmaca et al. 2002 47 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Copolov et al. 2000 68 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no futher details regarding sequence generation.
Copolov et al. 2000 68 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Copolov et al. 2000 68 | Blinding? | UNCLEAR | Reported as a DB trial, with no futher details regarding blinding.
Copolov et al. 2000 68 | Incomplete outcome data addressed? | NO | ITT principle not used and attrition rate was high with 33% of participants dropping out from the trial.
Copolov et al. 2000 68 | Free of selective reporting? | YES | Outcomes is the method section match with the results.
Copolov et al. 2000 68 | Free of other bias? | UNCLEAR | Baseline characteristics were similar, with the exception for differences in the subgroup diagnoses of schizoprhenia and AIMS scores. Other sources of bias were not detected.
Davidson et al. 2009 75 | Adequate sequence generation? | YES | Reported the use of a centralized computerized online randomization system.
Davidson et al. 2009 75 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Davidson et al. 2009 75 | Blinding? | NO | Reported as an open-label trial.
Davidson et al. 2009 75 | Incomplete outcome data addressed? | NO | ITT principle was not used, and attrition was high, with 43% of participants not completing the trial.
Davidson et al. 2009 75 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Davidson et al. 2009 75 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Emsley et al. 2000 79 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Emsley et al. 2000 79 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Emsley et al. 2000 79 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Emsley et al. 2000 79 | Incomplete outcome data addressed? | YES | Modified ITT using LOCF on those who received drug and had at least one followup observation. 98% analyzed.
Emsley et al. 2000 79 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Emsley et al. 2000 79 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Emsley et al. 2005 80 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Emsley et al. 2005 80 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Emsley et al. 2005 80 | Blinding? | UNCLEAR | Reported as investigator-blinded trial. No other details about blinding.
Emsley et al. 2005 80 | Incomplete outcome data addressed? | YES | 47 randomized; 33 analyzed; ITT reported (70% completion).
Emsley et al. 2005 80 | Free of selective reporting? | YES | Outcomes in method section are matched to the results.
Emsley et al. 2005 80 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Glick et al. 2005 65 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Glick et al. 2005 65 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Glick et al. 2005 65 | Blinding? | NO | Reported as an open-label trial.
Glick et al. 2005 65 | Incomplete outcome data addressed? | NO | ITT principle was not used, and attrition rate was high, with 66% of participants not available at the end of the trial.
Glick et al. 2005 65 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Glick et al. 2005 65 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Kahn et al. 2008 91 | Adequate sequence generation? | YES | Trial reported patients were randomly assigned by a dedicated web-based online system developed inhouse by the Data Management Department of the Julius Center for Health Sciences and Primary Care.
Kahn et al. 2008 91 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Kahn et al. 2008 91 | Blinding? | NO | Reported as an open-label trial. Patients and their treating psychiatrists were unmasked for the assigned treatment.
Kahn et al. 2008 91 | Incomplete outcome data addressed? | YES | 498 randomized. 498 analyzed. ITT reported. 342 completed followup.
Kahn et al. 2008 91 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Kahn et al. 2008 91 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
McCue et al. 2006 73 | Adequate sequence generation? | YES | Reported that randomization was performed using a website-based randomization scheme (www.randomization.com).
McCue et al. 2006 73 | Allocation concealment? | YES | Reported that the hospital staff with no clinical responsibilities and no knowledge of the patients oversaw the assignment procedure and assigned medications in sequential order, strictly following the randomized list. Also reported that the treating psychiatrist did not have access to this list.
McCue et al. 2006 73 | Blinding? | NO | Reported as an open-label study with both the patient and the treating psychiatrist being aware of the antipsychotic being prescribed.
McCue et al. 2006 73 | Incomplete outcome data addressed? | YES | ITT principle not used during the analysis, but 98% of randomized participants analyzed.
McCue et al. 2006 73 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
McCue et al. 2006 73 | Free of other bias? | UNCLEAR | Reported that there was a significant difference in the age of participants among the 6 treatment groups and a significantly different proportion of patients received additional medications. Other sources of bias were not detected.
Purdon et al. 2001 123 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Purdon et al. 2001 123 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Purdon et al. 2001 123 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Purdon et al. 2001 123 | Incomplete outcome data addressed? | UNCLEAR | Unequal dropout between groups. Analyses included a range of 84% to 100% of patients.
Purdon et al. 2001 123 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Purdon et al. 2001 123 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Velligan et al. 2002 143 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Velligan et al. 2002 143 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Velligan et al. 2002 143 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Velligan et al. 2002 143 | Incomplete outcome data addressed? | UNCLEAR | This is a substudy analysing 58/116 (50%) of eligible patients and excluded dropouts.
Velligan et al. 2002 143 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Velligan et al. 2002 143 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

AIMS = Abnormal Involuntary Movement Scale; DB = double-blind; ITT = intention-to-treat analysis; LOCF = last observation carried forward

Table 13 Risk of bias–haloperidol versus risperidone

Study | Item | Judgment | Description
Apiquain et al. 2008 45 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Apiquain et al. 2008 45 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Apiquain et al. 2008 45 | Blinding? | NO | Reported as an open-label trial.
Apiquain et al. 2008 45 | Incomplete outcome data addressed? | NO | ITT priniciple not used during the analysis, and only data from 53% of participants were included in the analyses.
Apiquain et al. 2008 45 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
Apiquain et al. 2008 45 | Free of other bias? | UNCLEAR | Baseline characteristics were similar except for educational level, marital status, and occupational status. Other sources of bias were not detected
Blin et al. 1996 52 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Blin et al. 1996 52 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Blin et al. 1996 52 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Blin et al. 1996 52 | Incomplete outcome data addressed? | UNCLEAR | ITT principle used during analysis, but attrition rate was moderate with 10/41 of participants not completing the trial.
Blin et al. 1996 52 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
Blin et al. 1996 52 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Borison et al. 1992 53 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Borison et al. 1992 53 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Borison et al. 1992 53 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Borison et al. 1992 53 | Incomplete outcome data addressed? | YES | ITT principle was used during analyses. Attrition was not reported to have occurred.
Borison et al. 1992 53 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Borison et al. 1992 53 | Free of other bias? | UNCLEAR | Baseline characteristics are presented in tabular format but with no mention of similarity between the groups. Other sources of bias were not detected.
Cavallaro et al. 2001 59 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Cavallaro et al. 2001 59 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Cavallaro et al. 2001 59 | Blinding? | YES | Reported as a DB trial using identical tablets.
Cavallaro et al. 2001 59 | Incomplete outcome data addressed? | UNCLEAR | ITT principle not used in analyses with moderate attrition rate with 22% of participants not completing the trial.
Cavallaro et al. 2001 59 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
Cavallaro et al. 2001 59 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Ceskova et al. 1993 60 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Ceskova et al. 1993 60 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Ceskova et al. 1993 60 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding patient or physcian blinding status provided in trial report.
Ceskova et al. 1993 60 | Incomplete outcome data addressed? | YES | ITT principle not used during analyses, but attrition rate was low with 3/62 patients not completing the trial.
Ceskova et al. 1993 60 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
Ceskova et al. 1993 60 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Chouinard et al. 1993 61 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Chouinard et al. 1993 61 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Chouinard et al. 1993 61 | Blinding? | YES | Reported as a DB trial using identical tablets.
Chouinard et al. 1993 61 | Incomplete outcome data addressed? | YES | ITT principle used during analyses and no reported dropouts.
Chouinard et al. 1993 61 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
Chouinard et al. 1993 61 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Citrome et al. 2001 62 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no futher details regarding sequence generation.
Citrome et al. 2001 62 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Citrome et al. 2001 62 | Blinding? | UNCLEAR | Reported as a DB trial, with blinded raters performed all the clinical assessments and dosage changes requested by blinded psychiatrists, but no description of how the patients were blinded.
Citrome et al. 2001 62 | Incomplete outcome data addressed? | NO | ITT principle was used during analyses, but attrition rate was high, with only 58% of participants completing the trial.
Citrome et al. 2001 62 | Free of selective reporting? | NO | Two outcomes (ESRS and NOSIE) are listed in the method section, but no results are presented.
Citrome et al. 2001 62 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Claus et al. 1992 64 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Claus et al. 1992 64 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Claus et al. 1992 64 | Blinding? | YES | Reported as a DB trial using matched oral solutions of each medication.
Claus et al. 1992 64 | Incomplete outcome data addressed? | YES | ITT principle not used, but 42 (95%) of participants included in the analyses.
Claus et al. 1992 64 | Free of selective reporting? | YES | Protocol was not available but all main outcomes were reported.
Claus et al. 1992 64 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Crespo-Faccoro et al. 2006 71 | Adequate sequence generation? | YES | Reported as a randomized trial using a computer-generated randomization list.
Crespo-Faccoro et al. 2006 71 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Crespo-Faccoro et al. 2006 71 | Blinding? | NO | Reported as an open-label trial.
Crespo-Faccoro et al. 2006 71 | Incomplete outcome data addressed? | YES | ITT principle not used, but attrition rate was low, and 172/182 were included in the analyses.
Crespo-Faccoro et al. 2006 71 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
Crespo-Faccoro et al. 2006 71 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Csernansky et al. 2002 72 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Csernansky et al. 2002 72 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Csernansky et al. 2002 72 | Blinding? | YES | Reported as a DB trial using identical-appearing tablets.
Csernansky et al. 2002 72 | Incomplete outcome data addressed? | YES | ITT principle not used in analyses, but the attrition rate was low with 365/397 participants analyzed.
Csernansky et al. 2002 72 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
Csernansky et al. 2002 72 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
de Sena et al. 2003 77 | Adequate sequence generation? | NO | Reported that randomization was performed based on the time of inclusion assigning patients to groups to even and odd numbers (i.e., quasi-randomization).
de Sena et al. 2003 77 | Allocation concealment? | NO | Allocation concealment was not possible because quasi-randomization was used.
de Sena et al. 2003 77 | Blinding? | UNCLEAR | No details regarding patient or physician blinding was provided in the trial report.
de Sena et al. 2003 77 | Incomplete outcome data addressed? | UNCLEAR | The number randomized was not provided, and there was no mention of dropouts.
de Sena et al. 2003 77 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
de Sena et al. 2003 77 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Emsley et al. 1999 81 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Emsley et al. 1999 81 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Emsley et al. 1999 81 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Emsley et al. 1999 81 | Incomplete outcome data addressed? | YES | ITT performed on all randomized patients.
Emsley et al. 1999 81 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Emsley et al. 1999 81 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Fakra et al. 2008 82 | Adequate sequence generation? | UNCLEAR | Block randomization with no further details.
Fakra et al. 2008 82 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Fakra et al. 2008 82 | Blinding? | NO | Reported as an open-label trial.
Fakra et al. 2008 82 | Incomplete outcome data addressed? | UNCLEAR | 12% dropout with no ITT.
Fakra et al. 2008 82 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Fakra et al. 2008 82 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Heck et al. 2000 85 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Heck et al. 2000 85 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Heck et al. 2000 85 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Heck et al. 2000 85 | Incomplete outcome data addressed? | YES | ITT analysis performed on all 77 (100%) patients.
Heck et al. 2000 85 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Heck et al. 2000 85 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Kee et al. 1998 99 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Kee et al. 1998 99 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Kee et al. 1998 99 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Kee et al. 1998 99 | Incomplete outcome data addressed? | YES | 20 randomized, 18 analyzed. No ITT reported.
Kee et al. 1998 99 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Kee et al. 1998 99 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Keefe et al. 2003 100 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Keefe et al. 2003 100 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Keefe et al. 2003 100 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Keefe et al. 2003 100 | Incomplete outcome data addressed? | NO | ITT principle not used, 16/49 (33%) of participants included in the analyses, but number per treatment group were not reported.
Keefe et al. 2003 100 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Keefe et al. 2003 100 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Keefe et al. 2006 101 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Keefe et al. 2006 101 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Keefe et al. 2006 101 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Keefe et al. 2006 101 | Incomplete outcome data addressed? | YES | 414 patients randomized. ITT reported. 414 analyzed.
Keefe et al. 2006 101 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Keefe et al. 2006 101 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Kim et al. 2010 102 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Kim et al. 2010 102 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Kim et al. 2010 102 | Blinding? | UNCLEAR | Reported as a DB trial. No further details regarding blinding.
Kim et al. 2010 102 | Incomplete outcome data addressed? | UNCLEAR | No ITT. No data regarding the number of dropouts.
Kim et al. 2010 102 | Free of selective reporting? | YES | Outcomes in the method section match to the results.
Kim et al. 2010 102 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Lee et al. 2007 107 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Lee et al. 2007 107 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Lee et al. 2007 107 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Lee et al. 2007 107 | Incomplete outcome data addressed? | YES | ITT analysis included all 20 patients.
Lee et al. 2007 107 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Lee et al. 2007 107 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Lim et al. 2010 151 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial according to a predefined randomization code that was balanced to ensure even distribution of patients in each treatment group.
Lim et al. 2010 151 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Lim et al. 2010 151 | Blinding? | NO | Reported as an open-label trial, but rater blinded.
Lim et al. 2010 151 | Incomplete outcome data addressed? | YES | ITT & LOCF reported. 124 randomized. 124 analyzed.
Lim et al. 2010 151 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Lim et al. 2010 151 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Liu et al. 2000 111 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial using block randomization in sizes of four with no further details.
Liu et al. 2000 111 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Liu et al. 2000 111 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Liu et al. 2000 111 | Incomplete outcome data addressed? | NO | ITT principle not used, 38/56 (68%) of participants included in the analyses.
Liu et al. 2000 111 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Liu et al. 2000 111 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Marder et al. 1994 114 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Marder et al. 1994 114 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Marder et al. 1994 114 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding the methods used for blinding.
Marder et al. 1994 114 | Incomplete outcome data addressed? | NO | High attrition rates (53%) due to insufficient response, AEs, uncooperative etc.
Marder et al. 1994 114 | Free of selective reporting? | YES | Protocol was not available but all main outcomes were reported.
Marder et al. 1994 114 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias.
Marder et al. 2003 113 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Marder et al. 2003 113 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Marder et al. 2003 113 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Marder et al. 2003 113 | Incomplete outcome data addressed? | YES | 63 patients randomized, 29 completed the study, 63 patients analyzed. No ITT reported.
Marder et al. 2003 113 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Marder et al. 2003 113 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
McCue et al. 2006 73 | Adequate sequence generation? | YES | Reported that randomization was performed using a website-based randomization scheme (www.randomization.com).
McCue et al. 2006 73 | Allocation concealment? | YES | Reported that the hospital staff with no clinical responsibilities and no knowledge of the patients oversaw the assignment procedure and assigned medications in sequential order, strictly following the randomized list. Also reported that the treating psychiatrist did not have access to this list.
McCue et al. 2006 73 | Blinding? | NO | Reported as an open-label study, with both the patient and the treating psychiatrist being aware of the antipsychotic being prescribed.
McCue et al. 2006 73 | Incomplete outcome data addressed? | YES | ITT principle not used during the analysis, but 98% of randomized participants analyzed.
McCue et al. 2006 73 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
McCue et al. 2006 73 | Free of other bias? | UNCLEAR | Reported that there was a significant difference in the age of participants among the 6 treatment groups and a significantly different proportion of patients received additional medications. Other sources of bias were not detected.
Min et al. 1993 117 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Min et al. 1993 117 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Min et al. 1993 117 | Blinding? | YES | All medication was identical and labled with a protocol number.
Min et al. 1993 117 | Incomplete outcome data addressed? | YES | ITT analysis performed on all 35 patients.
Min et al. 1993 117 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Min et al. 1993 117 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Moller et al. 2008 118 | Adequate sequence generation? | UNCLEAR | Block randomization with no further details.
Moller et al. 2008 118 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Moller et al. 2008 118 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Moller et al. 2008 118 | Incomplete outcome data addressed? | YES | The ITT sample comprised all randomized patients except those whose initial diagnosis had been revised. 98% were analyzed.
Moller et al. 2008 118 | Free of selective reporting? | YES | Trial design described in a publication prior to results of trial. Methods match results reported.
Moller et al. 2008 118 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias.
Peuskens et al. 1995 120 | Adequate sequence generation? | YES | Reported as a randomized trial, with no further details regarding sequence generation.
Peuskens et al. 1995 120 | Allocation concealment? | UNCLEAR | Randomized sequence transferred to sealed envelopes, but did not mention that envelopes were opaque.
Peuskens et al. 1995 120 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding the methods used for blinding.
Peuskens et al. 1995 120 | Incomplete outcome data addressed? | UNCLEAR | No ITT reported. Analysis included 1019/1362 (75%) randomized patients.
Peuskens et al. 1995 120 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Peuskens et al. 1995 120 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Purdon et al. 2000 124 | Adequate sequence generation? | YES | Reported as a randomized trial using a computer-generated random number table.
Purdon et al. 2000 124 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Purdon et al. 2000 124 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Purdon et al. 2000 124 | Incomplete outcome data addressed? | YES | 65 randomized, 55 analyzed with LOCF. ITT reported.
Purdon et al. 2000 124 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Purdon et al. 2000 124 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Remillard et al. 2008 125 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Remillard et al. 2008 125 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Remillard et al. 2008 125 | Blinding? | UNCLEAR | The experimenter was blind to the participants' medication and psychopathological status; the clinician assessing psychopathology and EPS was blind to their cognitive performance and medication status.
Remillard et al. 2008 125 | Incomplete outcome data addressed? | YES | All 28 were included in analyses.
Remillard et al. 2008 125 | Free of selective reporting? | YES | Protocol was not available but all main outcomes were reported.
Remillard et al. 2008 125 | Free of other bias? | UNCLEAR | Significant differences in baseline characteristics. Other sources of bias not found.
Schooler et al. 2005 132 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial using 1:1 randomization scheme balanced by site, with no further detail.
Schooler et al. 2005 132 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Schooler et al. 2005 132 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Schooler et al. 2005 132 | Incomplete outcome data addressed? | UNCLEAR | State ITT principle used, but the denominator for primary outcome. They must have analyzed 521/559 (93%) of patients to obtain their result. Over the 2 yrs of trial, there was a 60.4% dropout rate.
Schooler et al. 2005 132 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Schooler et al. 2005 132 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias.
Sergi et al. 2007 134 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Sergi et al. 2007 134 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Sergi et al. 2007 134 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Sergi et al. 2007 134 | Incomplete outcome data addressed? | UNCLEAR | ITT not reported. 73/100 (73%) included in analysis.
Sergi et al. 2007 134 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Sergi et al. 2007 134 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias.
Shrivastava et al. 2000 135 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Shrivastava et al. 2000 135 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Shrivastava et al. 2000 135 | Blinding? | NO | Reported as an open-label study.
Shrivastava et al. 2000 135 | Incomplete outcome data addressed? | UNCLEAR | ITT not reported. 100/125 (80%) included in analysis.
Shrivastava et al. 2000 135 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Shrivastava et al. 2000 135 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias.
Tamrakar et al. 2006 139 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Tamrakar et al. 2006 139 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Tamrakar et al. 2006 139 | Blinding? | NO | Reported as a randomized open-label trial.
Tamrakar et al. 2006 139 | Incomplete outcome data addressed? | UNCLEAR | ITT not reported. 36/45 (80%) included in analysis.
Tamrakar et al. 2006 139 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Tamrakar et al. 2006 139 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias.
Volakva et al. 2002 145 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Volakva et al. 2002 145 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Volakva et al. 2002 145 | Blinding? | UNCLEAR | Reported as a DB trial; clinicians who adjusted the dosing and outcome assessors were blinded. Patients were blinded to BDZ, not to the antipsychotics.
Volakva et al. 2002 145 | Incomplete outcome data addressed? | YES | 101 patients randomized, and 101 patients analyzed. No clear description of how many randomized.
Volakva et al. 2002 145 | Free of selective reporting? | UNCLEAR | NOSIE and ESRS are in method section. But, no numeric data is reported in results, just F-value, degrees of freedom, and p-value are reported.
Volakva et al. 2002 145 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Wirshing et al. 1999 146 | Adequate sequence generation? | YES | Reported as a randomized trial using a computerized random-number-generating program.
Wirshing et al. 1999 146 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Wirshing et al. 1999 146 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Wirshing et al. 1999 146 | Incomplete outcome data addressed? | UNCLEAR | 10–30% dropout with no ITT.
Wirshing et al. 1999 146 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Wirshing et al. 1999 146 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias.
Wynn et al. 2007 148 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Wynn et al. 2007 148 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Wynn et al. 2007 148 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Wynn et al. 2007 148 | Incomplete outcome data addressed? | NO | ITT not reported. 51/100 (51%) included in analysis.
Wynn et al. 2007 148 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Wynn et al. 2007 148 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias.
Yen et al. 2004 149 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Yen et al. 2004 149 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Yen et al. 2004 149 | Blinding? | NO | Single-blind study (rater blinded).
Yen et al. 2004 149 | Incomplete outcome data addressed? | UNCLEAR | Used an endpoint LOCF, but it is not clear if used ITT (41 patients randomized, 14 dropped out) and included all patients.
Yen et al. 2004 149 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Yen et al. 2004 149 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias.
Zhang et al. 2001 150 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Zhang et al. 2001 150 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Zhang et al. 2001 150 | Blinding? | UNCLEAR | Reported as a DB trial, with blinded assessors. No detail about patient blinding.
Zhang et al. 2001 150 | Incomplete outcome data addressed? | YES | ITT not reported but 75/80 (94%) included in analysis.
Zhang et al. 2001 150 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Zhang et al. 2001 150 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

AE = adverse events; BDZ = benzodiazepine; DB = double-blind; EPS = extrapyramidal symptoms; ESRS = Extrapyramidal Symptom Rating Scale; ITT = intention-to-treat analysis; LOCF = last observation carried forward; NOSIE = Nurses’ Observation Scale for Inpatient Evaluation

Table 14 Risk of bias–haloperidol versus ziprasidone

Study | Item | Judgment | Description
Brook et al. 2005 57 | Adequate sequence generation? | UNCLEAR | Reported as randomized trial using a 3:1 randomization ratio, with no further details in the trial report.
Brook et al. 2005 57 | Allocation concealment? | UNCLEAR | Reported as masked randomization schedule consisting of a list of numbers to which the study drugs had been randomly allocated, but there were no details on how the masking was performed.
Brook et al. 2005 57 | Blinding? | NO | Reported that this trial was an open-label, flexible-dose design trial, with all assessments conducted by evaluators blinded to drug allocation.
Brook et al. 2005 57 | Incomplete outcome data addressed? | NO | ITT principle was used with LOCF method used for missing data, but there was a high attrition rate with 33% of participants not completing the trial.
Brook et al. 2005 57 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are consistent.
Brook et al. 2005 57 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Corripio et al. 2005 69 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Corripio et al. 2005 69 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment.
Corripio et al. 2005 69 | Blinding? | NO | Reported as a single-blined trial, with physicians blinded to treatment status and patients not blinded.
Corripio et al. 2005 69 | Incomplete outcome data addressed? | YES | ITT principle used with no reported dropouts.
Corripio et al. 2005 69 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Corripio et al. 2005 69 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Davidson et al. 2009 75 | Adequate sequence generation? | YES | Reported the use of a centralized computerized online randomization system.
Davidson et al. 2009 75 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Davidson et al. 2009 75 | Blinding? | NO | Reported as an open-label trial.
Davidson et al. 2009 75 | Incomplete outcome data addressed? | NO | ITT principle was not used, and attrition was high with 43% of participants not completing the trial.
Davidson et al. 2009 75 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Davidson et al. 2009 75 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Goff et al. 1998 83 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Goff et al. 1998 83 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Goff et al. 1998 83 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Goff et al. 1998 83 | Incomplete outcome data addressed? | NO | ITT reported. Unknown number screened or randomized, 46/90 completed.
Goff et al. 1998 83 | Free of selective reporting? | YES | Outcomes in the method section match to the results.
Goff et al. 1998 83 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Hirsch et al. 2002 86 | Adequate sequence generation? | NO | Reported using a computer-generated pseudo-random code.
Hirsch et al. 2002 86 | Allocation concealment? | UNCLEAR | Reported use of ‘envelope method,’ but no further details provided.
Hirsch et al. 2002 86 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Hirsch et al. 2002 86 | Incomplete outcome data addressed? | UNCLEAR | No ITT. 227/301 (75%) analyzed.
Hirsch et al. 2002 86 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Hirsch et al. 2002 86 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Kahn et al. 2008 91 | Adequate sequence generation? | YES | Trial reported patients were randomly assigned by a dedicated web-based online system developed inhouse by the Data Management Department of the Julius Center for Health Sciences and Primary Care.
Kahn et al. 2008 91 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Kahn et al. 2008 91 | Blinding? | NO | Reported as an open-label trial. Patients and their treating psychiatrists were unmasked for the assigned treatment.
Kahn et al. 2008 91 | Incomplete outcome data addressed? | YES | 498 randomized. 498 analyzed. ITT reported. 342 completed followup.
Kahn et al. 2008 91 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Kahn et al. 2008 91 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
McCue et al. 2006 73 | Adequate sequence generation? | YES | Reported that randomization was performed using a website-based randomization scheme (www.randomization.com).
McCue et al. 2006 73 | Allocation concealment? | YES | Reported that the hospital staff with no clinical responsibilities and no knowledge of the patients oversaw the assignment procedure and assigned medications in sequential order, strictly following the randomized list. Also reported that the treating psychiatrist did not have access to this list.
McCue et al. 2006 73 | Blinding? | NO | Reported as an open-label study with both the patient and the treating psychiatrist being aware of the antipsychotic being prescribed.
McCue et al. 2006 73 | Incomplete outcome data addressed? | YES | ITT principle not used during the analysis but 98% of randomized participants analyzed.
McCue et al. 2006 73 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
McCue et al. 2006 73 | Free of other bias? | UNCLEAR | Reported that there was a significant difference in the age of participants among the six treatment groups and a significantly different proportion of patients received additional medications. Other sources of bias were not detected.
Miceli et al. 2010 116 | Adequate sequence generation? | YES | Reported as a randomized trial: patients were randomly assigned, using a computer-generated protocol.
Miceli et al. 2010 116 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Miceli et al. 2010 116 | Blinding? | NO | Reported as a single blind trial, with no further details regarding blinding.
Miceli et al. 2010 116 | Incomplete outcome data addressed? | UNCLEAR | 59 patients randomized to treatment. 9 patients discontinued treatment (15.25%). Not reported use of ITT.
Miceli et al. 2010 116 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Miceli et al. 2010 116 | Free of other bias? | UNCLEAR | Baseline comparability was unclear. Other sources of bias were not detected.
Potkin et al. 2009 122 | Adequate sequence generation? | YES | Randomization was by computer-generated schedule with a permuted block design.
Potkin et al. 2009 122 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment.
Potkin et al. 2009 122 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Potkin et al. 2009 122 | Incomplete outcome data addressed? | YES | No ITT. The full analysis set included 536 subjects who had at least one post-baseline efficacy assessment. 536/599 (89%) analyzed at end of 40 week phase using LOCF, and 186/186 analyzed after 3 year extension using LOCF (Table 2.)
Potkin et al. 2009 122 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Potkin et al. 2009 122 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

DB = double-blind; ITT = intention-to-treat; LOCF = last observation carried forward

Table 15 Risk of Bias – perphenazine versus aripiprazole

Study | Item | Judgment | Description
Kane et al. 2007 93 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Kane et al. 2007 93 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Kane et al. 2007 93 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Kane et al. 2007 93 | Incomplete outcome data addressed? | UNCLEAR | Modified ITT. Included only subjects who took 1 dose of medication ( LOCF); 75% completed the 6 weeks treatment (25% dropouts).
Kane et al. 2007 93 | Free of selective reporting? | YES | Outcomes in the method section match to the results.
Kane et al. 2007 93 | Free of other bias? | UNCLEAR | It is unclear if baseline characteristics were similar.

DB = double-blind; ITT = intention-to-treat; LOCF = last observation carried forward

Table 16 Risk of bias–perphenazine versus olanzapine

Study | Item | Judgment | Description
Ascher-Svanum et al. 2008 131 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Ascher-Svanum et al. 2008 131 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Ascher-Svanum et al. 2008 131 | Blinding? | NO | Reported as an open-label treatment.
Ascher-Svanum et al. 2008 131 | Incomplete outcome data addressed? | YES | 664 patients randomized. 648 analyzed. No ITT reported.
Ascher-Svanum et al. 2008 131 | Free of selective reporting? | YES | Methods match results reported.
Ascher-Svanum et al. 2008 131 | Free of other bias? | YES | No significant differences between treatment groups.
Lieberman et al. 2005 23 | Adequate sequence generation? | UNCLEAR | Reported as a stratified randomized trial, with no further details regarding sequence generation.
Lieberman et al. 2005 23 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment.
Lieberman et al. 2005 23 | Blinding? | YES | Reported as a DB: patients and assessors blinded.
Lieberman et al. 2005 23 | Incomplete outcome data addressed? | YES | ITT performed on 96% of patients.
Lieberman et al. 2005 23 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Lieberman et al. 2005 23 | Free of other bias? | UNCLEAR | Baseline comparability was unclear. Other sources of bias were not detected.

DB = double-blind; ITT = intention-to-treat

Table 17 Risk of bias–perphenazine versus quetiapine

Study | Item | Judgment | Description
Lieberman et al. 2005 23 | Adequate sequence generation? | UNCLEAR | Reported as a stratified randomized trial, with no further details regarding sequence generation.
Lieberman et al. 2005 23 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment.
Lieberman et al. 2005 23 | Blinding? | YES | Reported as a DB: Patients and assessors blinded.
Lieberman et al. 2005 23 | Incomplete outcome data addressed? | YES | ITT performed on 96% of patients.
Lieberman et al. 2005 23 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Lieberman et al. 2005 23 | Free of other bias? | UNCLEAR | Baseline comparability was unclear. Other sources of bias were not detected.

DB = double-blind; ITT = intention-to-treat

Table 18 Risk of bias–perphenazine versus risperidone

Study | Item | Judgment | Description
Ascher-Svanum et al. 2008 131 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Ascher-Svanum et al. 2008 131 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Ascher-Svanum et al. 2008 131 | Blinding? | NO | Reported as an open-label treatment.
Ascher-Svanum et al. 2008 131 | Incomplete outcome data addressed? | YES | 664 patients randomized. 648 analyzed. No ITT reported.
Ascher-Svanum et al. 2008 131 | Free of selective reporting? | YES | Methods match results reported.
Ascher-Svanum et al. 2008 131 | Free of other bias? | YES | No significant differences between treatment groups.
Lieberman et al. 2005 23 | Adequate sequence generation? | UNCLEAR | Reported as a stratified randomized trial, with no further details regarding sequence generation.
Lieberman et al. 2005 23 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment.
Lieberman et al. 2005 23 | Blinding? | YES | Reported as a DB: patients and assessors blinded.
Lieberman et al. 2005 23 | Incomplete outcome data addressed? | YES | ITT performed on 96% of patients.
Lieberman et al. 2005 23 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Lieberman et al. 2005 23 | Free of other bias? | UNCLEAR | Baseline comparability was unclear. Other sources of bias were not detected.

DB = double-blind; ITT = intention-to-treat

Table 19 Risk of bias–perphenazine versus ziprasidone

Study | Item | Judgment | Description
Lieberman et al. 2005 23 | Adequate sequence generation? | UNCLEAR | Reported as a stratified randomized trial, with no further details regarding sequence generation.
Lieberman et al. 2005 23 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment.
Lieberman et al. 2005 23 | Blinding? | YES | Reported as a DB: patients and assessors blinded.
Lieberman et al. 2005 23 | Incomplete outcome data addressed? | YES | ITT performed on 96% of patients.
Lieberman et al. 2005 23 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Lieberman et al. 2005 23 | Free of other bias? | UNCLEAR | Baseline comparability was unclear. Other sources of bias were not detected.

DB = double-blind; ITT = intention-to-treat

Table 20 Risk of bias– trifluoperazine versus clozapine

Study | Item | Judgment | Description
Rinieris et al. 1980 157 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Rinieris et al. 1980 157 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Rinieris et al. 1980 157 | Blinding? | UNCLEAR | No information reported regarding patient or physcian blinding status.
Rinieris et al. 1980 157 | Incomplete outcome data addressed? | NO | ITT principle was not used in analyses with only 59% of randomized participants included in analyses.
Rinieris et al. 1980 157 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results were similar.
Rinieris et al. 1980 157 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias.

DB = double-blind; ITT = intention-to-treat

### B Bipolar Disorder

Table 21 Risk of bias–chlorpromazine versus clozapine

Study | Item | Judgment | Description
Barbini et al. 1997 48 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Barbini et al. 1997 48 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Barbini et al. 1997 48 | Blinding? | NO | Reported as an open-label trial.
Barbini et al. 1997 48 | Incomplete outcome data addressed? | YES | ITT principle not used, but 90% of randomized participants were included in the analyses.
Barbini et al. 1997 48 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Barbini et al. 1997 48 | Free of other bias? | UNCLEAR | Treatment groups were similar except duration of last euthymic period, which was significantly longer in participants randomized to chlorpromazine. Other sources of bias were not detected.

ITT = intention-to-treat

Table 22 Risk of bias – haloperidol versus aripiprazole

Study | Item | Judgment | Description
Vieta et al. 2005 32 | Adequate sequence generation? | UNCLEAR | Reported as using a fixed randomization schedule, with no further details regarding sequence generation in trial report.
Vieta et al. 2005 32 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Vieta et al. 2005 32 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding patient or physician blinding.
Vieta et al. 2005 32 | Incomplete outcome data addressed? | YES | ITT principle not used, but 338/ 347 participants were included in analyses.
Vieta et al. 2005 32 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
Vieta et al. 2005 32 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Young et al. 2009 33 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Young et al. 2009 33 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Young et al. 2009 33 | Blinding? | UNCLEAR | No information reported regarding patient or physcian blinding status provided in trial report.
Young et al. 2009 33 | Incomplete outcome data addressed? | YES | ITT principle not used and attrition rate was high with 43% of randomized participants not completing the trial.
Young et al. 2009 33 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Young et al. 2009 33 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

DB = double-blind; ITT = intention-to-treat

Table 23 Risk of bias–haloperidol versus olanzapine

Study | Item | Judgment | Description
Moreno et al. 2007 119 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Moreno et al. 2007 119 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Moreno et al. 2007 119 | Blinding? | YES | Reported as a DB trial. The two drugs to be compared had the same appearance and were packaged identically, and matched in order to satisfy the requirements of a DB study.
Moreno et al. 2007 119 | Incomplete outcome data addressed? | YES | All 12 patients included in the analyses.
Moreno et al. 2007 119 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Moreno et al. 2007 119 | Free of other bias? | UNCLEAR | Patients did have statistically significant differences between groups. Other sources of bias were not detected.
Tohen et al. 2003 140 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial. Not clear how the sequence was generated.
Tohen et al. 2003 140 | Allocation concealment? | YES | Allocation concealment was done using a call-in interactive voice response system.
Tohen et al. 2003 140 | Blinding? | UNCLEAR | Blinding was not reported.
Tohen et al. 2003 140 | Incomplete outcome data addressed? | NO | ITT reported 256/453 completed.
Tohen et al. 2003 140 | Free of selective reporting? | YES | All outcomes in methods are apparently reported in results.
Tohen et al. 2003 140 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

DB = double-blind; ITT = intention-to-treat

Table 24 Risk of bias–haloperidol versus quetiapine

Study | Item | Judgment | Description
McIntyre et al. 2005 115 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
McIntyre et al. 2005 115 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
McIntyre et al. 2005 115 | Blinding? | UNCLEAR | Reported as a DB trial; medication was identical in number, form, and color but no mention of assessor blinding.
McIntyre et al. 2005 115 | Incomplete outcome data addressed? | YES | ITT performed on 299/302 randomized patients.
McIntyre et al. 2005 115 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
McIntyre et al. 2005 115 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

DB = double-blind; ITT = intention-to-treat

Table 25 Risk of bias–haloperidol versus risperidone

Study | Item | Judgment | Description
Janicak et al. 2001 90 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Janicak et al. 2001 90 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Janicak et al. 2001 90 | Blinding? | YES | Described as DB using identical-appearing preparations supplied by Janssen Pharmaceutical Products.
Janicak et al. 2001 90 | Incomplete outcome data addressed? | NO | Results tables have no Ns reported, but Table 1 indicates that 25/62 (40%) finished the trial.
Janicak et al. 2001 90 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results match.
Janicak et al. 2001 90 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Sachs et al. 2002 128 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Sachs et al. 2002 128 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Sachs et al. 2002 128 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding patient or physician blinding.
Sachs et al. 2002 128 | Incomplete outcome data addressed? | NO | ITT principle not used in analyses and attrition rate was high with 59/ 105 of participants not completing the trial.
Sachs et al. 2002 128 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
Sachs et al. 2002 128 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Segal et al. 1998 133 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in trial report.
Segal et al. 1998 133 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in trial report.
Segal et al. 1998 133 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding patient or physician blinding.
Segal et al. 1998 133 | Incomplete outcome data addressed? | YES | ITT principle used in analyses.
Segal et al. 1998 133 | Free of selective reporting? | YES | Protocol is not available, but outcomes in the methods and results are similar.
Segal et al. 1998 133 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.
Smulevich et al. 2005 138 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation.
Smulevich et al. 2005 138 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Smulevich et al. 2005 138 | Blinding? | UNCLEAR | Reported as a DB trial, with no further details regarding blinding.
Smulevich et al. 2005 138 | Incomplete outcome data addressed? | YES | ITT not reported but 297/297 (100%) included in analysis.
Smulevich et al. 2005 138 | Free of selective reporting? | YES | Protocol was not available, but outcomes in the methods and results are similar.
Smulevich et al. 2005 138 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

DB = double-blind; ITT = intention-to-treat

Table 26 Risk of bias–haloperidol versus ziprasidone

Study | Item | Judgment | Description
Vieta et al. 2010 144 | Adequate sequence generation? | UNCLEAR | Reported as a randomized trial, with no further details regarding sequence generation in the trial report.
Vieta et al. 2010 144 | Allocation concealment? | UNCLEAR | No information reported regarding allocation concealment in the trial report.
Vieta et al. 2010 144 | Blinding? | UNCLEAR | Reported as a DB, double-dummy, with no further details regarding blinding.
Vieta et al. 2010 144 | Incomplete outcome data addressed? | NO | ITT priniciple used in the analyses, but the attrition rate was high with 57% of participants did not complete the trial.
Vieta et al. 2010 144 | Free of selective reporting? | YES | Protocol not available, but the outcomes in the methods and results are similar.
Vieta et al. 2010 144 | Free of other bias? | YES | No significant differences in baseline characteristics or other sources of bias detected.

DB = double-blind; ITT = intention-to-treat