# Sample Data Extraction and Quality Assessment Forms

Comparative Effectiveness of FGA and SGA

First Versus Second Generation Antipsychotics (Adults)

Outcomes Data Extraction Template (v1.6)1

Risk of Bias (ROB): Randomized Controlled Trials