# Literature Search Strategies

Table A-1 MEDLINE^®^–Ovid Version

Date searched: 15Jul10 (reviews); 22Jul10 (RCTs); 9Aug10 (cohort studies); 13April11 (all study designs); 11Jul11(all study designs) Notes: limit to: RCT/CCT, cohort studies, systematic reviews, English only, 1950–present, adult (19–64 years)
1. exp Schizophrenia/; 2. Schizophrenia, Catatonic/; 3. Schizophrenia, Disorganized/; 4. Schizophrenia, Paranoid/; 5. Psychotic Disorders/; 6. Schizotypal Personality Disorder/; 7. schizophreniform.tw.; 8. (schizoaffective or schizo-affective).tw.; 9. schizophren$.mp.; 10. (dementia adj (praecox or precox)).tw.; 11. (delusional adj2 disorder*).tw.; 12. ((negative or positive) adj syndrome*).tw.; 13. hebephrenia.tw.; 14. exp Bipolar Disorder/; 15. (((bipolar or manic) adj2 (I or II or illness or disorder or psychos?s or depress$)) or mania*).tw.; 16. (BPD or hypoman$ or manic-depressive).tw.; 17. (BP 1 or BP 2 or BP I or BP II).tw.; 18. (cyclothym$ or euthymic).tw.; 19. (acute adj2 mania).tw.; 20. (acute adj2 mixed adj episode*).tw.; 21. (rapid-cycling adj5 bipolar).tw.; 22. (rapid adj2 cycling adj5 bipolar).tw.; 23. (mixed adj2 state* adj3 bipolar).tw.; 24. or/1–23; 25. exp Antipsychotic Agents/; 26. exp Tranquilizing Agents/; 27. (neuroleptic adj2 (agent* or drug*)).tw.; 28. or/25–27; 29. ((first or 1st) adj generation adj antipsychotic*).tw.; 30. chlorpromazine/; 31. 50-53-3.rn.; 32. (Aminazin or Aminazine or Ampliactil or BC 135 or Chlorpromazine or Chlorpromazinum or Clorpromazina or Chlor-Promanyl or Chlorpromados or Chlorderazin or Chlorpromazin or Contomin or Elmarin or Esmind or Fenactil or Fenaktyl or HL 5746 or Largactil or Largactilothiazine or Megaphen or Largactyl or Klooripromatsiini or Klorpromazin or 6 Copin or Trinicalm Forte or Diminex Balsamico Juven Tos or Largatrex or Phenactyl or Proma or Promactil or Promazil or Prozil or Psychozine or Sanpron or Thorazine or Torazina or Wintermin).mp.; 33. Droperidol/; 34. 548-73-2.rn.; 35. (Dehydrobenzoperidol or Dehydrobenzperidol or Deidrobenzperidolo or Dridol or Droleptan or Droperidol or Droperidoli or Droperidolis or Droperidolum or Disifelit or Halkan or Inapsin or Inapsine or Inopsin or Thalamonal or Nilperidol or Properidol or Sintodril or Vetkalm).mp.; 36. fluphenazine/; 37. 69-23-8.rn.; 38. (Dapotum or Elinol or Flufenazina or Fluofenazine or Fluphenazine or Fluorphenazine or Fluphenazinum or Ftorphenazine or Moditen or Pacinol or Sevinol or Siqualon or Triflumethazine or Valamina or Vespazine).mp.; 39. haloperidol/; 40. 52-86-8.rn.; 41. (Aldo or Aloperidin or Aloperidol or Aloperidolo or Brootopon or Dozic or Einalon S or Eukystol or Fortunan or Galoperidol or Haldol or Halojust or Halopal or Haloperidol or Haloperidoli or Haloperidolis or Haloperidolu or Halopoidol or Serenace or Halopidol or Haloper or Halperon or Keselan or Lealgin or Linton or Mixidol or Peluces or Pernox or Serenace or Serenefl or Sernas or Sernel or Serenase or Ulcolind or Uliolind or Vesalium).mp.; 42. loxapine/; 43. 1977-10-2.rn.; 44. (Cloxazepine or CL 62362 or Dibenzacepin or Dibenzoazepine or Hydrofluoride 3170 or LW 3170 or Lossapina or Loksapiini or Loxapin or Loxapina or Loxapine or Loxapinum or Oxilapine or Loxapac or SUM 3170 or Loxitane or Desconex).mp.; 45. perphenazine/; 46. 58-39-9.rn.; 47. (Chlorperphenazine or Chlorpiprazine or Decentan or Emesinal or Etaperazin or Etaperazine or Ethaperazine or Etrafon or F-mon or Fentazin or Mutabon or Perfenazin or Perfenazina or Perfenazinas or Perfenazine or Perphenazin or Perphenazine or Perfenazyna or Perphenazinum or Pertriptyl or Sch 3940 or Thilatazin or Tranquisan or Trifaron or Trilafon or Trilifan or Triptafen or Triphenot or Triavil).mp.; 48. Pimozide/; 49. 2062-78-4.rn.; 50. (Antalon or Opiran or Orap or Pimotsidi or Pimozid or Pimozida or Pimozidas or Pimozide or Pimozidum or Pimozyd).mp.; 51. Prochlorperazine/; 52. 58-38-8.rn.; 53. (Apo-Prochlorazine or Capazine or Chlormeprazine or Compazine or Compro or Dhaperazine or Emelent or Kronocin or Nipodal or Novamin or Nu-Prochlor or Meterazin or Meterazine or Mitil or Prochlorpemazine or Prochlorperazinum or Proclorperazina or Proklooriperatsiini or Proklorperazin or Prorazin or Phenothiazine or Seratil or Stemetil or Tementil or Temetid).mp.; 54. thiothixene/; 55. 5591-45-7.rn.; 56. (Navane or Navaron or Orbinamon or Thiothixene or Tiotikseeni or Tiotixen or Tiotixeno or Tiotixenum or Thixit or Tiotixene).mp.; 57. trifluoperazine/; 58. 117-89-5.rn.; 59. (Cuait D or Cuait N or eskazine or flupazine or Jatrosom or Jalonac or Parstelin or Parmodalin or stelazine or Stelabid or Stelapar or Sycot or Terfluzine or Trifluoperazine or Trifluoperazini Hydrochloridum or triftazin or Trinicalm Forte or Trinicalm Plus).mp.; 60. thioridazine/; 61. 50-52-2.rn.; 62. (Aldazine or Dazithin or Detril or Elperil or Mallorol or Malloryl or Melleril or Meleril or Mellaril or Mellerets or Mellerette or Melleretten or Melleril or Sonapax or Thioridazin or Thioridazine or Thioridazinum or Tioridatsiini or Tioridazin or Tioridazina or Tioridazinas).mp.; 63. methotrimeprazine/; 64. 60-99-1.rn.; 65. (Dedoran or Hirnamin or Hirnamine or Levomepromazine or Levomepromazin or Levomepromazina or Levopromazioni or Levomepromazinum or Levoprome or Levotomin or Mepromazine or Methotrimeprazine or Neurocil or Neozine or Nirvan or Nocinan or Momizan or Nozinane or Sinogan or Levolam or Nozinan or Sinogan or Tisercin or Veractil).mp.; 66. Phenothiazines/ad, to, tu, ct, po, ae [Administration & Dosage, Toxicity, Therapeutic Use, Contraindications, Poisoning, Adverse Effects]; 67. Butyrophenones/ad, to, tu, ct, po, ae; 68. Thioxanthenes/ad, to, tu, ct, po, ae; 69. Dibenzoxazepines/ad, to, tu, ct, po, ae; 70. Indoles/ad, to, tu, ct, po, ae; 71. or/29–70; 72. atypical antipsychotic$.tw.; 73. ((second or 2nd) adj generation adj antipsychotic*).tw.; 74. ((third or 3rd) adj generation adj antipsychotic*).tw.; 75. Asenapine/; 76. 65576-45-6.rn.; 77. (Asenapine or EINECS 265-829-4).mp.; 78. clozapine/; 79. 5786-21-0.rn.; 80. (Clozapin or Clozapina or Clozapine or Clozapinum or Clorazil or Clozaril or FazaClo or Leponex or LX 100-129 or Zaponex).mp.; 81. risperidone/; 82. 106266-06-2.rn.; 83. (Apexidone or Psychodal or Risperdal or Risperidona or Risperidone or Risperidonum or Risperin or Risperilept or Rispolin or Spiron).mp.; 84. olanzapine.mp.; 85. 132539-06-1.rn.; 86. (Zyprexa or Olantsapiini or Olanzapin or Olanzapina or Olanzapinum or Olansek or Zalasta or Zypadhera or Symbyax).mp.; 87. quetiapine.mp.; 88. (111974-69-7 or 111974-72-2).rn.; 89. (Co-Quetiapine or HSDB 7557 or Seroquel).mp.; 90. ziprasidone.mp.; 91. 146939-27-7.rn.; 92. (Zeldox or zeldrox or geodon).mp.; 93. aripiprazole.mp.; 94. 129722-12-9.rn.; 95. (Abilitat or Abilify or Aripiprazole or Discmelt or OPC 31 or OPC 14597).mp.; 96. paliperidone.mp.; 97. 144598-75-4.rn.; 98. (9-Hydroxyrisperidone or Invega or R 76477 or RO76477).mp.; 99. Iloperidone/; 100. 133454-47-4.rn.; 101. (Fanapt or Iloperidone or HP 873 or Zomaril).mp.; 102. Isoxazoles/ad, to, tu, ct, po, ae; 103. Dibenzazepines/ad, to, tu, ct, po, ae; 104. Pyrimidinones/ad, to, tu, ct, po, ae; 105. Piperidines/ad, to, tu, ct, po, ae; 106. Dibenzothiazepines/ct, ad, to, tu, ae, po; 107. Piperazines/ad, tu, to, ct, po, ae; 108. Pirenzepine/tu, ad, to, ct, po, ae; 109. Thiazoles/ad, th, ct, po, to, ae; 110. Quinolones/to, po, ct, ad, tu, ae; 111. or/72–110; 112. and/71,111; 113. and/28,71,111; 114. or/112–113; 115. randomized controlled trial.pt.; 116. controlled clinical trial.pt.; 117. randomi?ed.ab.; 118. placebo*.ab.; 119. drug therapy.fs.; 120. randomly.ab.; 121. trial.ab.; 122. groups.ab.; 123. or/115–122; 124. humans/not (animals and humans).hw,sh.; 125. 123 and 124; 126. and/24,114,125; 127. limit 126 to yr=“1987 – 2010”; 128. limit 127 to english language; 129. limit 126 to yr=“1950 – 1986”; 130. limit 129 to english language; 131. cohort studies/; 132. followup studies/; 133. longitudinal studies/; 134. prospective studies/; 135. Retrospective Studies/; 136. (observation$ or prospectiv$ or retrospectiv$ or cohort$ or control$ or volunteer$ or evaluat$ or compar$ or longitudinal or long term or long-term or longterm or followup or followup or followup).mp. and (study or studies or trial$).ti,ab,sh.; 137. or/131–136; 138. humans.hw,sh.; 139. and/137–138; 140. meta-analysis.mp,pt.; 141. review.pt.; 142. search:.tw.; 143. or/140–142; 144. and/24,114,139; 145. and/24,114,143; 146. limit 145 to yr=“1987 – 2010”; 147. limit 146 to english language; 148. limit 145 to yr=“1950 – 1986”; 149. limit 148 to english language; 150. limit 144 to yr=“1987–2010”; 151. limit 150 to english language; 152. limit 144 to yr=“1950–1986”; 153. limit 152 to english language

CCT = controlled clinical trial; RCT = randomized controlled trial

Table A-2 PsycINFO–Ovid Version

Date searched: 16Jul10; 13April11; 11Jul11 Notes: limit to: RCT/CCT, cohort studies, systematic reviews, English only, 1950-–present
1. exp schizophrenia/; 2. exp “fragmentation (schizophrenia)”/; 3. exp “positive and negative symptoms”/; 4. exp schizoaffective disorder/; 5. exp schizoid personality disorder/; 6. exp schizotypal personality disorder/; 7. exp psychosis/; 8. or/1–7; 9. schizophren*.mp.; 10. (schizoaffective or schizo-affective).tw.; 11. (dementia adj praecox).tw.; 12. (delusional adj2 disorder*).tw.; 13. ((negative or positive) adj syndrome*).tw.; 14. hebephrenia.tw.; 15. or/9–14; 16. or/8,15; 17. exp Bipolar Disorder/; 18. affective psychosis/; 19. mania/; 20. exp affective disorders/; 21. or/17–20; 22. (((bipolar or manic) adj2 (I or II or illness or disorder or psychos?s or depress$)) or mania*).tw.; 23. (BPD or hypoman$ or manic-depressive).tw.; 24. (BP 1 or BP 2 or BP I or BP II).tw.; 25. (cyclothym$ or euthymic).tw.; 26. (acute adj2 mania).tw.; 27. (acute adj2 mixed adj episode*).tw.; 28. (rapid-cycling adj5 bipolar).tw.; 29. (rapid adj2 cycling adj5 bipolar).tw.; 30. (mixed adj2 state* adj3 bipolar).tw.; 31. or/22–30; 32. or/21,31; 33. or/16,32; 34. exp Neuroleptic Drugs/; 35. ((first or 1st) adj generation adj antipsychotic*).tw.; 36. exp Chlorpromazine/; 37. (Aminazin or Aminazine or Ampliactil or BC 135 or Chlorpromazine or Chlorpromazinum or Clorpromazina or Chlor-Promanyl or Chlorpromados or Chlorderazin or Chlorpromazin or Contomin or Elmarin or Esmind or Fenactil or Fenaktyl or HL 5746 or Largactil or Largactilothiazine or Megaphen or Largactyl or Klooripromatsiini or Klorpromazin or 6 Copin or Trinicalm Forte or Diminex Balsamico Juven Tos or Largatrex or Phenactyl or Proma or Promactil or Promazil or Prozil or Psychozine or Sanpron or Thorazine or Torazina or Wintermin).mp.; 38. Droperidol.mp.; 39. (Dehydrobenzoperidol or Dehydrobenzperidol or Deidrobenzperidolo or Dridol or Droleptan or Droperidol or Droperidoli or Droperidolis or Droperidolum or Disifelit or Halkan or Inapsin or Inapsine or Inopsin or Thalamonal or Nilperidol or Properidol or Sintodril or Vetkalm).mp.; 40. exp Fluphenazine/; 41. (Dapotum or Elinol or Flufenazina or Fluofenazine or Fluphenazine or Fluorphenazine or Fluphenazinum or Ftorphenazine or Moditen or Pacinol or Sevinol or Siqualon or Triflumethazine or Valamina or Vespazine).mp.; 42. exp Haloperidol/; 43. (Aldo or Aloperidin or Aloperidol or Aloperidolo or Brootopon or Dozic or Einalon S or Eukystol or Fortunan or Galoperidol or Haldol or Halojust or Halopal or Haloperidol or Haloperidoli or Haloperidolis or Haloperidolu or Halopoidol or Serenace or Halopidol or Haloper or Halperon or Keselan or Lealgin or Linton or Mixidol or Peluces or Pernox or Serenace or Serenefl or Sernas or Sernel or Serenase or Ulcolind or Uliolind or Vesalium).mp.; 44. exp Loxapine/; 45. (Cloxazepine or CL 62362 or Dibenzacepin or Dibenzoazepine or Hydrofluoride 3170 or LW 3170 or Lossapina or Loksapiini or Loxapin or Loxapina or Loxapine or Loxapinum or Oxilapine or Loxapac or SUM Sinophenin or Talofen or Talofen or Tomil or Verophen).mp.; 46. exp Perphenazine/; 47. (Chlorperphenazine or Chlorpiprazine or Decentan or Emesinal or Etaperazin or Etaperazine or Ethaperazine or Etrafon or F-mon or Fentazin or Mutabon or Perfenazin or Perfenazina or Perfenazinas or Perfenazine or Perphenazin or Perphenazine or Perfenazyna or Perphenazinum or Pertriptyl or Sch 3940 or Thilatazin or Tranquisan or Trifaron or Trilafon or Trilifan or Triptafen or Triphenot or Triavil).mp.; 48. Pimozide/; 49. (Antalon or Opiran or Orap or Pimotsidi or Pimozid or Pimozida or Pimozidas or Pimozide or Pimozidum or Pimozyd).mp.; 50. Prochlorperazine/; 51. (Apo-Prochlorazine or Capazine or Chlormeprazine or Compazine or Compro or Dhaperazine or Emelent or Kronocin or Nipodal or Novamin or Nu-Prochlor or Meterazin or Meterazine or Mitil or Prochlorpemazine or Prochlorperazinum or Proclorperazina or Prochlorperazine or Proklooriperatsiini or Proklorperazin or Prorazin or Phenothiazine or Seratil or Stemetil or Tementil or Temetid).mp.; 52. exp Thioridazine/; 53. (Aldazine or Dazithin or Detril or Elperil or Mallorol or Malloryl or Melleril or Meleril or Mellaril or Mellerets or Mellerette or Melleretten or Melleril or Sonapax or Thioridazin or Thioridazine or Thioridazinum or Tioridatsiini or Tioridazin or Tioridazina or Tioridazinas).mp.; 54. exp Thiothixene/; 55. (Navane or Navaron or Orbinamon or Tiotixene or Tiotikseeni or Tiotixen or Tiotixeno or Tiotixenum or Thixit or Tiotixene or Thiothixene).mp.; 56. exp Trifluoperazine/; 57. (Cuait D or Cuait N or eskazine or flupazine or Jatrosom or Jalonac or Parstelin or Parmodalin or stelazine or Stelabid or Stelapar or Sycot or Terfluzine or Trifluoperazine or Trifluoperazini Hydrochloridum or triftazin or Trinicalm Forte or Trinicalm Plus or Trifluperazine).mp.; 58. or/35–57; 59. ((second or 2nd) adj generation adj antipsychotic*).tw.; 60. ((third or 3rd) adj generation adj antipsychotic*).tw.; 61. exp Aripiprazole/; 62. (Abilitat or Abilify or Aripiprazole or Discmelt or OPC 31 or OPC 14597).mp.; 63. Asenapine.mp.; 64. (Blonanserin or AD 5423).mp.; 65. Iloperidone.mp.; 66. (Fanapt or HP 873 or Zomaril).mp.; 67. exp Olanzapine/; 68. (Zyprexa or Olantsapiini or Olanzapin or Olanzapina or Olanzapinum or Olansek or Olanzapine or Zalasta or Zypadhera or Symbyax).mp.; 69. paliperidone.tw.; 70. (9-Hydroxyrisperidone or Invega or R 76477 or RO76477).mp.; 71. exp Quetiapine/; 72. (Co-Quetiapine or HSDB 7557 or Quetiapine or Seroquel).mp.; 73. exp Risperidone/; 74. (Apexidone or Psychodal or Risperdal or Risperidona or Risperidone or Risperidonum or Risperin or Risperilept or Rispolin or Spiron).mp.; 75. ziprasidone.tw.; 76. (Zeldox or zeldrox or geodon).mp.; 77. or/59–76; 78. or/34,58,77; 79. or/58,77; 80. or/78–79; 81. randomi?ed controlled trial.tw,pt.; 82. exp Clinical Trials/; 83. controlled clinical trial.tw,pt.; 84. randomi?ed.ab.; 85. placebo*.ab.; 86. randomly.ab.; 87. trial.ab.; 88. groups.ab.; 89. or/81–88; 90. exp Animals/; 91. 89 not 90; 92. and/33,80,91; 93. limit 92 to english language; 94. limit 93 to (adulthood <18+ years> and “300 adulthood “); 95. exp Clinical Trials/; 96. clinical trial:.mp.; 97. random:.tw.; 98. placebo:.mp.; 99. double-blind:.mp.; 100. or/95–99; 101. and/33,80,100; 102. limit 101 to english language; 103. limit 102 to yr=“1950 – 1986”; 104. limit 102 to (adulthood <18+ years> and “300 adulthood “); 105. limit 104 to “0100 journal”; 106. exp Followup Studies/; 107. exp longitudinal studies/; 108. exp prospective studies/; 109. exp retrospective studies/; 110. (observation$ or prospectiv$ or cohort$ or longitudinal or long term or long-term or longterm or followup or followup or followup).mp. and (study or studies or trial$).ti,ab,sh.; 111. or/106–110; 112. exp Animals/; 113. 111 not 112; 114. and/33,80,113; 115. limit 114 to english language; 116. limit 115 to yr=“1950 – 1986”; 117. limit 115 to “0100 journal”; 118. meta-analys?s.mp.; 119. search:.tw.; 120. review:.mp.; 121. or/118–120; 122. and/33,80,121; 123. and/33,80; 124. limit 123 to “0830 systematic review”; 125. or/122,124; 126. limit 125 to english language; 127. limit 126 to (adulthood <18+ years> and “300 adulthood “); 128. limit 127 to “0100 journal”; 129. adult*.mp.; 130. 125 and 129; 131. limit 130 to “0100 journal”; 132. 128 or 131; 133. limit 132 to yr=“1950 – 1986”

CCT = controlled clinical trial; RCT = randomized controlled trial

Table A-3 Cochrane Database of Systematic Reviews, Database of Abstracts of Reviews of Effects–Wiley Version, International Pharmaceutical Abstracts (IPAB)

Date searched: 19Jul10; 4Oct10; 13April11; 11Jul11 Notes: text word searching for CDSR, CENTRAL, IPA
1. schizophren$.mp.; 2. (schizoaffective or schizo-affective).tw.; 3. (delusional adj2 disorder*).tw.; 4. ((negative or positive) adj syndrome*).tw.; 5. hebephrenia.tw.; 6. Schizo$.mp.; 7. or/1–6; 8. bipolar$.mp.; 9. (manic or mania).mp.; 10. (acute adj2 mixed adj episode*).tw.; 11. (BP 1 or BP 2 or BP I or BP II).tw.; 12. (BPD or hypoman$ or manic-depressive).tw.; 13. or/8–12; 14. 7 or 13; 15. (antipsychotic adj2 (drug* or agent*)).mp.; 16. (neuroleptic adj2 (drug* or agent*)).mp.; 17. or/15–16; 18. (Aminazin or Aminazine or Ampliactil or BC 135 or Chlorpromazine or Chlorpromazinum or Clorpromazina or Chlor-Promanyl or Chlorpromados or Chlorderazin or Chlorpromazin or Contomin or Elmarin or Esmind or Fenactil or Fenaktyl or HL 5746 or Largactil or Largactilothiazine or Megaphen or Largactyl or Klooripromatsiini or Klorpromazin or 6 Copin or Trinicalm Forte or Diminex Balsamico Juven Tos or Largatrex or Phenactyl or Proma or Promactil or Promazil or Prozil or Psychozine or Sanpron or Thorazine or Torazina or Wintermin).mp.; 19. (Dehydrobenzoperidol or Dehydrobenzperidol or Deidrobenzperidolo or Dridol or Droleptan or Droperidol or Droperidoli or Droperidolis or Droperidolum or Disifelit or Halkan or Inapsin or Inapsine or Inopsin or Thalamonal or Nilperidol or Properidol or Sintodril or Vetkalm).mp.; 20. (Dapotum or Elinol or Flufenazina or Fluofenazine or Fluphenazine or Fluorphenazine or Fluphenazinum or Ftorphenazine or Moditen or Pacinol or Sevinol or Siqualon or Triflumethazine or Valamina or Vespazine).mp.; 21. (Aldo or Aloperidin or Aloperidol or Aloperidolo or Brootopon or Dozic or Einalon S or Eukystol or Fortunan or Galoperidol or Haldol or Halojust or Halopal or Haloperidol or Haloperidoli or Haloperidolis or Haloperidolu or Halopoidol or Serenace or Halopidol or Haloper or Halperon or Keselan or Lealgin or Linton or Mixidol or Peluces or Pernox or Serenace or Serenefl or Sernas or Sernel or Serenase or Ulcolind or Uliolind or Vesalium).mp.; 22. (Cloxazepine or CL 62362 or Dibenzacepin or Dibenzoazepine or Hydrofluoride 3170 or LW 3170 or Lossapina or Loksapiini or Loxapin or Loxapina or Loxapine or Loxapinum or Oxilapine or Loxapac or SUM Sinophenin or Talofen or Talofen or Tomil or Verophen).mp.; 23. (Chlorperphenazine or Chlorpiprazine or Decentan or Emesinal or Etaperazin or Etaperazine or Ethaperazine or Etrafon or F-mon or Fentazin or Mutabon or Perfenazin or Perfenazina or Perfenazinas or Perfenazine or Perphenazin or Perphenazine or Perfenazyna or Perphenazinum or Pertriptyl or Sch 3940 or Thilatazin or Tranquisan or Trifaron or Trilafon or Trilifan or Triptafen or Triphenot or Triavil).mp.; 24. (Antalon or Opiran or Orap or Pimotsidi or Pimozid or Pimozida or Pimozidas or Pimozide or Pimozidum or Pimozyd).mp.; 25. (Apo-Prochlorazine or Capazine or Chlormeprazine or Compazine or Compro or Dhaperazine or Emelent or Kronocin or Nipodal or Novamin or Nu-Prochlor or Meterazin or Meterazine or Mitil or Prochlorpemazine or Prochlorperazinum or Proclorperazina or Prochlorperazine or Proklooriperatsiini or Proklorperazin or Prorazin or Phenothiazine or Seratil or Stemetil or Tementil or Temetid).mp.; 26. (Aldazine or Dazithin or Detril or Elperil or Mallorol or Malloryl or Melleril or Meleril or Mellaril or Mellerets or Mellerette or Melleretten or Melleril or Sonapax or Thioridazin or Thioridazine or Thioridazinum or Tioridatsiini or Tioridazin or Tioridazina or Tioridazinas).mp.; 27. (Navane or Navaron or Orbinamon or Tiotixene or Tiotikseeni or Tiotixen or Tiotixeno or Tiotixenum or Thixit or Tiotixene or Thiothixene).mp.; 28. (Cuait D or Cuait N or eskazine or flupazine or Jatrosom or Jalonac or Parstelin or Parmodalin or stelazine or Stelabid or Stelapar or Sycot or Terfluzine or Trifluoperazine or Trifluoperazini Hydrochloridum or triftazin or Trinicalm Forte or Trinicalm Plus or Trifluperazine).mp.; 29. ((first or 1st) adj2 generation adj2 antipsychotic*).tw.; 30. or/18–29; 31. ((second or 2nd) adj generation adj antipsychotic*).tw.; 32. ((third or 3rd) adj generation adj antipsychotic*).tw.; 33. (Abilitat or Abilify or Aripiprazole or Discmelt or OPC 31 or OPC 14597).mp.; 34. (Asenapine or Blonanserin or AD 5423).mp.; 35. (Fanapt or HP 873 or Iloperidone or Zomaril).mp.; 36. (Zyprexa or Olantsapiini or Olanzapin or Olanzapina or Olanzapinum or Olansek or Olanzapine or Zalasta or Zypadhera or Symbyax).mp.; 37. (9-Hydroxyrisperidone or Invega or Paliperidone or R 76477 or RO76477).mp.; 38. (Co-Quetiapine or HSDB 7557 or Quetiapine or Seroquel).mp.; 39. (Apexidone or Psychodal or Risperdal or Risperidona or Risperidone or Risperidonum or Risperin or Risperilept or Rispolin or Spiron).mp.; 40. (Zeldox or zeldrox or Ziprasidone or geodon).mp.; 41. or/31–40; 42. and/14,30,41; 43. and/14,17,30,41; 44. or/42–43; 45. adult*.mp.; 46. 44 and 45; 47. (pediatric or child* or youth or teen* or adolescen* or elderly or aged).mp.; 48. 44 not 47; 49. or/46,48; 50. randomi?ed.mp.; 51. trial*.tw.; 52. random:.tw.; 53. or/50–52; 54. and/49,53; 55. and/44,53; 56. (cohort$ or longitudinal or retrospective or prospective or followup or case-control).mp.; 57. and/49,56; 58. limit 57 to yr=“1987–current”; 59. limit 57 to yr=“1950–1986”; 60. review:.mp.; 61. search:.tw.; 62. meta-analys?s:.mp.; 63. or/60–62; 64. and/49,63; 65. and/44,63; 66. limit 55 to (english language and yr=“1987 –Current”) [Limit not valid in CCTR,CDSR; records were retained]; 67. limit 55 to yr=“1950–1986”; 68. limit 44 to (english language and yr=“1987 –current”) [Limit not valid in CCTR,CDSR; records were retained]; 69. limit 44 to yr=“1950–1986”

CDSR = Cochrane Database of Systematic Reviews; IPA = International Pharmaceutical Abstracts

Table A-4 CINAHL^®^ (Cumulative Index to Nursing & Allied Health Literature)–EBSCO Version

Date searched: 21Jul10; 13April11; 11Jul11
S1 (MH “Schizophrenia+”); S2 (MH “Schizotypal Personality Disorder”); S3 schizophren* or schizotypal or ( schizoaffective or schizo-affective ) or ( dementia praecox OR dementia precox ) or negative syndrome or positive syndrome or hebephrenia; S4 (MH “Bipolar Disorder+”); S5 bipolar illness* or bipolar disorder* or bipolar psychos* or bipolar depress* or ( BPD OR BP1 or BP2 or BP I or BP II ); S6 manic illness* or manic disorder* or manic psychos* or ( manic depress* or manic-depress* ) or hypoman*; S7 cyclothym* or euthymic or rapid-cycling or mixed state; S8 S1 or S2 or S3 or S4 or S5 or S6 or; S9 (MH “Antipsychotic Agents+”); S10 first generation antipsychotic* or 1st generation antipsychotic; S11 MH chlorpromazine or TX chlorpromazine; S12 (“droperidol”) or (MH “Droperidol”); S13 (“fluphenazine”) or (MH “Fluphenazine”); S14 (“haloperidol”) or (MH “Haloperidol”); S15 loxapine; S16 perphenazine; S17 pimozide; S18 (“prochlorperazine”) or (MH “Prochlorperazine”); S19 Thiothixene; S20 trifluperazine; S21 (“trifluoperazine”) or (MH “Trifluoperazine Hydrochloride”); S22 (“Thioridazine”) or (MH “Thioridazine; S23 methotrimeprazine; S24 S10 or S11 or S12 or S13 or S14 or S15 or S16 or S17 or S18 or S19 or S20 or S21 or S22 or S23; S25 second generation antipsychotic* or 2nd generation antipsychotic*; S26 asenapine; S27 (“clozapine”) or (MH “Clozapine; S28 (“risperidone”) or (MH “Risperidone”); S29 (“olanzapine”) or (MH “Olanzapine”); S30 (“quetiapine”) or (MH “Quetiapine”); S31 ziprasidone; S32 (“Aripiprazole”) or (MH “Aripiprazole”); S33 paliperidone; S34 iloperidone; S35 S25 or S26 or S27 or S28 or S29 or S30 or S31 or S32 or S33 or S34; S36 randomi$ed or random* or TX trial*; S37 (MH “Clinical Trials+”); S38 S36 or S37; S40 S8 and S24 and S35 and S38 Limiters - Human; Language: English; Age Groups: Adult: 19–44 years, Middle Aged: 45–64 years; S39 S8 and S24 and S35 and S38

Table A-5 SCOPUS

Date searched: 1987–Present (22Jul10); 1950–1986 (04Oct10); 13April11; 11Jul11
1987–Present
(((((TITLE-ABS-KEY((schizophren* OR schizotypal OR schizoaffective OR schizo-affective OR hebephrenia) OR (dementia PRE/1 pr?ecox) OR (bipolar W/2 disorder*) OR (bipolar W/2 illness*) OR (bipolar W/2 psychos?s) OR (bipolar W/2 depress*) OR (bpd OR bp1 OR bp2 OR bp i OR bp ii) OR (hypoman* OR manic-depress OR cyclothym* OR euthymic OR rapid-cycling))) AND (KEY(antipsychotic* OR neuroleptic*)) AND ((TITLE-ABS-KEY((first PRE/1 generation PRE/1 antipsychotic*) OR (1st PRE/1 generation PRE/1 antipsychotic) OR (first PRE/1 generation PRE/1 neuroleptic*) OR (1st PRE/1 generation PRE/1 neuroleptic*) OR (typical PRE/1 antipsychotic*) OR (typical PRE/1 neuroleptic*))) OR (TITLE-ABS-KEY((chlorpromazine) OR (droperidol) OR (fluphenazine) OR (haloperidol) OR (loxapine) OR (perphenazine) OR (pimozide) OR (prochlorperazine) OR (thiothixene OR tiotixene) OR (trifluoperazine) OR (thioridazine) OR (methotrimeprazine)))) AND ((TITLE-ABS-KEY((second PRE/1 generation PRE/1 antipsychotic*) OR (2nd PRE/1 generation PRE/1 antipsychotic) OR (second PRE/1 generation PRE/1 neuroleptic*) OR (2nd PRE/1 generation PRE/1 neuroleptic*) OR (atypical PRE/1 antipsychotic*) OR (atypical PRE/1 neuroleptic*))) OR (TITLE-ABS-KEY((asenapine) OR (clozapine) OR (risperidone) OR (olanzapine OR symbyax) OR (quetiapine) OR (ziprasidone OR zeldox OR geodon) OR (aripiprazole) OR (paliperidone) OR (iloperidone))))) AND (LANGUAGE(english)) AND (PUBYEAR AFT 1986)) AND (SRCTYPE(j))) AND (TITLE-ABS-KEY((rct OR random* OR trial*) OR (control* PRE/2 trial*) OR (clinical PRE/2 trial*)))) AND (DOCTYPE(ar)) AND (KEY(human))
1950–1986
((((((TITLE-ABS-KEY((schizophren* OR schizotypal OR schizoaffective OR schizo-affective OR hebephrenia) OR (dementia PRE/1 pr?ecox) OR (bipolar W/2 disorder*) OR (bipolar W/2 illness*) OR (bipolar W/2 psychos?s) OR (bipolar W/2 depress*) OR (bpd OR bp1 OR bp2 OR bp i OR bp ii) OR (hypoman* OR manic-depress OR cyclothym* OR euthymic OR rapid-cycling))) AND (KEY(antipsychotic* OR neuroleptic*)) AND ((TITLE-ABS-KEY((first PRE/1 generation PRE/1 antipsychotic*) OR (1st PRE/1 generation PRE/1 antipsychotic) OR (first PRE/1 generation PRE/1 neuroleptic*) OR (1st PRE/1 generation PRE/1 neuroleptic*) OR (typical PRE/1 antipsychotic*) OR (typical PRE/1 neuroleptic*))) OR (TITLE-ABS-KEY((chlorpromazine) OR (droperidol) OR (fluphenazine) OR (haloperidol) OR (loxapine) OR (perphenazine) OR (pimozide) OR (prochlorperazine) OR (thiothixene OR tiotixene) OR (trifluoperazine) OR (thioridazine) OR (methotrimeprazine)))) AND ((TITLE-ABS-KEY((second PRE/1 generation PRE/1 antipsychotic*) OR (2nd PRE/1 generation PRE/1 antipsychotic) OR (second PRE/1 generation PRE/1 neuroleptic*) OR (2nd PRE/1 generation PRE/1 neuroleptic*) OR (atypical PRE/1 antipsychotic*) OR (atypical PRE/1 neuroleptic*))) OR (TITLE-ABS-KEY((asenapine) OR (clozapine) OR (risperidone) OR (olanzapine OR symbyax) OR (quetiapine) OR (ziprasidone OR zeldox OR geodon) OR (aripiprazole) OR (paliperidone) OR (iloperidone))))) AND (LANGUAGE(english)) AND (PUBYEAR BEF 1986)) AND (SRCTYPE(j))) AND (TITLE-ABS-KEY((rct OR random* OR trial*) OR (control* PRE/2 trial*) OR (clinical PRE/2 trial*)))) AND (DOCTYPE(ar)) AND (KEY(human))) AND NOT (KEY(animal*))