# Abbreviations

AE: Adverse event
AHRQ: Agency for Healthcare Research and Quality
APA: American Psychiatric Association
BMI: Body mass index
BPRS: Brief Psychiatric Rating Scale
CATIE: Clinical Antipsychotic Trials of Intervention Effectiveness
CDS–S: Calgary Depression Scale for Schizophrenia
CER: Comparative effectiveness review
CGI–BP: Clinical Global Impression–Bipolar
CGI–I: Clinical Global Impression–Improvement
CGI–S: Clinical Global Impression–Severity
CI: Confidence interval
CNS: Central nervous system
CUtLASS: Cost Utility of the Latest Antipsychotic Drugs in Schizophrenia Study
ECG: Electrocardiogram
EPC: Evidence-based Practice Center
EPS: Extrapyramidal symptom or syndrome
FDA: Food and Drug Administration
FGA: First-generation antipsychotic
GAF: Global Assessment of Functioning
GAS: Global Assessment Scale
HAM–A: Hamilton Rating Scale for Anxiety
HAM–D: Hamilton Rating Scale for Depression
I^2^: I-squared
IQR: Interquartile range
KQ: Key question
MADRS: Montgomery-Asberg Depression Rating Scale
MD: Mean difference
nRCTs: Nonrandomized controlled trial
PANSS: Positive and Negative Symptom Scale
RCT: Randomized controlled trial
SAE: Serious adverse event
SANS: Scale for the Assessment of Negative Symptoms
SAPS: Scale for the Assessment of Positive Symptoms
SCL: Symptom Checklist
SoE: Strength of evidence
SGA: Second-generation antipsychotic
YMRS: Young Mania Rating Scale