# Technical Expert Panel

Doug Campos-Outcalt, M.D., M.P.A.

Associate Head, Family and Community Medicine

Assistant Dean, Outreach and Multicultural Affairs

University of Arizona College of Medicine

Phoenix, AZ

Mark Frye, M.D., Ph.D.

Mayo Clinic Department of Psychiatry and Psychology

Rochester MN

Consultant and Professor of Psychiatry

UCLA Neuropsychiatric Institute

UCLA Medical Center

Los Angeles, CA

Gerald Gartlehner, M.D., M.PH.

Donau-Universität Krems

Department für Evidenzbasierte Medizin und Klinische Epidemiologie

Krems, Austria

Bradley N. Gaynes, M.D., M.P.H.

Associate Professor of Psychiatry

University of North Carolina School of Medicine

Chapel Hill, NC

Sidney H. Kennedy, FRCPC, M.B.B.S., M.D.

Clinical Department Head

Toronto General Hospital University Health Network

Toronto, ON Canada

Esther Konigsberg, M.D.

Assistant Clinical Professor, Department of Family Medicine

McMaster University

Hamilton, ON Canada

Assistant Clinical Professor, Department of Medicine

University of Arizon Center for Integrative Medicine

Tuscson, AZ

Anthony Levitt, Ph.D., M.B.B.S., FRCPC

Sunnybrook Health Sciences Centre

Toronto, ON Canada

Roger S. McIntyre, M.D., FRCPC

Head, Mood Disorders Psychopharmacology Unit

University Health Network

Associate Professor of Psychiatry and Pharmacology

University of Toronto

Toronto, ON Canada

David Price, M.D., CCFP, FCFP

Chair and Associate Professor, Department of Family Medicine

Faculty of Health Sciences

McMaster University Hamilton Health Sciences

Hamilton, ON Canada

Rhonda J. Robinson Beale, M.D.

Chief Medical Officer

United Behavioral Health

Glendale, CA