# References

1 Carvalho AF, Cavalcante JL, Castelo MS, et al. Augmentation strategies for treatment-resistant depression: A literature review. J Clin Pharm Ther. 2007;32(5):415-28. ISI:000249450400001. [pmid: 17875106].
2 Souery D, Papakostas GI, Trivedi MH. Treatment-resistant depression. J Clin Psychiatry. 2006;67(Suppl 6):16-22. [pmid: 16848672].
3 McIntyre RS, Fallu A, Konarski JZ. Measurable outcomes in psychiatric disorders: Remission as a marker of wellness. Clin Ther. 2006;28(11):1882-91. [pmid: 17213009].
4 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders IV. 1994. http://allpsych.com/disorders/dsm.html.
5 Judd LL, Rapaport MH, Paulus MP, et al. Subsyndromal symptomatic depression: A new mood disorder?. J Clin Psychiatry. 1994;55(Suppl):18-28. [pmid: 8077164].
6 Kessler RC, Berglund P, Demler O, et al. The epidemiology of major depressive disorder - Results from the National Comorbidity Survey Replication (NCS-R). J Am Med Assoc. 2003;289(23):3095-105. ISI:000183560400024.
7 Alonso J, Angermeyer MC, Bernert S, et al. Prevalence of mental disorders in Europe: Results from the European Study of the Epidemiology of Mental Disorders (ESEMeD) project. Acta Psychiatr Scand. 2004;(Suppl 420):21-7. [pmid: 15180776].
8 Beck CA, Patten SB. Adjustment to antidepressant utilization rates to account for depression in remission. Compr Psychiatry. 2004;45(4):268-74. [pmid: 15224269].
9 Brugha T, Jenkins R, Bebbington P, et al. Risk factors and the prevalence of neurosis and psychosis in ethnic groups in Great Britain. Soc Psychiatry Psychiatr Epidemiol. 2004;39(12):939-46. [pmid: 15583900].
10 Kessler RC, Demler O, Frank RG, et al. Prevalence and treatment of mental disorders, 1990 to 2003. N Engl J Med. 2005;352(24):2515-23. [pmid: 15958807].
11 Gonzalez HM, Vega WA, Williams DR, et al. Depression care in the United States: too little for too few. Arch Gen Psychiatry. 2010;67(1):37-46. [pmid: 20048221].
12 Spijker J, de Graaf R, Bijl RV, et al. Duration of major depressive episodes in the general population: Results from The Netherlands Mental Health Survey and Incidence Study (NEMESIS). Br J Psychiatry. 2002;181:208-13. [pmid: 12204924].
13 Birmaher B, Brent D, Bernet W, et al. Practice parameter for the assessment and treatment of children and adolescents with depressive disorders. J Am Acad Child Adolesc Psychiatry. 2007;46(11):1503-26. [pmid: 18049300].
14 US Preventive Services Task Force. Screening and treatment for major depressive disorder in children and adolescents: US Preventive Services Task Force Recommendation Statement. J Am Acad Pediatr. 2009;123(4):1223-8. [pmid: 19336383].
15 Birmaher B, Ryan ND, Williamson DE, et al. Childhood and adolescent depression: A review of the past 10 years, Part II. J Am Acad Child Adolesc Psychiatry. 1996;35(12):1575-83. [pmid: 8973063].
16 Murray CJ, Lopez AD. Evidence-based health policy--lessons from the Global Burden of Disease Study. Science. 1996;274(5288):740-3. [pmid: 8966556].
17 World Health Organization. The World Health Report 2001: Mental health: New understanding, new hope. 2001. Oct. 4. http://www.who.int/whr/2001/en/.
18 The Standing Senate Committee on Social Affairs SaT. Out of the shadows at last: Transforming mental health, mental illness and addiction services in Canada. 2006. http://www.parl.gc.ca/39/1/parlbus/commbus/senate/com-e/soci-e/rep-e/rep02may06-e.htm.
19 Rapaport MH, Clary C, Fayyad R, et al. Quality-of-life impairment in depressive and anxiety disorders. Am J Psychiatry. 2005;162(6):1171-8. [pmid: 15930066].
20 Greenberg PE, Kessler RC, Birnbaum HG, et al. The economic burden of depression in the United States: How did it change between 1990 and 2000?. Clin Psychiatry. 2003;64(12):1465-75.
21 Tompson MC, Pierre CB, Boger KD, et al. Maternal depression, maternal expressed emotion, and youth psychopathology. J Abnorm Child Psychol. 2010;38(1):105-17. [pmid: 19693663].
22 Eckshtain D, Ellis DA, Kolmodin K, et al. The effects of parental depression and parenting practices on depressive symptoms and metabolic control in urban youth with insulin dependent diabetes. J Pediatr Psychol. 2010;35(4):426-35. [pmid: 19710249].
23 Ramchandani P, Stein A. The impact of parental psychiatric disorder on children: Avoiding stigma, improving care. Br Med J. 2003;327(7409):242-3. [pmid: 12896914].
24 Adler DA, McLaughlin TJ, Rogers WH, et al. Job performance deficits due to depression. Am J Psychiatry. 2006;163(9):1569-76. [pmid: 16946182].
25 Lerner D, Adler DA, Chang H, et al. The clinical and occupational correlates of work productivity loss among employed patients with depression. J Occup Environ Med. 2004;46(6 Suppl):S46-55. [pmid: 15194895].
26 Hoge CW, Lesikar SE, Guevara R, et al. Mental disorders among U.S. military personnel in the 1990s: Association with high levels of health care utilization and early military attrition. Am J Psychiatry. 2002;159(9):1576-83. [pmid: 12202280].
27 Ciechanowski PS, Katon WJ, Russo JE. Depression and diabetes: Impact of depressive symptoms on adherence, function, and costs. Arch Intern Med. 2000;160(21):3278-85. [pmid: 11088090].
28 Aro AR, de Koning HJ, Absetz P, et al. Psychosocial predictors of first attendance for organised mammography screening. J Med Screen. 1999;6(2):82-8. [pmid: 10444726].
29 McIntyre RS, Soczynska JK, Konarski JZ, et al. The effect of antidepressants on glucose homeostasis and insulin sensitivity: Synthesis and mechanisms. Expert Opin Drug Saf. 2006;5(1):157-68. [pmid: 16370964].
30 Murphy JM, Horton NJ, Monson RR, et al. Cigarette smoking in relation to depression: Historical trends from the Stirling County Study. Am J Psychiatry. 2003;160(9):1663-9. [pmid: 12944343].
31 Van Gool CH, Kempen GI, Penninx BW, et al. Relationship between changes in depressive symptoms and unhealthy lifestyles in late middle aged and older persons: Results from the Longitudinal Aging Study Amsterdam. Age Ageing. 2003;32(1):81-7. [pmid: 12540353].
32 Kop WJ. The integration of cardiovascular behavioral medicine and psychoneuroimmunology: New developments based on converging research fields. Brain Behav Immun. 2003;17(4):233-7. [pmid: 12831824].
33 Corcos M, Guilbaud O, Hjalmarsson L, et al. Cytokines and depression: An analogic approach. Biomed Pharmacother. 2002;56(2):105-10. [pmid: 12000135].
34 Kop WJ, Gottdiener JS, Tangen CM, et al. Inflammation and coagulation factors in persons > 65 years of age with symptoms of depression but without evidence of myocardial ischemia. Am J Cardiol. 2002;89(4):419-24. [pmid: 11835923].
35 Musselman DL, Miller AH, Porter MR, et al. Higher than normal plasma interleukin-6 concentrations in cancer patients with depression: preliminary findings. Am J Psychiatry. 2001;158(8):1252-7. [pmid: 11481159].
36 Penninx BW, Kritchevsky SB, Yaffe K, et al. Inflammatory markers and depressed mood in older persons: Results from the Health, Aging and Body Composition study. Biol Psychiatry. 2003;54(5):566-72. [pmid: 12946885].
37 Taylor CB, Youngblood ME, Catellier D, et al. Effects of antidepressant medication on morbidity and mortality in depressed patients after myocardial infarction. Arch Gen Psychiatry. 2005;62(7):792-8. [pmid: 15997021].
38 Wassertheil-Smoller S, Shumaker S, Ockene J, et al. Depression and cardiovascular sequelae in postmenopausal women. The Women’s Health Initiative (WHI). Arch Intern Med. 2004;164(3):289-98. [pmid: 14769624].
39 Gilmour H. Depression and risk of heart disease. Health Reports. 82-003-XPE. Statistics Canada. 2008;19(3). http://dsp-psd.pwgsc.gc.ca/collection_2008/statcan/82-003-X/82-003-XIE2008003.pdf.
40 Patten SB, Williams JV, Lavorato DH, et al. Major depression as a risk factor for chronic disease incidence: Longitudinal analyses in a general population cohort. Gen Hosp Psychiatry. 2008;30(5):407-13. [pmid: 18774423].
41 Seguin M, Lesage A, Chawky N, et al. Suicide cases in New Brunswick from April 2002 to May 2003: The importance of better recognizing substance and mood disorder comorbidity. Can J Psychiatry. 2006;51(9):581-6. [pmid: 17007225].
42 Brent D, Emslie G, Clarke G, et al. Switching to another SSRI or to venlafaxine with or without cognitive behavioral therapy for adolescents with SSRI-resistant depression: The TORDIA randomized controlled trial. JAMA. 2008;299(8):901-13. [pmid: 18314433].
43 Williams JW Jr, Pignone M, Ramirez G, et al. Identifying depression in primary care: A literature synthesis of case-finding instruments. Gen Hosp Psychiatry. 2002;24(4):225-37. [pmid: 12100833].
44 Rush AJ, Trivedi MH, Wisniewski SR, et al. Bupropion-SR, sertraline, or venlafaxine-XR after failure of SSRIs for depression. N Engl J Med. 2006;354(12):1231-42. [pmid: 16554525].
45 Bilsker D, Goldner EM, Jones W. Health service patterns indicate potential benefit of supported self-management for depression in primary care. Can J Psychiatry. 2007;52(2):86-95. [pmid: 17375863].
46 Kupfer DJ. Long-term treatment of depression. J Clin Psychiatry. 1991;52(Suppl 5):28-34. [pmid: 1903134].
47 Paykel ES, Ramana R, Cooper Z, et al. Residual symptoms after partial remission: An important outcome in depression. Psychol Med. 1995;25(6):1171-80. [pmid: 8637947].
48 Papakostas GI, Perlis RH, Scalia MJ, et al. A meta-analysis of early sustained response rates between antidepressants and placebo for the treatment of major depressive disorder. J Clin Psychopharmacol. 2006;26(1):56-60. [pmid: 16415707].
49 Posternak MA, Zimmerman M. Is there a delay in the antidepressant effect? A meta-analysis. J Clin Psychiatry. 2005;66(2):148-58. [pmid: 15704999].
50 Taylor MJ, Freemantle N, Geddes JR, et al. Early onset of selective serotonin reuptake inhibitor antidepressant action: Systematic review and meta-analysis. Arch Gen Psychiatry. 2006;63(11):1217-23. [pmid: 17088502].
51 Wade A, Friis Andersen H. The onset of effect for escitalopram and its relevance for the clinical management of depression. Curr Med Res Opin. 2006;22(11):2101-10. [pmid: 17076970].
52 Trivedi MH, Greer TL, Grannemann BD, et al. Exercise as an augmentation strategy for treatment of major depression. J Psychiatr Pract. 2006;12(4):205-13. [pmid: 16883145].
53 Parikh SV, Segal ZV, Grigoriadis S, et al. Canadian Network for Mood and Anxiety Treatments (CANMAT) Clinical guidelines for the management of major depressive disorder in adults. II. Psychotherapy alone or in combination with antidepressant medication. J Affect Disord. 2009;117(Suppl 1):S15-S25. [pmid: 19682749].
54 Ravindran AV, Lam RW, Filteau MJ, et al. Canadian Network for Mood and Anxiety Treatments (CANMAT) Clinical guidelines for the management of major depressive disorder in adults. V. Complementary and alternative medicine treatments. J Affect Disord. 2009;117(Suppl 1):S54-S64. [pmid: 19666194].
55 Qaseem A, Snow V, Denberg TD, et al. Using second-generation antidepressants to treat depressive disorders: A clinical practice guideline from the American College of Physicians. Ann Intern Med. 2008;149(10):725-33. [pmid: 19017591].
56 Hamilton M. A rating scale for depression. J Neurol Neurosurg Psychiatry. 1960;23:56-62. [pmid: 14399272].
57 Montgomery SA, Asberg M. A new depression scale designed to be sensitive to change. Br J Psychiatry. 1979;134:382-9. [pmid: 444788].
58 Uher R, Farmer A, Maier W, et al. Measuring depression: Comparison and integration of three scales in the GENDEP study. Psychol Med. 2008;38(2):289-300. [pmid: 17922940].
59 Riedel M, Moller HJ, Obermeier M, et al. Response and remission criteria in major depression - A validation of current practice. J Psychiatr Res. 2010;44(15):1063-8. [pmid: 20447651].
60 Biak S, Gonzales J, Bowers B. Reinvention of depression instruments by primary care clinicians. Ann Fam Med. 2010;8(3):224-30. [pmid: 20458105].
61 Michell AJ, Vaze A, Rao S. Clinical diagnosis of depression in primary care: A meta-analysis. Lancet. 2009;374(9690):609-19. [pmid: 19640579].
62 Frank E, Prien RF, Jarrett RB, et al. Conceptualization and rationale for consensus definitions of terms in major depressive disorder - Remission, recovery, relapse, and recurrence. Arch Gen Psychiatry. 1991;48(9):851-5. ISI:A1991GF52300010. [pmid: 1929776].
63 Gartlehner G, Hansen RA, Thieda P, et al. Comparative effectiveness of second-generation antidepressants in the pharmacologic treatment of adult depression. Comparative Effectiveness Review Number 7. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
64 Williams AL, Girard C, Jui D, et al. S-adenosylmethionine (SAMe) as treatment for depression: A systematic review. Clin Invest Med. 2005;28(3):132-9. [pmid: 16021987].
65 Souery D, Amsterdam J, de Montigny C, et al. Treatment resistant depression: Methodological overview and operational criteria. Eur Neuropsychopharmacol. 1999;9(1–2):83-91. [pmid: 10082232].
66 Berlim MT, Fleck MP, Turecki G. Current trends in the assessment and somatic treatment of resistant/refractory major depression: An overview. Ann Med. 2008;40(2):149-59. ISI:000253505400007. [pmid: 18293145].
67 Fava M. Diagnosis and definition of treatment-resistant depression. Biol Psychiatr. 2003;53(8):649-59. ISI:000182360400004.
68 Field M, Lohr K. Institute of Medicine, Guidelines for clinical practice: From development to use. Washington, DC. National Academy Press. 1992.
69 Higgins JPT. Cochrane Handbook for Systematic Reviews of Interventions Version 5.0.2. 2008. http://www.cochrane-handbook.org/.
70 Hartling L, Ospina M, Liang Y, et al. Risk of bias versus quality assessment of randomised controlled trials: Cross sectional study. Br Med J. 2009;339:1-6. [pmid: 19841007].
71 Wells GA, Shea B, O’Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Last Accessed February 1, 2009. http://www.ohri.ca/programs/clinical_epidemiology/oxford.htm.
72 Santaguida P, Raina P. Development of a quality assessment scale specific to harms in studies evaluating the efficacy of health technologies: Manual for using the McHarm. 2010. http://hiru.mcmaster.ca/epc/mcharm.pdf.
73 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: Assessing harms when comparing medical interventions: AHRQ and the effective health-care program. J Clin Epidemiol. 2010;63(5):502-12. [pmid: 18823754].
74 The AGREE Next Steps Consortium. Appraisal of guidelines for research and evaluation II (AGREE II). The AGREE Research Trust. 2009. www.agreetrust.org/?o=1397.
75 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: Grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
76 GRADE working group. Grading the quality of evidence and the strength of recommendations. www.gradeworkinggroup.org.
77 Heres S, Davis J, Maino K, et al. Why olanzapine beats resperidone, resperidone beats quetiapine, and quetiapine beats olanzapine: An exploratory analysis of head-to-head comparison studies of second-generation antipsychotics. Am J Psychiatry. 2006;163(2):185-94. [pmid: 16449469].
78 Blumenthal D, Campbell E, Anderson M, et al. Withholding research results in academic life science - Evidence from a national survey of faculty. JAMA. 1997;277(15):1224-8. [pmid: 9103347].
79 Berman RM, Fava M, Thase ME, et al. Aripiprazole augmentation in major depressive disorder: A double-blind, placebo-controlled study in patients with inadequate response to antidepressants. CNS Spect. 2009;14(4):197-206. [pmid: 19407731].
80 Preskorn SH, Baker B, Kolluri S, et al. An innovative design to establish proof of concept of the antidepressant effects of the NR2B subunit selective N-methyl-D-aspartate antagonist, CP-101,606, in patients with treatment-refractory major depressive disorder. J Clin Psychopharmacol. 2008;28(6):631-7. [pmid: 19011431].
81 Rush AJ, Wisniewski SR, Warden D, et al. Selecting among second-step antidepressant medication monotherapies: Predictive value of clinical, demographic, or first-step treatment features. Arch Gen Psychiatry. 2008;65(8):870-80. [pmid: 18678792].
82 Altamura AC, Dell’Osso B, Buoli M, et al. Intravenous augmentative citalopram versus clomipramine in partial/nonresponder depressed patients: A short-term, low dose, randomized, placebo-controlled study. J Clin Psychopharmacol. 2008;28(4):406-10. [pmid: 18626267].
83 Altamura AC, Dell’Osso B, Buoli M, et al. Short-term intravenous citalopram augmentation in partial/nonresponders with major depression: A randomized placebo-controlled study. Int Clin Psychopharmacol. 2008;23(4):198-202. [pmid: 18545057].
84 George TP, Sacco KA, Vessicchio JC, et al. Nicotinic antagonist augmentation of selective serotonin reuptake inhibitor-refractory major depressive disorder: A preliminary study. J Clin Psychopharmacol. 2008;28(3):340-4. [pmid: 18480694].
85 Lenox-Smith AJ, Jiang Q. Venlafaxine extended release versus citalopram in patients with depression unresponsive to a selective serotonin reuptake inhibitor. Int Clin Psychopharmacol. 2008;23(3):113-9. [pmid: 18408525].
86 Dunner DL, Amsterdam JD, Shelton RC, et al. Efficacy and tolerability of adjunctive ziprasidone in treatment-resistant depression: A randomized, open-label, pilot study. J Clin Psychiatry. 2007;68(7):1071-7. [pmid: 17685744].
87 Michelson D, Adler LA, Amsterdam JD, et al. Addition of atomoxetine for depression incompletely responsive to sertraline: A randomized, double-blind, placebo-controlled study. J Clin Psychiatry. 2007;68(4):582-7. [pmid: 17474814].
88 Thase ME, Corya SA, Osuntokun O, et al. A randomized, double-blind comparison of olanzapine/fluoxetine combination, olanzapine, and fluoxetine in treatment-resistant major depressive disorder. J Clin Psychiatry. 2007;68(2):224-36. [pmid: 17335320].
89 Shapira B, Nemets B, Trachtenberg A, et al. Phenytoin as an augmentation for SSRI failures: A small controlled study. J Affect Disord. 2006;96(1–2):123-6. [pmid: 16814397].
90 Thase ME, Shelton RC, Khan A. Treatment with venlafaxine extended release after SSRI nonresponse or intolerance: A randomized comparison of standard- and higher-dosing strategies. J Clin Psychopharmacol. 2006;26(3):250-8. [pmid: 16702889].
91 Seidman SN, Miyazaki M, Roose SP. Intramuscular testosterone supplementation to selective serotonin reuptake inhibitor in treatment-resistant depressed men: Randomized placebo-controlled clinical trial. J Clin Psychopharmacol. 2005;25(6):584-8. [pmid: 16282843].
92 Landen M, Hogberg P, Thase ME. Incidence of sexual side effects in refractory depression during treatment with citalopram or paroxetine. J Clin Psychiatry. 2005;66(1):100-6. [pmid: 15669895].
93 Perry EB, Berman RM, Sanacora G, et al. Pindolol augmentation in depressed patients resistant to selective serotonin reuptake inhibitors: A double-blind, randomized, controlled trial. J Clin Psychiatry. 2004;65(2):238-43. [pmid: 15003079].
94 Wiles NJ, Hollinghurst S, Mason V, et al. A randomized controlled trial of cognitive behavioural therapy as an adjunct to pharmacotherapy in primary care based patients with treatment resistant depression: A pilot study. Behav Cognit Psychother. 2008;36(1):21-33.
95 Keitner GI, Garlow SJ, Ryan CE, et al. A randomized, placebo-controlled trial of risperidone augmentation for patients with difficult-to-treat unipolar, non-psychotic major depression. J Psychiatr Res. 2009;43(3):205-14. [pmid: 18586273].
96 Sokolski KN, Conney JC, Brown BJ, et al. Once-daily high-dose pindolol for SSRI-refractory depression. Psychiatry Res. 2004;125(2):81-6. [pmid: 15006431].
97 Landén M, Björling G, Agren H, et al. A randomized, double-blind, placebo-controlled trial of buspirone in combination with an SSRI in patients with treatment-refractory depression. J Clin Psychiatry. 1998;59(12):664-8. [pmid: 9921700].
98 Fava M, Rosenbaum JF, McGrath PJ, et al. Lithium and tricyclic augmentation of fluoxetine treatment for resistant major depression: A double-blind, controlled study. Am J Psychiatry. 1994;151(9):1372-4. [pmid: 8067495].
99 Fava M, Rush AJ, Alpert JE, et al. Difference in treatment outcome in outpatients with anxious versus nonanxious depression: A STAR*D report. Am J Psychiatry. 2008;165(3):342-51. ISI:000253779400014. [pmid: 18172020].
100 Rush AJ, Warden D, Wisniewski SR, et al. STAR*D: Revising conventional wisdom. CNS Drugs. 2009;23(8):627-47. [pmid: 19594193].
101 Amsterdam JD, Williams D, Michelson D, et al. Tachyphylaxis after repeated antidepressant drug exposure in patients with recurrent major depressive disorder. Neuropsychobiol. 2009;59(4):227-33. [pmid: 19571597].
102 Warden D, Rush AJ, Wisniewski SR, et al. What predicts attrition in second step medication treatments for depression?: A STAR*D Report. Int J Neuropsychopharmacol. 2009;12(4):459-73. [pmid: 18611293].
103 Perahia DG, Quail D, Desaiah D, et al. Switching to duloxetine in selective serotonin reuptake inhibitor non- and partial-responders: Effects on painful physical symptoms of depression. J Psychiatr Res. 2009;43(5):512-8. [pmid: 18707693].
104 Ruhe HG, Booij J, Weert HC, et al. Evidence why paroxetine dose escalation is not effective in major depressive disorder: A randomized controlled trial with assessment of serotonin transporter occupancy. Neuropsychopharmacol. 2009;34(4):999-1010. [pmid: 18830236].
105 Marcus RN, McQuade RD, Carson WH, et al. The efficacy and safety of aripiprazole as adjunctive therapy in major depressive disorder: A second multicenter, randomized, double-blind, placebo-controlled study. J Clin Psychopharmacol. 2008;28(2):156-65. [pmid: 18344725].
106 Perahia DG, Quail D, Desaiah D, et al. Switching to duloxetine from selective serotonin reuptake inhibitor antidepressants: A multicenter trial comparing 2 switching techniques. J Clin Psychiatry. 2008;69(1):95-105. [pmid: 18312043].
107 Alexopoulos GS, Canuso CM, Gharabawi GM, et al. Placebo-controlled study of relapse prevention with risperidone augmentation in older patients with resistant depression. Am J Geriatr Psychiatry. 2008;16(1):21-30. [pmid: 17928573].
108 Mahmoud RA, Pandina GJ, Turkoz I, et al. Risperidone for treatment-refractory major depressive disorder: A randomized trial. Ann Intern Med. 2007;147(9):593-602. [pmid: 17975181].
109 Berman RM, Marcus RN, Swanink R, et al. The efficacy and safety of aripiprazole as adjunctive therapy in major depressive disorder: A multicenter, randomized, double-blind, placebo-controlled study. J Clin Psychiatry. 2007;68(6):843-53. [pmid: 17592907].
110 Thase ME, Friedman ES, Biggs MM, et al. Cognitive therapy versus medication in augmentation and switch strategies as second-step treatments: A STAR*D report. Am J Psychiatry. 2007;164(5):739-52. [pmid: 17475733].
111 Rush AJ, Trivedi MH, Wisniewski SR, et al. Acute and longer-term outcomes in depressed outpatients requiring one or several treatment steps: A STAR*D report. Am J Psychiatry. 2006;163(11):1905-17. [pmid: 17074942].
112 Bondolfi G, Aubry JM, Golaz J, et al. A stepwise drug treatment algorithm to obtain complete remission in depression: A Geneva study. Swiss Med Week. 2006;136(5–6):78-85. [pmid: 16633950].
113 Trivedi MH, Fava M, Wisniewski SR, et al. Medication augmentation after the failure of SSRIs for depression. N Engl J Med. 2006;354(12):1243-52. [pmid: 16554526].
114 Fava M, Thase ME, DeBattista C. A multicenter, placebo-controlled study of modafinil augmentation in partial responders to selective serotonin reuptake inhibitors with persistent fatigue and sleepiness. J Clin Psychiatry. 2005;66(1):85-93. [pmid: 15669893].
115 Birkenhager TK, van den Broek WW, Mulder PG, et al. Efficacy and tolerability of tranylcypromine versus phenelzine: A double-blind study in antidepressant-refractory depressed inpatients. J Clin Psychiatry. 2004;65(11):1505-10. [pmid: 15554763].
116 Perlis RH, Alpert J, Nierenberg AA, et al. Clinical and sociodemographic predictors of response to augmentation, or dose increase among depressed outpatients resistant to fluoxetine 20 mg/day. Acta Psychiatr Scand. 2003;108(6):432-8. [pmid: 14616224].
117 Rocca P, Marchiaro L, Rasetti R, et al. A comparison of paroxetine versus paroxetine plus amisulpride in the treatment of dysthymic disorder: Efficacy and psychosocial outcomes. Psychiatry Res. 2002;112(2):145-52. [pmid: 12429360].
118 Fava M, Alpert J, Nierenberg A, et al. Double-blind study of high-dose fluoxetine versus lithium or desipramine augmentation of fluoxetine in partial responders and nonresponders to fluoxetine. J Clin Psychopharmacol. 2002;22(4):379-87. [pmid: 12172337].
119 Licht RW, Qvitzau S. Treatment strategies in patients with major depression not responding to first-line sertraline treatment. A randomised study of extended duration of treatment, dose increase or mianserin augmentation. Psychopharmacol. 2002;161(2):143-51. [pmid: 11981594].
120 Appelberg BG, Syvalahti EK, Koskinen TE, et al. Patients with severe depression may benefit from buspirone augmentation of selective serotonin reuptake inhibitors: results from a placebo-controlled, randomized, double-blind, placebo wash-in study. J Clin Psychiatry. 2001;62(6):448-52. [pmid: 11465522].
121 Ferreri M, Lavergne F, Berlin I, et al. Benefits from mianserin augmentation of fluoxetine in patients with major depression non-responders to fluoxetine alone. Acta Psychiatr Scand. 2001;103(1):66-72. [pmid: 11202131].
122 Shelton RC, Tollefson GD, Tohen M, et al. A novel augmentation strategy for treating resistant major depression. Am J Psychiatry. 2001;158(1):131-4. [pmid: 11136647].
123 Nemets B, Mishory A, Levine J, et al. Inositol addition does not improve depression in SSRI treatment failures. J Neural Transm. 1999;106(7–8):795-8. [pmid: 10907738].
124 Baumann P, Nil R, Souche A, et al. A double-blind, placebo-controlled study of citalopram with and without lithium in the treatment of therapy-resistant depressive patients: A clinical, pharmacokinetic, and pharmacogenetic investigation. J Clin Psychopharmacol. 1996;16(4):307-14. [pmid: 8835706].
125 Dinan TG. Lithium augmentation in sertraline-resistant depression: A preliminary dose-response study. Acta Psychiatr Scand. 1993;88(4):300-1. [pmid: 8256650].
126 Thase ME, Trivedi MH, Nelson JC, et al. Examining the efficacy of adjunctive aripiprazole in major depressive disorder: A pooled analysis of 2 studies. Prim Care Comp J Clin Psychiatry. 2008;10(6):440-7.
127 Carta MG, Hardoy MC, Pilu A, et al. Improving physical quality of life with group physical activity in the adjunctive treatment of major depressive disorder. Clin Pract Epidemiol Ment Health. 2008;4(1):1-6. [pmid: 18221549].
128 Lynch TR, Cheavens JS, Cukrowicz KC, et al. Treatment of older adults with co-morbid personality disorder and depression: A dialectical behavior therapy approach. Int J Geriatr Psychiatry. 2007;22(2):131-43. [pmid: 17096462].
129 Zourkova A. Effect of mirtazapine and paroxetine on residual symptoms of depressive disorders and their effect on P450 CYP 2D6 activity. Homeost Health Dis. 2001;41(6):242-9.
130 Landén M, Eriksson E, Agren H, et al. Effect of buspirone on sexual dysfunction in depressed patients treated with selective serotonin reuptake inhibitors. J Clin Psychopharmacol. 1999;19(3):268-71. [pmid: 10350034].
131 Nelson JC, Mankoski R, Baker RA, et al. Effects of aripiprazole adjunctive to standard antidepressant treatment on the core symptoms of depression: A post-hoc, pooled analysis of two large, placebo-controlled studies. J Affect Disord. 2010;120(1–3):133-40. [pmid: 19656577].
132 Reimherr F, Amsterdam J, Dunner D, et al. Genetic polymorphisms in the treatment of depression: speculations from an augmentation study using atomoxetine. Psychiatry Res. 2010;175(1–2):67-73. [pmid: 19969374].
133 Martire LM, Schulz R, Reynolds CF III, et al. Treatment of late-life depression alleviates caregiver burden. J Am Geriatr Soc. 2010;58(1):23-9. [pmid: 19943833].
134 Bauer M, El-Khalili N, Datto C, et al. A pooled analysis of two randomised, placebo-controlled studies of extended release quetiapine fumarate adjunctive to antidepressant therapy in patients with major depressive disorder. [Review]. J Affect Disord. 2010;127(1–3):19-30. [pmid: 20884063].
135 Greenlee A, Karp JF, Dew MA, et al. Anxiety impairs depression remission in partial responders during extended treatment in late-life. Depress Anxiety. 2010;27(5):451-6. [pmid: 20186975].
136 Nelson JC, Thase ME, Trivedi MH, et al. Safety and tolerability of adjunctive aripiprazole in major depressive disorder: A pooled post hoc analysis (studies CN138-139 and CN138-163). Prim Care Comp J Clin Psychiatry. 2009;11(6):344-52.
137 Reynolds CFI, Dew MA, Martire LM, et al. Treating depression to remission in older adults: A controlled evaluation of combined escitalopram with interpersonal psychotherapy versus escitalopram with depression care management. Int J Geriatr Psychiatry. 2010;25(11):1134-41. [pmid: 20957693].
138 Heiligenstein JH, Hoog SL, Wagner KD, et al. Fluoxetine 40–60 mg versus fluoxetine 20 mg in the treatment of children and adolescents with a less-than-complete response to nine-week treatment with fluoxetine 10–20 mg: A pilot study. Journal of Child & Adolescent Psychopharmacology. 2006;16(1–2):207-17. [pmid: 16553541].
139 Vitiello B, Brent DA, Greenhill LL, et al. Depressive Symptoms and clinical status during the treatment of adolescent suicide attempters (TASA) study. J Am Acad Child Adolesc Psychiatry. 2009;48(10):997-1004. [pmid: 20854770].
140 Brent DA, Emslie GJ, Clarke GN, et al. Predictors of spontaneous and systematically assessed suicidal adverse events in the treatment of SSRI-resistant depression in adolescents (TORDIA) study. Am J Psychiatry. 2009;166(4):418-26. [pmid: 19223438].
141 Asarnow JR, Emslie G, Clarke G, et al. Treatment of selective serotonin reuptake inhibitor-resistant depression in adolescents: Predictors and moderators of treatment response. J Am Acad Child Adolesc Psychiatry. 2009;48(3):330-9. [pmid: 19182688].
142 Brent DA, Greenhill LL, Compton S, et al. The Treatment of Adolescent Suicide Attempters Study (TASA): Predictors of suicidal events in an open treatment trial. J Am Acad Child Adolesc Psychiatry. 2009;48(10):987-96. [pmid: 19730274].
143 Stanley B, Brown G, Brent DA, et al. Cognitive-Behavioral Therapy for Suicide Prevention (CBT-SP): Treatment model, feasibility, and acceptability. J Am Acad Child Adolesc Psychiatry. 2009;48(10):1005-13. [pmid: 19730273].
144 Brent D, Melhem N, Ferrell R, et al. Association of FKBP5 polymorphisms with suicidal events in the Treatment of Resistant Depression in Adolescents (TORDIA) study. Am J Psychiatry. 2010;167(2):190-7. [pmid: 20008943].
145 Goldstein BI, Shamseddeen W, Spirito A, et al. Substance use and the treatment of resistant depression in adolescents. J Am Acad Child Adolesc Psychiatry. 2009;48(12):1182-92. [pmid: 19858762].
146 Emslie GJ, Mayes T, Porta G, et al. Treatment of Resistant Depression in Adolescents (TORDIA): Week 24 outcomes. Am J Psychiatry. 2010;167(7):782-91. [pmid: 20478877].
147 Sakolsky DJ, Perel JM, Emslie GJ, et al. Antidepressant exposure as a predictor of clinical outcomes in the Treatment of Resistant Depression in Adolescents (TORDIA) study. J Clin Psychopharmacol. 2011;31(1):92-7. [pmid: 21192150].
148 Shamseddeen W, Asarnow JR, Clarke G, et al. Impact of physical and sexual abuse on treatment response in the treatment of resistant depression in adolescent study (TORDIA). J Am Acad Child Adolesc Psychiatry. 2011;50(3):293-301. [pmid: 21334569].
149 Lynch FL, Dickerson JF, Clarke G, et al. Incremental cost-effectiveness of combined therapy vs. medication only for youth with selective serotonin reuptake inhibitor-resistant depression: Treatment of SSRI-resistant depression in adolescents trial findings. Arch Gen Psychiatry. 2011;68(3):253-62.
150 Rapaport MH, Gharabawi GM, Canuso CM, et al. Effects of risperidone augmentation in patients with treatment-resistant depression: Results of open-label treatment followed by double-blind continuation. Neuropsychopharmacol. 2006;31(11):2505-13.
151 Jaehne ME. Health care guideline: Major depression in adults in primary care 12th edition. Institute for Clinical Systems Improvement.
152 Depression clinical practice guidelines. National Guidline Clearinghouse. 2004:1-20.
153 Steinman LE, Frederick JT, Prohaska T, et al. Recommendations for treating depression in community-based older adults. Am J Prev Med. 2007;33(3):175-81. [pmid: 17826575].
154 Bauer M, Bschor T, Pfennig A, et al. World Federation of Societies of Biological Psychiatry (WFSBP) guidelines for biological treatment of unipolar depressive disorders in primary care. World J Biol Psychiatry. 2007;8(2):67-104. [pmid: 17455102].
155 Davidson KW, Kupfer DJ, Bigger JT, et al. Assessment and treatment of depression in patients with cardiovascular disease: National Heart, Lung, and Blood Institute Working Group Report. Psychosom Med. 2006;68(5):645-50. [pmid: 17012516].
156 Ellis P. Royal Australian and New Zealand College of Psychiatrists Clinical Practice Guidelines Team for Depression. Australian and New Zealand clinical practice guidelines for the treatment of depression. Aust NZ J Psychiatry. 2004;38(6):389-407. [pmid: 15209830].
157 Malhi GS, Adams D, Porter R, et al. Clinical practice recommendations for depression. Acta Psychiatr Scand. 2009;119(Suppl 439):8-26.
158 Ravindran AV. If a patient does not respond to a full dose of fluvoxamine for at least 12 weeks, what alternatives should be considered?. J Psychiatry Neurosci. 1998;23(2):136. [pmid: 9549254].
159 Lam RW, Kennedy SH, Grigoriadis S, et al. Canadian Network for Mood and Anxiety Treatments (CANMAT) Clinical guidelines for the management of major depressive disorder in adults. III. Pharmacotherapy. J Affect Disord. 2009;117(Suppl 1):S26-S43. [pmid: 19674794].
160 Conn DK, Gibson M, Feldman S, et al. National guidelines for seniors’ mental health: The assessment and treatment of mental health issues in long-term care homes (focus on mood and behaviour symptoms). Can J Geriatr. 2006;9(Suppl 2):S59-S64.
161 Mahendran R, Yap HL. Clinical practice guidelines for depression. Singapore Med J. 2005;46(11):610-5. 2005. [pmid: 16228091].
162 National Institute for Health and Clinical Excellence. Computerised cognitive behaviour therapy for depression and anxiety. 2006;97. 2006.
163 Nutt DJ, Davidson JR, Gelenberg AJ, et al. International consensus statement on major depressive disorder. J Clin Psychiatry. 2010;71(Suppl E1):e08. [pmid: 20371035].
164 National Institute for Health and Clinical Excellence. Depression in adults (update): Depression: The treatment and management of depression in adults, Final Version of guideline 90. London. NICE. 2009.
165 Harter M, Klesse C, Bermejo I, et al. Unipolar depression: Diagnostic and therapeutic recommendations from the current S3/National Clinical Practice Guideline. Deutsches Arzteblatt International. 2010;107(40):700-8. [pmid: 21031129].
166 Gelenberg A, Freeman M, Markowitz J, et al. Practice guideline for the treatment of patients with major depressive disorder. American Psychiatric Association. 2010.
167 Karasu B, Gelenberg A, Merriam A, et al. Practice guideline for treatment of patients with depression disorder second edition. APA Practice Guidlines. 2009:1-78.
168 Depression: Management of depression in primary and secondary care. 2004;23.
169 National Institute for Health and Clinical Excellence. Depression: The treatment and management of depression in adults. 2009:1-585. 2009.
170 Pilling S, Anderson I, Goldberg D, et al. Guidelines: Depression in adults, including those with a chronic physical health problem: Summary of NICE guidance. Br Med J. 2009;339(7728):1025-7.
171 National Institute for Health and Clinical Excellence. Depression in adults with a chronic physical health problem: Treatment and management, NICE clinical guideline 91. London. NICE. 2009.
172 Zuckerbrot R, Cheung MH, Jensen P, et al. Guidelines for adolescent Depression in primary care (GLAD-PC) I, Identification, assessment, and initial management. Pediatr. 2009;120(5):1299-312.
173 Hughes CW, Emslie GJ, Crismon ML, et al. Texas Children’s Medication Algorithm Project: update from Texas Consensus Conference Panel on medication treatment of childhood major depressive disorder. J Am Acad Child Adolesc Psychiatry. 2007;46(6):667-86. [pmid: 17513980].
174 Cheung AH, Zuckerbrot RA, Jensen PS, et al. Guidelines for adolescent depression in primary care (GLAD-PC): II. Treatment and ongoing management. J Am Acad Pediatr. 2007;120(5):e1313-e1326.
175 Gallagher R. Evidence-based psychotherapies for depressed adolescents: A review and clinical guidelines. Prim Psychiatry. 2005;12(9):33-9.
176 National Institute for Clinical Excellence. Depression in Children and Young People: Identification and management in primary, community and secondary care. 2005:1-233. 2005.
177 Anderson IM, Ferrier IN, Baldwin RC, et al. Evidence-based guidelines for treating depressive disorders with antidepressants: A revision of the 2000 British Association for Psychopharmacology guidelines. J Psychopharmacol (Oxf). 2008;22(4):343-96. [pmid: 18413657].
178 Corya SA, Williamson D, Sanger TM, et al. A randomized, double-blind comparison of olanzapine/fluoxetine combination, olanzapine, fluoxetine, and venlafaxine in treatment-resistant depression. Depress Anxiety. 2006;23(6):364-72. [pmid: 16710853].
179 Shelton RC, Williamson DJ, Corya SA, et al. Olanzapine/fluoxetine combination for treatment-resistant depression: A controlled study of SSRI and nortriptyline resistance. J Clin Psychiatry. 2005;66(10):1289-97. [pmid: 16259543].
180 Mazeh D, Shahal B, Aviv A, et al. A randomized, single-blind, comparison of venlafaxine with paroxetine in elderly patients suffering from resistant depression. Int Clin Psychopharmacol. 2007;22(6):371-5. [pmid: 17917556].
181 McGrath PJ, Stewart JW, Fava M, et al. Tranylcypromine versus venlafaxine plus mirtazapine following three failed antidepressant medication trials for depression: A STAR*D report. Am J Psychiatry. 2006;163(9):1531-41. [pmid: 16946177].
182 Fava M, Rush AJ, Wisniewski SR, et al. A comparison of mirtazapine and nortriptyline following two consecutive failed medication treatments for depressed outpatients: A STAR*D report. Am J Psychiatry. 2006;163(7):1161-72. [pmid: 16816220].
183 Nierenberg AA, Fava M, Trivedi MH, et al. A comparison of lithium and T(3) augmentation following two failed medication treatments for depression: A STAR*D report. Am J Psychiatry. 2006;163(9):1519-30. [pmid: 16946176].
184 Perlis RH, Moorjani P, Fagerness J, et al. Pharmacogenetic analysis of genes implicated in rodent models of antidepressant response: Association of TREK1 and treatment resistance in the STAR(*)D study. Neuropsychopharmacol. 2008;33(12):2810-9. [pmid: 18288090].
185 Yates WR, Mitchell J, Rush AJ, et al. Clinical features of depressed outpatients with and without co-occurring general medical conditions in STAR*D. Gen Hosp Psychiatry. 2004;26(6):421-9. [pmid: 15567207].
186 Lesser IM, Leuchter AF, Trivedi MH, et al. Characteristics of insured and noninsured outpatients with depression in STAR*D. Psychiatr Serv. 2005;56(8):995-1004. [pmid: 16088018].
187 Perlis RH, Patrick A, Smoller JW, et al. When is pharmacogenetic testing for antidepressant response ready for the clinic? A cost-effectiveness analysis based on data from the STAR*D study. Neuropsychopharmacol. 2009;34(10):2227-36. [pmid: 19494805].
188 El-Khalili N, Joyce M, Atkinson S, et al. Extended-release quetiapine fumarate (quetiapine XR) as adjunctive therapy in major depressive disorder (MDD) in patients with an inadequate response to ongoing antidepressant treatment: A multicentre, randomized, double-blind, placebo-controlled study. Int J Neuropsychopharmacol. 2010;13(7):917-32. [pmid: 20175941].
189 New Zealand Guidelines Group. Identification of common mental disorders and management of depression in primary care. 2008:1-190. 2008.
190 Ravindran AV, Lam RW, Filteau MJ, et al. Canadian Network for Mood and Anxiety Treatments (CANMAT) Clinical guidelines for the management of major depressive disorder in adults. V. Complementary and alternative medicine treatments. J Affect Disord. 2009;117:S54-64. ISI:000271042300007. [pmid: 19666194].
191 Kennedy SH, Lam RW, Parikh SV, et al. Canadian Network for Mood and Anxiety Treatments (CANMAT) Clinical guidelines for the management of major depressive disorder in adults Introduction. J Affect Disord. 2009;117:S1-2. ISI:000271042300001. [pmid: 19682750].
192 Anderson IM, Haddad PM. CANMAT Guidelines for depression: Clear and user-friendly. J Affect Disord. 2009;117:S3-4. ISI:000271042300002. [pmid: 19646763].
193 Horsley L. ACP guideline on second-generation antidepressants for depression treatment. Am Fam Physician. 2009;80(3):291-4.
194 Dudley M, Hadzi-Pavlovic D, Andrews D, et al. New-generation antidepressants, suicide and depressed adolescents: How should clinicians respond to changing evidence?. Aust NZ J Psychiatry. 2008;42(6):456-66. [pmid: 18465372].
195 Papakostas GI, Petersen TJ, Green C, et al. A description of next-step switching versus augmentation practices for outpatients with treatment-resistant major depressive disorder enrolled in an academic specialty clinic. Ann Clin Psychiatry. 2005;17(3):161-5. [pmid: 16433058].
196 Blier PSST. Potential mechanisms of action of atypical antipsychotic medications in treatment-resistant depression and anxiety. J Clin Psychiatry. 2005;66(Suppl 8):30-40. [pmid: 16336034].
197 McIntyre RS, Muzina DJ, Adams A, et al. Quetiapine XR efficacy and tolerability as monotherapy and as adjunctive treatment to conventional antidepressants in the acute and maintenance treatment of major depressive disorder: A review of registration trials. Expert Opin Pharmacother. 2009;10(18):3061-75. [pmid: 19954275].
198 Bauer M, El Khalili N, Datto C, et al. A pooled analysis of two randomised, placebo-controlled studies of extended release quetiapine fumarate adjunctive to antidepressant therapy in patients with major depressive disorder. J Affect Disord. 2010;127(1–3):19-30. [pmid: 20884063].
199 Nelson JC, Papakostas GI. Atypical antipsychotic augmentation in major depressive disorder: A meta-analysis of placebo-controlled randomized trials. Am J Psychiatry. 2009;166(9):980-91. [pmid: 19687129].
200 Bauer M, Pretorius HW, Constant EL, et al. Extended-release quetiapine as adjunct to an antidepressant in patients with major depressive disorder: Results of a randomized, placebo-controlled, double-blind study. J Clin Psychiatry. 2009;70(4):540-9. [pmid: 19358791].
201 Fredman SJ, Fava M, Kienke AS, et al. Partial response, nonresponse, and relapse with selective serotonin reuptake inhibitors in major depression: A survey of current “next-step” practices. J Clin Psychiatry. 2000;61(6):403-8. [pmid: 10901336].
202 Baldessarini RJ, Tondo L, Hennen J. Treating the suicidal patient with bipolar disorder. Reducing suicide risk with lithium. Ann N Y Acad Sci. 2001;932:24-38. [pmid: 11411189].
203 Lyness JM, Heo M, Datto CJ, et al. Outcomes of minor and subsyndromal depression among elderly patients in primary care settings. Ann Intern Med. 2006;144(7):496-504. [pmid: 16585663].
204 Piaggio G, Elbourne DR, Altman DG, et al. Reporting of noninferiority and equivalence randomized trials: An extension of the CONSORT statement. JAMA. 2006;295(10):1152-60. [pmid: 16522836].
205 Kennard BD, Clarke GN, Weersing VR, et al. Effective components of TORDIA cognitive-behavioral therapy for adolescent depression: Preliminary findings. J Consult Clin Psychol. 2009;77(6):1033-41. [pmid: 19968380].
206 Scott J, Paykel E, Morriss R, et al. Cognitive-behavioural therapy for severe and recurrent bipolar disorders: Randomised controlled trial. BR J PSYCHIATR. 2006;188:313-20. [pmid: 16582056].
207 Ioannidis JPA, Evans SJW, Gotzsche PC, et al. Better reporting of harms in randomized trials: An extension of the CONSORT statement. Ann Intern Med. 2004;141(10):781-8. ISI:000225206900005. [pmid: 15545678].
208 Adli M, Bauer M, Rush AJ. Algorithms and collaborative-care systems for depression: are they effective and why? A systematic review. Biol Psychiatry. 2006;59(11):1029-38. [pmid: 16769294].
209 Turner EH, Matthews AM, Linardatos E, et al. Selective publication of antidepressant trials and its influence on apparent efficacy. N Engl J Med. 2008;358(3):252-60. [pmid: 18199864].