# Peer Reviewers

Doug Campos-Outcalt, M.D., M.P.A.

Associate Head, Family and Community Medicine

Assistant Dean, Outreach and Multicultural Affairs

University of Arizona College of Medicine

Phoenix, AZ

Bradley N. Gaynes, M.D., M.P.H.

Associate Professor of Psychiatry

University of North Carolina School of Medicine

Chapel Hill, NC

Nicholas Meader, B.Sc., Ph.D.

National Collaborating Centre for Mental Health

Royal College of Psychiatrists’ Research Unit

London, UK

Wendy Weber, N.D., Ph.D., M.P.H.

Naturopath and Senior Scientist

National Center for Complimentary and Alternative Medicine

Bethesda, MD