# Key Informants

Bradley N. Gaynes, M.D., M.P.H.

Associate Professor of Psychiatry

University of North Carolina School of Medicine

Chapel Hill, NC

Anthony Levitt, Ph.D., M.B.B.S., FRCPC

Sunnybrook Health Sciences Centre

Toronto, ON Canada

Madhukar H. Trivedi, M.D.

Department of Psychiatry

University of Texas Southwestern Medical Center at Dallas

Dallas, TX

Sandeep Wadhwa, M.D.

State Medicaid Director

Colorado Department of Health Care Policy and Financing

Denver, CO

John W. Williams Jr., M.D., M.H.S.

Professor of Medicine & Psychiatry

Scientific Editor, NC Medical Journal

Duke University and Durham VA Medical Center

Durham, NC

Judy Zerzan, M.D., M.PH.

Colorado Medicaid Medical Director

Colorado Department of Health Care Policy and Financing

Denver, CO