# Introduction

## Background

Depression is a complex mental illness that is associated with disability and reduced quality of life for the person with depression, as well as substantial societal burden. Pharmacological agents are one of several treatment modalities used for depression and one of the most frequently utilized classes of antidepressant medications are the selective serotonin reuptake inhibitors (SSRIs). The rate of treatment response following first-line treatment with SSRIs is moderate, however, varying from 40 to 60 percent; remission rates vary from 30 to 45 percent.1 Up to one third of persons taking antidepressant medications will develop recurrent symptoms of depression while on therapy.2 The definition of an adequate response to SSRI medications is not consistently operationalized, but it is generally accepted that a 50 percent decrease in symptom severity constitutes a response.3 Remission from depression is defined as being free or nearly free of symptoms for the current episode. This review evaluates treatment options for patients who fail to improve fully, who only improve partially, or who have no response to an SSRI medication.

### Epidemiology of Depression in Adults and Adolescents

Major depressive disorder (MDD) is the occurrence of one or more major depressive episodes (MDE). An MDE is defined as a period of at least 2 weeks that is characterized either by depressed mood and/or markedly diminished interest or pleasure in all, or almost all, activities in addition to at least four other symptoms.4 Dysthymic disorder is characterized by a chronically depressed mood and at least two other depressive symptoms that occur most of the day, more days than not, for at least 2 years. The Diagnostic and Statistical Manual, 4^th^ edition, Text Revision (DSM-IV-TR) includes specifiers that can be used to further describe the characteristics of MDE or dysthymic disorder, such as whether an episode of depression includes psychosis or occurs in the postpartum period. The operational definition for subsyndromal depression was defined by Judd5 for individuals who do not meet criteria for a diagnosis of minor depression, major depression, and/or dysthymia. The definition specifies the presence of two or more simultaneous symptoms of depression associated with evidence of social dysfunction for most or all of the time for at least 2 weeks. Depression is common in adults and adolescents and is characterized by chronic, recurrent episodes that have significant impact on disability and mortality.

There is increasing acceptance that symptoms that do not meet the full criteria for MDD, but that are persistent, may cause distress and disability in persons with these symptoms. The DSM-IV-TR describes two related subthreshold categories of dysthymia and minor depression. dysthymia is characterized by an overwhelming yet chronic state of depression, exhibited by a depressed mood for most of the days, for more days than not, for at least 2 years. In children and adolescents, mood can be irritable and duration must be at least 1 year. The person who suffers from this disorder must not have gone for more than 2 months without experiencing two or more of the following symptoms: poor appetite or overeating, insomnia or hypersomnia, low energy or fatigue, low self-esteem, poor concentration or difficulty making decisions, or feelings of hopelessness. In addition, no MDD episode has been present during the first 2 years (or 1 year in children and adolescents) and there has never been a manic episode, a mixed episode, or a hypomanic episode, and criteria have never been met for cyclothymic disorder. Further, the symptoms cannot be due to the direct physiological effects of the use or abuse of a substance such as alcohol, drugs or medication, or a general medical condition. The symptoms must also cause significant distress or impairment in social, occupational, educational, or other important areas of functioning.

#### Prevalence of Depressive Disorders

Kessler reported estimates of 16 percent lifetime prevalence and 7 percent annual prevalence of depression in the United States for adults.6 These are slightly higher than European prevalence rates of 13 percent lifetime and 4 percent annual.7 European estimates of the prevalence of dysthymic disorder in adults based on DSM-IV-TR criteria, are 4 percent lifetime and 1 percent annual.7 Despite increases in provision of treatment for people with depression,8 a reduction in prevalence has not yet been discernable in those countries where before–after comparisons have been feasible.9,10 This may be in part because a substantial number of people with depression remain untreated or receive inadequate treatment.11 The Netherlands Mental Health Survey and Incidence Study assessed episode duration in community residents with new-onset episodes. Although 50 percent of people recovered within 3 months, the recovery rate flattened over time, and the authors estimated that approximately 20 percent would have episodes lasting longer than 24 months.12

The prevalence of MDD in adolescents, 12 to 16 years of age, varies from 4 to 8 percent. There is an increased risk of depression following puberty, especially in girls relative to boys (2:1 ratio).13,14 Prevalence of MDD among adolescents has been reported to be as high as 20 percent.14

Although the literature is limited, the few studies that evaluate dysthymia in adolescents report disease prevalence varying from 1.6 percent to 8.0 percent.15 Adolescents with depression have high rates of comorbid psychiatric conditions (reports vary from 40 to 90 percent), including anxiety, attention deficit hyperactivity disorder and substance abuse problems.13

#### The Disease Burden Associated With MDD, Dysthymia

MDD is a leading cause of disability across the world.16,17 Specifically, depression is the second leading medical cause of long-term disability and the fourth leading cause of the global burden of disease, predicted to become the second highest cause of disability by 2020. The ongoing transition to a knowledge-based economy is expected to further magnify the impact of MDD on occupational functioning.18 Depressive disorders negatively affect quality of life (QOL); 63 percent of respondents with MDD had severe impairment in QOL, while 85 percent of those with double depression (MDD and dysthymic disorder) and 56 percent of those with dysthymic disorder had QOL impairment in the severe range.19 The economic burden of depressive disorders is estimated to be $83.1 billion per year.20

The National Comorbidity Survey Replication study in the United States found that role impairment in people with MDD was lowest in the occupational domain and highest in the social domain.6 About 60 percent of respondents with an MDE in the past year reported severe or very severe role impairment. Parental depression has a negative effect on the development of their children and on family dynamics,21,22 and intergenerational effects may amplify the impact of depression on population health.23

Depression also has a negative impact on occupational functioning. In one study, depressed workers had significantly greater performance deficits than control workers who had rheumatoid arthritis, with regard to performing mental tasks, time management, output tasks, and physical tasks.24 When depressed workers were compared to workers with rheumatoid arthritis, the depressed employees were almost five times as likely to become unemployed than those with arthritis.25 Depressed employees are also more likely to become unemployed or miss time at work than physically ill employees.26

Depression exerts a negative impact on physical health; it reduces adherence to medical treatment,27 reduces participation in preventive activities,28 and increases the likelihood of risk factors such as obesity,29 smoking,30 and a sedentary lifestyle.31 MDD may be associated with immune dysfunction,32–36 cardiovascular disease,37–39 endocrine and neurological diseases, and a general increase in chronic disease incidence.40 Mortality rates are high; approximately four percent of people with a mood disorder die by their own hand and about two thirds of suicides are preceded by depression.41

In adolescents, untreated depression results in significant disability in school performance, interpersonal relationships, risk of suicidal behavior and completion of suicide, risk of early pregnancy, occupational adjustment, and impaired social and family functioning.14,42

### Clinical Assessment, Management, and Response

Depression is frequently underdiagnosed in primary practice in both adults and adolescents. The World Health Organization (WHO) Psychological Problems in General Health Care study reported that primary care physicians diagnosed only 42 percent of adult patients with major depression. Possible benefits of screening and diagnostic tools to improve detection of depression in primary practice have been examined. Several tools are available for monitoring of depressive symptoms and there were no major differences between these instruments in a comparative study.43 The Patient Health Questionnaire-9 item (PHQ-9)44 or the Quick Inventory of Depressive Symptoms–Self Report (QIDS-SR) appear to be increasing in use, perhaps because of their brevity and strong alignment with DSM-IV-TR. The spectrum of depressive morbidity encountered by primary care physicians is broad. There is also recent evidence suggesting that diagnosis of depression in primary care may not be the major barrier to successful treatment; rather, it may be that patients are not receptive to suggested treatment for a condition that was not the reason for the visit to the physician. In primary care, the range of interventions offered may extend from close monitoring of mild episodes without immediate treatment (watchful waiting), through guided self-management, brief psychological or behavioral interventions, pharmacological management, and, if needed, referral to more specialized services or hospital admission.45

#### Phases of Treatment of Major Depressive Episodes

Based on the work of Kupfer,46 treatment for MDD is commonly div6ided into three phases: acute, continuation, and maintenance. Acute treatment is aimed at the elimination of symptoms of depression and the restoration of psychosocial functioning. Continuation is a prolongation of treatment from four to nine months, such that the episode of depression is considered completely resolved. For the continuation phase, the treatment aims to return patients to baseline function and quality of life, and to prevent recurrence of symptoms. For the maintenance phase when symptoms have been resolved, the treatment goal is to prevent recurrence of new episodes of MDD. In this context, relapse is understood to occur during the continuation phase, but recurrence during the maintenance phase.

The target goal for acute treatment should be remission, which is defined as a resolution of depressive symptoms (score within a normal range of the symptom scale). Response to treatment, usually defined as at least a 50 percent reduction in symptom levels,3 may not be sufficient as a target outcome because residual depressive symptoms are risk factors for relapse and negative predictors of long-term outcome.47

#### Duration of First-Line Treatment Prior To Establishing Adequate Response

Embedded within the decision that a patient has not had an adequate response to treatment, is the issue of defining an adequate duration for that treatment. Antidepressant effect may begin within 1 to 2 weeks of initiation48–50 and early improvement is a prognostic factor for remission.51 In STAR*D, 93 percent of patients first achieved response after 8 or more weeks, while 41 percent of patients who ultimately remitted first attained remission between 4 and 8 weeks after initiating treatment.52

Some guidelines suggest that patients with at least minimal improvement (≥20 percent improvement in scores on a depression rating scale after four to six weeks) should continue with the antidepressant for another two to four weeks before considering additional strategies.53,54 The American College of Physicians (ACP) recommends that clinicians modify treatment if the patient does not have an adequate response to pharmacotherapy within 6 to 8 weeks of the initiation of therapy for MDD.55

#### Outcomes of Importance

There are a number of outcomes that are used within primary care and psychiatry to assess and monitor response to treatment. These scales include those that are self-report or completed by the clinician. Outcome assessment is usually conducted using validated interviewer-rated scales such as the Hamilton Depression Rating Scale (HAMD)56 or the Montgomery Åsberg Depression Rating Scale (MADRS).57 Although limitations have been recognized to the use of the HAMD in outpatient populations, it remains widely used.58 Response is typically defined as >50 percent reduction in scores on these scales, while remission is defined as a score within the normal range.3,58,59 However, despite a number of well-validated instruments to assess depression symptoms, there is some suggestion that physicians in primary care may not routinely use these; based on qualititative analyses, factors that influenced the use of use these standardized assessments were time constraints, clinician familiarity with the instrument, and lack of clinical evidence.60 There is also some evidence that primary care physicians have a sensitivity varying from 48 to 50 percent when ruling in depression using unassisted methods (without the use of severity scales, diagnostic instruments, educational programs, or other organizational approaches).61

#### Defining Inadequate Response and Estimates Within the Population

Subjects who are classified as having failed treatment or as having an “inadequate response” are eligible for this review. Treatment failure subjects would ideally be defined as those subjects who are currently on SSRI treatment for the index episode at the time of entry into the study. At that point these subjects have been judged to have had an “inadequate response” at the time of entry into the study or just prior to randomization. An “inadequate response” is typically established using a standardized instrument, where the scores relative to baseline reflect an improvement of less than 50 percent.3,62 The term “inadequate response” is therefore synonymous with terms such as “nonresponders,” “failure to respond,” and “treatment failure.” These terms primarily reflect the perspective of the clinician or researcher. Partial response refers to a change in baseline score from 25 to 49 percent. Nonresponse is defined as less than 25 percent change in baseline score.

The rate of treatment response following treatment with SSRIs is moderate, varying from 40 to 60 percent.1 Up to two thirds of adult patients will not achieve remission with SSRI treatment.52 Up to one third of adults on drug treatment will develop recurrent symptoms of depression while on therapy.2 Moreover, there is limited evidence identifying reliable predictors (demographic, clinical, or genetic characteristics) of individual response.63

Within their systematic review evaluating the efficacy of treatment for adolescents, Williams, et al.,64 showed that the rates of children failing to respond to an initial trial of SSRIs varied from 31 to 64 percent in eligible studies. Similarly, up to 60 percent of adolescents placed on combined treatment for depression (including pharmacological and behavioral therapies) respond positively to these interventions.42

A portion of patients who have experienced an inadequate response from a clinical perspective may also go on to be defined as treatment resistant if they also fail to respond to subsequent treatment strategies. Treatment resistance is variably defined but usually refers to patients who have failed at least two trials of medication that have been of adequate dose and duration.65 Some definitions suggest that the failures should be to medications of different classes, but this is not universally accepted.

Monitoring adherence to antidepressants is sometimes difficult, but nonadherence may account for up to 20 percent of patients classified as having treatment resistant depression.66 Similarly, there is the potential for pseudoresistance or nonresponse to inadequate treatment. All this would suggest the difficulty of defining and capturing subjects who have had treatment failure and related subgroups. It may also reflect heterogeneity across studies evaluating the efficacy of SSRIs within this patient population.

#### Treatment After an Inadequate Response

Treatment strategies following an inadequate response to an SSRI vary and can include monotherapy or combined therapy. Monotherapy options include: (1) an optimization strategy (increasing the dose or extending the duration of the SSRI), (2) switching to another SSRI, (3) switching to another class of antidepressants, or (4) switching to a nonpharmacological intervention. Combination or add-on therapy options include: (1) combining the SSRI with an augmenting agent, (2) combining antidepressants, or, (3) combining the SSRI with a nonpharmacological therapy.67 It is also an option to switch to a new antidepressant and simultaneously combine that antidepressant with a second pharmacological or nonpharmacological treatment. This is sometimes referred to as an acceleration strategy.

#### Evaluation of Current Clinical Practice Guidelines for Inadequate Response

Recognizing that clinicians have a number of treatment options when addressing patients with an inadequate response, we thought it would be important to identify and evaluate current recommendations within current guidelines regarding the optimal approach to treatment. Our goal was to critically appraise these current guidelines and compare any differences in recommendations.

## Scope and Purpose of this Review

A variety of treatment strategies aimed at helping individuals who have inadequate responses to SSRIs have been studied in patients with depression. The primary goal of this comparative effectiveness review (CER) is to examine the evidence guiding clinical treatment decisions and ultimately to aid clinicians in their care of patients when SSRI therapy for an index episode does not result in an adequate treatment response. The Key Questions are as follows:

Key Question 1 Among adults and adolescents with major depressive disorder (MDD), dysthymia, or subsyndromal depression who are started on an SSRI and who are compliant with treatment but fail to improve either fully, partially, or have no response, what is the benefit (efficacy or effectiveness) of monotherapy and combined therapy?
Key Question 1a How does the efficacy/effectiveness vary among the different monotherapies and combined therapies?
Key Question 2 What are the harms of each of the monotherapies or combined therapies among these adults and adolescents? How do the harms compare across different interventions?
Key Question 3 How do these therapies compare in different populations (e.g., different depressive diagnoses, disease severity, ages, gender, racial and socioeconomic group, and medical or psychiatric comorbidities)? These subgroups will be considered with respect to the different interventions.
Key Question 4 What is the range of recommended clinical actions following the failure of one adequate course of SSRI based on clinical practice guidelines published between 2004 and April 2011?