# Discussion

## Overview

Pharmacological agents are one of several treatment modalities used to treat major depressive disorder (MDD). One of the most frequently utilized classes of antidepressant medications is the selective serotonin reuptake inhibitors (SSRIs). However, the rates of treatment response following first-line treatment with SSRIs is moderate, varying from 40 to 60 percent; remission rates may vary from 30 to 45 percent.1 This CER has summarized the evidence for management of patients subsequent to a trial of an SSRI that did not result in an adequate response.

### KQ1 Among adults and adolescents with Major Depressive Disorder, Dysthymia, and Subsyndromal Depression, who are started on an SSRI and who are compliant with treatment but fail to improve either fully, partially, or have no response, what is the benefit (efficacy or effectiveness) of monotherapy and combined therapy?

### KQ1a How does the efficacy/effectiveness vary between the different monotherapies and combined therapies?

#### Adults

This CER has identified and shown that the evidence comparing varying treatment strategies following failed response to an SSRI are of low quality or are insufficient overall. The evidence for single treatments (monotherapies) compared either with the same or lower doses, switching to different agents, or augmentation or combination therapies following inadequate response to SSRIs is limited with respect to the number of studies, the agents evaluated, and their methodological quality. As such, many relatively straightforward clinical questions remain to be addressed. When patients are being treated with an antidepressant and are not improving, the first step is often to ‘optimize’ the treatment, most often defined as an adequate dose for an adequate duration of time; there is, however, no consensus on exactly how long a patient should be treated with a medication before there is a decision made that the response has been inadequate.

The issue of determining what defines an inadequate trial of an SSRI is therefore not straightforward; while most studies used adequate doses of medications (as defined when the medication receives an indication from a regulatory authority) the duration of treatment with the SSRI before a judgment is made regarding the inadequacy of the response, was highly variable across the trials that were reviewed. The duration of treatment with an SSRI prior to the determination of an inadequate response ranged from a mean of approximately 4 to 12 weeks. Although adequate doses may be those defined in product monographs, there has been uncertainty regarding the maximal dose to which many common antidepressants should be prescribed. Despite this, a survey conducted a decade ago suggested that the preferred intervention of clinicians following inadequate response to an SSRI was a dose increase. Only three studies have examined whether an increase in dose in this population is associated with a comparable probability of response or remission relative to maintaining standard doses (either as a continuation of the original SSRI or as switch to a new antidepressant); direct comparison of dose changes relative to selecting another strategy, such as a medication switch or an add-on therapy, was not evaluated in the eligible studies within this review.

Once a decision is made to move beyond optimizing the SSRI regimen, clinicians have several options available, including switching to a new medication (either of the same antidepressant class or a different class), adding a second antidepressant, or adding another agent that itself might not be recognized as an antidepressant in monotherapy. In recent years, the line between ‘augmentation’ agents and ‘antidepressant’ medications has been questioned, leading some investigators to suggest that the standard terminologies of ‘combination’ therapy (to refer to multiple antidepressant treatments, either pharmacological or other, being used at the same time) and ‘augmentation’ therapy (to refer to an antidepressant used in conjunction with another nonantidepressant therapy) should be collapsed and called ‘add-on’ therapy. Regardless of preferences for nomenclature, this review has highlighted that there is an extremely limited evidence base to support clinical decisionmaking about any of these strategies or which agents to select. The variation amongst CPGs reflects this uncertainty.

A common treatment approach following inadequate response to first treatment is to switch medications. Despite the large cohort of patients in the STAR*D trial, there remains insufficient or low quality evidence to determine whether a patient who elects to have a medication switch following an inadequate response to one SSRI can be switched to another SSRI with equal likelihood of response or remission compared to a switch to a medication from another class. The STAR*D trial suggested that this might be the case, at least when comparing sertraline, venlafaxine, and bupropion, but given the frequency with which this question arises in clinical practice, a more substantive evidentiary base on which to make this decision appears warranted.

Another common clinical issue following inadequate treatment response is whether to add a medication, either another antidepressant or a nonantidepressant agent, traditionally called an augmenting agent. Adding a second antidepressant to an SSRI is not uncommon in clinical practice, particularly if patients have had a partial response (at least 20 percent improvement).

Altamura and colleagues82,83 have compared intravenous citalopram with intravenous clomipramine following inadequate response to SSRIs, but these trials were preliminary and the short term use of intravenous medication does not address the more typical situation in which patients have a second oral medication added to the SSRI.

Traditional augmentation strategies comprised the bulk of studies meeting criteria for inclusion in this review. Most trials investigated whether adding a new agent to ongoing SSRI treatment was preferable to adding a placebo to ongoing SSRI treatment. Therefore, in most instances what was compared was monotherapy with the initial SSRI against cotherapy with the original SSRI and a new agent. Although the majority of studies fell into this category, there are a limited number of studies for any particular augmenting agent, limiting the strength of the results. The array of agents studied meant that it was difficult to make informed decisions regarding specific classes of medications. Additionally, there are very few studies that examined augmentation compared with switching strategies, which is a clinically relevant question. That is, many clinicians would likely find it helpful to understand the conditions under which it is preferable to add a second treatment rather than switch medications. At least one previous report suggested that clinicians tend to switch medications when there has been minimal response to the treatment and augment when there has been partial response, but whether this approach results in optimal outcomes is not known.195

The use of atypical antipsychotics has recently gained prominence in the clinical community. Olanzapine was one of the first atypical antipsychotic medications evaluated. Other atypical antipsychotic medications have since been studied as potential add-on, and even monotherapy, treatments for MDD. Aripiprazole has been studied as an add-on therapy for patients not responding to antidepressant medications,105,109,126,131 but the results are not reported in these publications, as SSRI-specific subgroup data are reported only as mean change scores rather than remission and response rates. In the United States, this agent now has an indication as an add-on therapy for patients who do not have adequate response to antidepressant treatment. Similarly, quetiapine, another atypical antipsychotic medication, has been studied as add-on therapy in MDD, but the studies were not restricted to SSRI treated patients and the data could not be disaggregated in order to examine the effectiveness of this approach for patients treated only with SSRIs.196,197 A recent pooled analysis not eligible for our review due to publication date, reports showing statistically significant differences in mean scores for the SSRI subgroup favoring quetiapine.198

A meta-analysis examined the role of atypical antipsychotic medications as add-on therapies in MDD.199 The authors reported that the mean odds ratios (ORs) were similar for the various atypical agents studied (olanzapine, quetiapine, risperidone, and aripiprazole); they further reported that they could not appreciate that trial duration or method of establishing treatment resistance influenced the pattern or magnitude of the reported results. The OR reported for response in that meta-analysis (OR 1.69, 95% CI 1.46 to 1.59 ) is comparable to the relative risk (RR) in the risperidone trial by Mahmoud and colleagues108 (RR 1.86, 95% CI 1.16 to 2.96), and more modest than the preliminary results presented by Shelton and colleagues for olanzapine in combination with fluoxetine (RR 13.0, 95% CI 0.83 to 203.0).122

Although lithium was once described as the single agent with the most extensive evidence base for use as an augmenting agent in MDD,200 surveys suggested that it did not have wide uptake in the United States as an agent for treating people with unipolar depression.201 The results of lithium trials in this evidence review do not support its position as a leading augmentation strategy for this population. We recognize that the trials examined here represent only the portion of lithium trials in which patients were treated with SSRIs initially (meeting the criteria for inclusion in this review). Lithium may, however, have anti-suicide properties202 or other features that may make it attractive as an add-on agent in some patients with MDD, such as its low potential to induce a mood switch or cycling in depressed patients with strong genetic vulnerability to bipolar disorder.

There is an extremely limited evidentiary base on which to make conclusions regarding the relative efficacies of various combination treatment approaches for patient with an inadequate response to an SSRI. One treatment strategy is to use a combination of treatment modalities, such as a medication in combination with cognitive behavioral therapy (CBT). The STAR*D trial attempted to measure the value of both CBT as monotherapy and CBT in combination with ongoing citalopram treatment, but the number of patients electing CBT or agreeing to the possibility of being randomized to CBT was small compared to the overall sample size, and this limits conclusions that can be drawn about CBT from the STAR*D trial. A number of issues related to the provision of CBT in the STAR*D trial have been suggested to account for the relatively small number of patients who found CBT an acceptable option, and these may have limited the generalizability of the patients willing to enter that arm. Another eligible trial of a modified cognitive therapy administered to patients as an augmenting agent following nonresponse to antidepressant medication, found that psychotherapy was not different to next step pharmacotherapies that were described to have “closely paralleled those in the STAR*D study.” A relevant question for clinicians is whether patients who do not have an adequate response to treatment with an antidepressant would do better with an additional medical or with a talk therapy; studies to date do not provide evidence that there are reliable differences in the expected outcomes between these approaches. A caveat to that statement, however, is that patients in both STAR*D and the recent REVAMP trial had many past episodes of depression and it is therefore unknown whether younger patients or those earlier in their course of illness would be more likely to benefit from the addition of CBT than the more chronic group.84 The TORDIA trial of adolescents with depression who received CBT in combination with medication suggested that this combination might be beneficial in those with a low past illness burden.42,140,141

A large number of studies included a portion of patients treated with SSRIs and a portion treated with other antidepressant medications. Response and remission rates were not reported as a function of baseline therapy for most studies and although there was a systematic process for contacting authors of the studies, very few were able to provide response and remission data for the subgroup of patients treated with SSRIs. Even registration trials of new add-on treatments for patients not responding to an antidepressant medication have not examined whether the add-on agent is equally effective when added to a range of antidepressant classes. This resulted in the exclusion of a large number of studies containing relevant data because the data for SSRI treated patients could not be disaggregated from those treated with other antidepressants. There appears to be an assumption amongst investigators in this field that response and remission will be comparable regardless of the class of background medication. We are not aware of clinical or neurobiological data to convincingly support this assumption and we suggest that perhaps the assumption should be revisited. It is likely that the major disincentive to examining the effectiveness of various add-on therapies as a function of the antidepressant class used as cotherapy is that it will add to required sample sizes. It is possible that if extant studies were examined by disaggregating the various antidepressants employed as the primary treatment, that a preliminary investigation of whether add-on treatments are equally effective for all antidepressant classes could be conducted.

Depressive symptoms that do not meet full DSM criteria for a major depressive episode can be persistent and disabling. The DSM-IV has provided classification for dysthymia, but there is little evidence that dysthymia is distinct from subthreshold depressive symptoms apart from the extended duration of symptoms required for the diagnosis of dysthymia.164 The PROSPECT trial evaluated treatment of subthreshold symptoms in the elderly, and combined patients with subsyndromal depression (two symptoms), dysthymia, and minor depression as a single group.203 It would be useful for investigators to expand the evidence base examining whether distinctions between these subthreshold groups are important. It would also be useful for future treatment studies if a consensus could be reached regarding how to define treatment response or nonresponse when few symptoms are present at baseline.

Finally, the majority of studies did not state an intention to evaluate equivalency, noninferiority, or superiority relative to the standard treatment. Even if the trials had attempted to establish these differences, there are several challenges that need to be considered. The first challenge is specifying a priori the margins for defining equivalence, noninferiority, and superiority. There is a need to engage in consensus work to establish acceptable boundaries for these margins. Following this, appropriate power and statistical analyses to establish the equivalence, noninferiority, or superiority also need to be adequately reported.204 Additionally, an underlying assumption to such trial analyses, is that the standard treatment is efficacious. This assumption is problematic in those studies where one arm of the trial is a continuation of the same intervention to which failed response is established. Similarly, studies that switch subjects to new treatments as the standard arm also challenge the assumption of efficacy.

#### Adolescents

Only three trials were identified that were of relevance to the adolescent population. The subset of relevant patients could not be extracted from one study (TADS),139 leaving two studies of children and adolescents that addressed the question of next line treatment for young people who have not had an adequate response to an SSRI. The TORDIA study appears to emphasize the role for CBT in treating youth. Results continue to emerge from the TORDIA trial146–149,205 and will likely provide further information describing the effective components of care for adolescents who have treatment resistant depression. The single trial evaluating dose escalation in children and adolescents would suggest that a dose increase did not show any significant differences in either outcomes of benefit or harm; however, this trial was not adequately powered.138 While the TORDIA trial represents a major advance in the recognition of the need to have data on second-line treatment approaches for adolescents with MDD, much more work is required to determine the most effective ways to optimize short- and long-term outcomes for adolescents with depression. The apparent benefit of CBT in combination with medication that was observed in the TORDIA trial was not similarly apparent in either the STAR*D or REVAMP trials. The TORDIA trial explicitly states that almost three in four patients were receiving their first treatment for MDD, while the STAR*D participants had a much higher average burden of illness, and the REVAMP participants were specifically chosen to have chronic depression. This raises the question of whether the effectiveness of CBT is determined in part by the illness history and burden of participants; it has been suggested that this might be the case for CBT in patients with bipolar disorder206 and is worthy of further investigation in unipolar depression. Access to CBT is limited in many jurisdictions, and as such, clinicians may choose to reserve the therapy for those who are in a stage of illness where there is a reasonable probability that it will be associated with superior results than other, more accessible, treatment modalities.

### KQ2 What are the harms of each of the monotherapies or combined therapies among these adults and adolescents? How do the harms compare across different interventions?

It is difficult to summarize any specific trend observed for harms in adults across all the different interventions in the eligible studies within this CER. In general, the types of the events reported were consistent with the use of antidepressants and these were generally classified as mild and relatively transient. The findings from this CER have shown that most treatment strategies show no relative differences and that either strategy (the standard or comparator) are likely of modest or uncertain benefit. In this context, evaluation of the harms takes on greater importance. That is, if there is no meaningful difference in the potential outcomes of benefit, the margins between benefits and harms become narrower. Given that many of the treatments that were evaluated likely have no difference (or are potentially equivalent), evaluation of the harms profile also takes on a greater importance in judging the relative efficacy of the two interventions. However, the limitations observed in collecting and reporting harms across the studies constrains the judgments made regarding the margin of difference between harms and benefits and the relative differences in safety profiles of likely equivalent treatments. The inability to distinguish if the studies did not measure these harms, rather simply not reporting them (either because no events occurred or they occurred at the lowest frequencies) makes rating strength of evidence (SOE) problematic. We considered the measurement of sucidiality critical, and therefore necessary for all studies, given the potential of a serious event in MDD and with most treatment approaches. The atypical antipsychotic medications carry a substantial burden of short-and long-term side effects, along with a need for routine metabolic monitoring. Other augmentation agents, such as lithium and tri-iodothyronine, also have short-and long-term harms associated and also require the need for routine bloodwork and possibly other monitoring. Because the short-or long-term harms have not been systematically compared across agents, it is not possible to make a relative determination regarding the potential for harms between agents added as a second-line treatment. There are other potential harms, such as the lethality of a medication in overdose, that are relevant to prescribing physicians but are not routinely captured in clinical trials.

All but one study112 reported some aspect of safety and tolerability, and similarly, only one study was partially designed to evaluate harms as a primary outcome.114 No observational studies evaluating inadequate response to SSRIs were eligible for this review; as such, potentially long-term consequences of these treatment strategies (e.g., increasing the dose or adding an augmenting agent) typically evaluated in such studies are therefore not known. Recognizing that from a statistical perspective, it may be difficult to evaluate statistical differences when event rates are low, we found that the majority of studies did not undertake such tests when comparing differences between groups. Thus, establishing clinically important differences in harms profiles (largely reported as frequencies) is based mainly on judgements.

Rates of discontinuation due to adverse events were variable. The duration of a study can have an important influence on the reported rate of discontinuation. In studies with open-label prospective failure components, the number of patients who had adverse events and did not proceed to the next phase, were not consistently reported. In studies with historical failure, the proportion of subjects who had experienced inadequacy of response due to intolerance because of harms, was not sufficiently detailed. Some studies excluded subjects with any history of drug reactions. Thus, intolerance was not distinguished from inadequate response in these retrospective studies. Disentangling this issue may prove to be helpful in understanding who may achieve a more favorable response in second-line treatment approaches.

Washout periods were included in very few study protocols. For interventions with a switch to new interventions, this may be problematic as early side effects from these new treatments may reflect symptoms related to withdrawal from the previous SSRI or medication rather than reflecting the harms associated with the new treatment.

The method of assessing adverse events differed greatly among studies, with a limited number utilizing standardized scales specific to harms, or reporting adequate details about the protocols and methods used to assess harms. A priori definitions of serious or severe harms were consistently not specified within eligible studies. Details regarding the qualificatons of the assessor or how harms were decided to be linked to the treatment were almost always lacking. Both of these factors suggest the high risk of bias due to misclassification. Future clinical trials should conform to CONSORT reporting standards for harms.207

The two studies evaluating harms in adolescents used standardized harms reporting instruments and provided details about the frequency of assessment, assessor characteristics and sufficient details about how the harms were collected to allow for replication of the methods. This suggests a higher sensitivity for adequate collection and reporting of harms in this younger population. However, the potential for long-term adverse events within this population is not known, as no observational studies specific to the failed SSRI group were identified.

### KQ3 How do these therapies compare in different populations (e.g., different depressive diagnoses, disease severity, age, gender, racial and socioeconomic group, and medical or psychiatric comorbidities)? These subgroups will be considered with respect to the different interventions

There are seven studies in adults and one for adolescents with MDD that undertook stratified or subgroup analyses evaluating factors that may impact treatment outcomes. The findings for baseline severity are inconsistent, with two studies suggesting no impact and three showing that higher baseline scores were linked to a greater change in scores, or that those with more severe depression are less likely to achieve remission. It is important to note that many studies excluded subjects with psychiatric comorbidities, particularly subjects with anxiety disorders, bipolar disorder, or depression with psychotic features. The STAR*D cohort showed that those with concurrent anxiety related psychiatric comorbidities were less likely to achieve remission, and that the various treatments did not benefit the anxious group any differently. No clear trend emerges for previous history of failure, age, gender, or race. From a clinical perspective, all of these factors have face validity as potentially important treatment modifiers. One could argue that there is a greater need to evaluate these characteristics as potential prognostic factors in populations who have failed to respond. The link with risk factors for predicting failed initial response (first episode) may provide important information for subsequent management of these patient populations.

Neither of the two studies evaluating children and adolescents assess specific subgroups with respect to age or severity. An analysis of the TORDIA trial42,140,141,144–149 on predictors of treatment response showed that milder depression, less family conflict, and absence of suicidal behavior were associated with greater likelihood of a positive treatment response at 12 weeks. There was some evidence that there was a differential response to combined treatment in adolescents with a history of sexual and physical abuse; this suggests that specialized clinical approaches may need to be considered in this subgroup of patients.

### KQ4 What is the range of recommended clinical actions following the failure of one adequate course of an SSRI based on current clinical practice guidelines published between 2004 and April 2011?

To our knowledge, a comparison of CPGs on managing MDD, dysthymia, and subsyndromal depression in general, much less for those who failed to respond to antidepressant treatment, has not yet been undertaken. This CER evaluated 27 CPGs published in English, limited to those applicable in the national context or from large national professional associations. Seven CPG that were specific only to adolescents, 18 CPG to adults alone, and two were applicable to both adults and adolescents. All guidelines were applicable to patients with MDD but only four CPGs included recommendations for patients with dysthymia and subsyndromal depression. None of the four guidelines with recommendations for this subgroup provided recommendations for those who had failed to respond to previous treatment, possibly reflecting a lack of consensus for treatment in general or recognition for management of this subgroup of depressive disorders. This also raises the issue of interpreting “failed” response in a group for which the range of change is much smaller (fewer symptoms at baseline) relative to those with MMD for which the outcomes were originally designed.

From these CPGs, four did not provide any recommendations for subjects who had an inadequate response. These guidelines were not excluded, as our interest was in identifying the relative proportion of guidelines that did not address the population of interest.

From 18 CPGs in adults, the majority did not report any specific definitions for adequate response or remission within the guideline. For CPGs that did report a formal definition of inadequate response, only two CPGs provided clear indications for differential treatment strategies for those with partial versus nonresponse. This would suggest that the clinical and research community may require both consensus work and knowledge translation strategies to establish standardized definitions for failed or inadequate response. Concommitant to this issue is work to either select a single instrument or to allow for cross referencing between instruments. It is not clear that a 50 percent change in response relative to baseline on the PHQ-9 is similar to a 50 percent change on the HAMD-31.

Evaluation with the AGREE II instrument showed very high variation in the domains of rigour of development, applicability, and editorial indepndence. This was amplified for the guidance targeted at groups that had inadequate responses to initial treatment. This AGREE II criterion assessed whether the recommendations were clear and unambiguous, such that treatment options were distinctly presented, and key recommendations easily identifiable. The wide variation in strategies recommended across CPGs would seem to match the insufficiency of the evidence shown in our review for many treatment strategies. Although some CPGs clearly stated the limitations of the evidence, others did not and often selectively reported findings from studies to match the recommended course of action. The uncertainty of the evidence needs to be better highlighted in these CPGs.

The operational definition of CPGs is “systematically developed statements about specific clinical problems intended to assist practitioners and patients in making decisions about appropriate health care”68 presented some challenges. Our review excluded algorithms, which aim to provide guidance with regard to treatment strategies, methods of implementation, and treatment steps.208 Algorithms are often included in CPGs, but are not in and of themselves a guideline and the process of development may be preceded by a review of the evidence. The use of algorithims in clinical practice may be as prevalent as the use of CPGs, for example, the Texus Algorithm for MDD.207 Future developers of CPGs may wish to develop algorithims that can be incorporated into their guidelines that are evidence-based or at the least identify that they represent best practices.

Most CPGs failed to note or include any patient representation (a key stakeholder) in the development process. Although the CPGs generally rated as acceptable (higher scores) for attempting to link the evidence with the recommendations, the clinical sensibility of these treatment strategies are not addressed by the AGREE II. A variety of grading systems were used and comparison across different CPGs was problematic. The lack of clear guidance for some treatment options further compounded interpretations across guidelines.

The recommendations for most CPGs were stated broadly (switch or augment) and the link between the presentation of the evidence and the specific treatment recommendations was problematic in most CPGs. Few provided clear specification that there was insufficient evidence; rather, any available evidence was summarized with valuations of the strength of the evidence. For adults, the majority of CPGs did not indicate specific types of antidepressants when recommending switching to monotherapy strategies. Increases in the dose and duration of treatment was frequently recommended but the treatment interval or change in dose was not specified. When combined therapy was recommended there was a greater tendency to specify the medication to be added. However, there was great variability across CPGs in the augmenting agents recommended. The lack of specificity and the relatively high degree of variability is most likely related to the limitations of the evidentiary base.

Guidelines for adolescents scored equally poorly on the AGREE II domain for clarity of presentation of the recommendations. Three of seven guidelines cited adult evidence to justify recommendations for some pharmacological strategies, particularly the use of augmentation agents. Only two CPGs provided definitions of inadequate response. Two guidelines considered failure following nonpharmacological interventions rather than inadequate response to antidepressants, which may reflect a preferential tendency to adopt nonpharmacological strategies in youth. In general, the CPGs for adolescents had a greater tendency to specify the medications to consider for both monotherapy and combined therapy. However, all noted the limitations of the evidence applicable to adolescents.

## Applicability

The study populations in the eligible literature were relatively homogenous but were limited to predominately white or Caucasian women within a relatively narrow age range, often with mild to moderate depression. Additionally, there was a tendency to exclude patients who had medical and psychiatric comorbidities. The majority of the participants in the studies often had greater than two past episodes and high numbers (greater than two) past treatment failures on antidepressants. As such, the study subjects represent a narrow spectrum of patients with MDD who are likely to fail to respond when presenting to clinicians in primary care settings. As noted previously, there were few studies evaluating patients with dysthymia and subsyndromal depression, or in children and adolescents.

The dose range of many of the SSRIs and other antidepressants were within standard ranges used as monotherapy or as add-on agents. However, there was some variability in dosing for some augmentation agents and a general lack of rationale for the selected doses of these agents. There are limited data confirming that the doses selected for nonantidepressant augmentation agents reflect the optimum doses of those medications, in the context of augmenting another agent in a person with MDD. In some instances, the rigour of the nonpharmacological treatments may not be consistent with those seen in outpatient settings that patients might access. For example, within the TORDIA trial, the type of CBT was intensive and had high fidelity, but it is not clear if accessing therapists with expertise in working with adolescents is feasible in all jurisdictions. The variation in treatment duration across studies is potentially problematic; this may reflect a lack of consensus as to what constitutes an adequate treatment duration. The assumption has been that treatment duration with combined pharmacological agents are similar to those for antidepressants (a miminum of 4 to 6 weeks).

There is the additional problem of regulatory approval for many of the drugs used as augmenting agents. Some of these drugs do not have any approval by the U.S. Food and Drug Administration (Agomelatine (Valdoxan), Reboxetine (Edronax, Vestra), Norvale (Mianserin, Bolvidon, Tolvan), and many others do not have approval as augmenting agents, suggesting their off label use.

The outcomes used in most studies (for example, the MADRS or HAMD) are clinician administered; fewer studies used self-report instruments (for example, the QID-SR16 or the PHQ-9). The feasibility of using such instruments in primary care is a consideration that is recognized in the clinical literature.151 Most of these studies were undertaken in outpatient mental health or primary care settings and are therefore applicable to the settings to which the majority of patients will be seen by practitioners. Conversely, the findings of this review may not be applicable to patients in different settings such as inpatient or specialized psychiatric contexts. However, we note that characteristics of inpatient and outpatient settings differ within health care systems and countries; it is conceivable that important patient characteristics (e.g., severity, duration) may not actually differ between some inpatient and outpatient settings.

There are some special considerations with respect to the monitoring of harms in primary care settings. Although we found the majority of studies did not provide sufficient detail regarding the collection of harms, there is a tendency to monitor harms more rigourously and with the use of standardized instruments in the studies. For example, the TORDIA trial had employed rigourous methods for monitoring harms (for example, weekly monitoring for those displaying any adverse events) and this may be difficult in replicate primary care settings.

## Comparative Effectiveness Review Limitations

This CER has several constraints in its methodology in the context of the literature search. Although over 40,000 citations were screened, the citations were limited to those published in the English language. In addition, the search was limited to publications from 1980 forward, as SSRIs were not in use prior to this time. In consultation with the TEP and partners, issues around predictors of response were considered and it was recognized that the scope of the review was sufficiently large to prohibit evaluation of predictors of response.

We identified a large number of studies that had patients who had failed to respond to a variety of antidepressants; those studies that clearly included only 100 percent of patients who failed on a nonSSRI, or those who had failed on combination therapies prior to entry into the study, were excluded. However, there was a subset of studies that had some proportion who may have failed treatment on an SSRI prior to entry. Attempts were made to contact all authors (n=167 studies) of these studies, who were asked to provide subgroup data specific to the SSRI failed group. Some authors declared that they could not provide us with stratified analyses and these studies were excluded. The contact information for some authors was incorrect, and several attempts to find information related to the publication investigators was made; for some of these, direct contact with the authors was not successful and these studies were excluded as well. Some of the authors did not respond to emails, and after two attempts we excluded these publications as well. A limited number of authors provided us with some stratified results for outcomes and we acknowledge that some of the findings from these stratified analyses may be compromised as the study designs were not such to ensure balance between the SSRI and nonSSRI failed subjects.

A search of the grey literature identified approximately 350 links to regulatory agency documentation, and 171 of these were directly related to drugs found within our eligible studies. The aim in searching these sources was to identify unpublished trials and for potential deviations for reporting of study findings. However, none of these sources provided additional information to identify unpublished trials and evaluate the potential for reporting biases; this was primarily limited by the population (previous failure to SSRI). Previous research specific to antidepressants has shown significant differences in the information reported to the FDA, relative to the same study publication in peer review journals.209 Our search of clinical trial registries identified that only 11 from 44 of our eligible studies (adults and adolescents) had been registered within the sources we were able to search.42,44,80,87–89,101,103–106,108–110,113,126,131,132,140,141 Moreover, the abbreviated information within the registry trials was not helpful in identifying selective reporting of outcomes or deviations to the stated protocols (for example, reporting information on early phases of the trial or not detailing any subsequent protocol modifications). Trial registries are dependent on investigators to voluntarily update information and may not reflect the most updated source of trial protocol information.

## Summary/Conclusions

### KQ1 Among adults and adolescents with Major Depressive Disorder, Dysthymia, and Subsyndromal Depression, who are started on an SSRI and who are compliant with treatment but fail to improve either fully, partially, or have no response, what is the benefit (efficacy or effectiveness) of monotherapy and combined therapy?

### KQ1a How does the efficacy/effectiveness vary between the different monotherapies and combined therapies?

1. Studies in adults with MDD and an inadequate response to an SSRI included a preponderance of subjects with multiple past depressive episodes and multiple past unsuccessful treatment trials. The generalizability of these data to people with few past episodes of depression may be limited.
2. Studies in adults with MDD and an inadequate response to an SSRI included a high proportion of whites and women and tended to have an average patient age in the early forties.
3. Studies in adults examining treatment for a major depressive episode following inadequate response to an SSRI examined monotherapy compared with monotherapy, monotherapy with combination therapy or combinations of therapies. The majority of studies compared monotherapy (usually ongoing treatment with the initial SSRI) with a combination of therapies (usually ongoing treatment with the initial SSRI in addition to a nonantidepressant medication).
  a. The number of studies comparing single medications against each other (monotherapy compared with monotherapy) following an inadequate response to an SSRI is extremely limited. Extant studies are limited in type of agents utilized, sample sizes, and population characteristics. The extant data do not support a difference between various single agent therapies for the outcomes of response and remission.
    i. Strength of Evidence: There is insufficient evidence to evaluate the benefits of changing the dose, switching to a different SSRI, a nonSSRI antidepressant, a nonantidepressant medication, or a nonpharmacological treatment following an inadequate response to an SSRI. With respect to harms there is also insufficient evidence from the studies that were reviewed but the known differential adverse effect profiles amongst different drug categories may provide guidance in making a comparative benefit-risk assessment.
  b. The largest number of eligible studies examined monotherapy with combination therapy. The majority of studies compared outcomes following ongoing treatment with placebo added to the initial SSRI (the agent to which the subject had not responded by a defined time interval) with outcomes when an active agent was added to the initial SSRI.
    i. Strength of Evidence: There is insufficient evidence to evaluate the benefits of ongoing monotherapy with an SSRI as opposed to combination treatment involving the addition of another antidepressant medication to the initial SSRI.
    ii. Strength of Evidence: There is low grade evidence that comparable results are achieved following switch to an alternate antidepressant medication (monotherapy with a new antidepressant) when compared with adding a nonantidepressant treatment to the initial SSRI (traditional augmentation approach).
    iii. Strength of Evidence: There is low grade evidence that adding an atypical antipsychotic medication to ongoing SSRI treatment is associated with higher response and remission rates compared with adding a placebo to ongoing SSRI treatment.
    iv. Strength of Evidence: There is insufficient evidence for the benefit of other augmentation agents (buspirone, lithium, mianserin, other pharmacological agents, and psychological interventions).
  c. Studies examining combinations of treatment were also extremely limited in number, types of medications, and homogeneity of populations. Extant data do not suggest that any specific combination of active treatments is different to another specific combination of treatments.
    i. Strength of Evidence: There is insufficient evidence to evaluate the benefits or harms of specific combinations of treatments relative to alternative combinations.
4. Studies examining response and remission rates in children and adolescents to treatment subsequent to an inadequate SSRI response were extremely limited. Of three potential trials, data could only be extracted from two and one was a pilot study evaluating dose escalation. The TORDIA trial was of high quality and the results did not show a difference when monotherapy treatments were compared; a switch from the inadequate SSRI to another SSRI was associated with comparable outcomes to a switch to an SNRI. The trial did, however, report that combination therapy of a medication and CBT was superior to monotherapy with a medication.
  a. Strength of evidence: There is low grade evidence to support the use of CBT in combination with an antidepressant following inadequate response to an SSRI for adolescents (age 12 to 18) with MDD.
5. Studies examining response and remission rates in patients specifically selected to have subsyndromal symptoms associated with inadequate response to SSRI were also extremely limited. Only one trial was eligible and that trial had metabolic parameters as the primary outcomes interest.
  a. Strength of evidence: There is insufficient evidence to support the use of specific treatments for patients with subsyndromal symptoms following an inadequate response to SSRI medications.
6. Studies examining patients with dysthymia, but not MDD, and an inadequate response to an SSRI medication were extremely limited. Only one trial was eligible and that trial did not report a difference between treatment with paroxetine 40mg compared with paroxetine 20mg and amisulpride.
  a. Strength of evidence: There is insufficient evidence to support the use of various treatment approaches for patients with dysthymia who have inadequate response to an SSRI.

### KQ2 What are the harms of each of the monotherapies or combined therapies among these adults and adolescents? How do the harms compare across different interventions?

1. Harms for interventions used in both adults and adolescents with MDD who had failed to respond to an SSRI were derived from RCTs that evaluated treatment strategies in this population; no observational studies were eligible. A clear trend for harms was difficult to specify across the differing interventions in adults. Harms were evaluated and reported in a comprehensive and unbiased manner in the single study in adolescents.
2. Reporting and collecting of harms was problematic, particularly for predefining harms including serious and severe events and reporting total number of events per group in the studies with adults. The single study evaluating harms in adolescents provided high quality evidence for harms within this population when receiving pharmacological and psychological treatment.
3. The studies included were short term treatment trials. Harms that may not be apparent in short term clinical trials might emerge with long term use of agents. The relative potential for long term harms and monitoring burden of various agents was not evaluable in the short term treatment trials included here.

### KQ3 How do these therapies compare in different populations (e.g., different depressive diagnoses, disease severity, ages, gender, racial and socioeconomic group, and medical or psychiatric comorbidities)?

1. There are a limited number of studies that have evaluated the impact of disease type, disease severity, previous comorbidities, age, gender, and race in the treatment of adults and adolescents who have failed to respond to an SSRI.
2. Only two studies have evaluated psychiatric comorbidities, and findings from the STAR*D cohort of level two adult patients would suggest that patients with anxiety related disorders (particularly anxious patients) are less likely to achieve remission.
3. There is high quality evidence from the TORDIA trial suggesting that mild depression, less family conflict, and the absence of suicidal behavior is associated with a greater likelihood of response in adolescents.

### KQ4 What is the range of recommended clinical actions following the failure of one adequate course of an SSRI based on current clinical practice guidelines published between 2004 and April 2011?

1. The majority of clinical practice guidelines (CPGs) for adults were applicable to patients with MDD for outpatient and primary care settings. The majority of CPGs provided recommendations for patients who had failed previous treatments, but did not specify definitions of “inadequate response.”
2. No recommendations for persons with dysthymia or subsyndromal depression who had failed previous treatment were found in the limited number of CPGs that included this population.
3. Recommendations for monotherapy, including dose or interval changes, switching to a different SSRI, or a nonSSRI, were nonspecific as to the drug, interval, or dose change.
4. Recommendations for combination therapy tended to recommend specific types of antidepressants and augmenting agents. However, there was inconsistency across CPGs with regard to the types of augmenting agents to use.

## Future Research Recommendations

Future research should attempt to incorporate the following recommendations for primary studies evaluating patients who have failed to respond to an SSRI:

### Population

1. Include a broader representation of adult patients with respect to age (>50 and <40), gender (equal proportion of men), and ethnicity (increased proportion of non-white or non-Caucasian, or provide broader representation of all ethnic groups).
2. Include patients derived from primary care settings to incorporate a complete spectrum of participants who have failed to respond to an SSRI.
3. Give detailed specifications of how previous history of failed treatment was determined. The number of previous failures and, where possible, the antidepressant to which subjects had not responded and any factors associated with intolerance to antidepressants.
4. Specify previous mental health history including age at first diagnosis, length of current episode, and number of previous episodes at baseline.
5. Collect information about the presence of other medical and mental health comorbidities at baseline.
6. Collect information on the use of complimentary and alternative medicine (CAM) therapies that have the potential to confound and contaminate study interventions.

### Comparator and Study Design

7 Determine treatment failure using a two-part study, the first part of which involves treating patients with SSRIs to prospectively determine failure. This confers methodological advantages in minimizing bias and allows the disentanglement of failure of response due to adverse events, compliance, or physiological response.
8 Specify the intent of the trial as attempting to establish equivalence, noninferiority, or superiority. Justification for the margin of inferiority or superiority should be detailed. Ideally, designing trials to establish superiority is preferred as this would assist clinicians in selecting treatment strategies.
9 Establish a sufficient sample size to show expected margins of difference between groups.
10 Establish a sufficient sample size to evaluate potentially important confounders such as age, gender, and baseline severity.
11 Consideration for possible additional studies that include subjects with dysthymia who have failed to respond to a previous SSRI. The validity of treating this diagnostic group needs to be considered, and if meriting treatment, then the evidence base should increase.
12 Consideration for possible additional studies with subjects with subsyndromal depression who have failed to respond to a previous SSRI. A clear definition of this subgroup (relative to dysthymia or minor depression) should be established. The validity of treating this diagnostic group needs to be considered, and if meriting treatment, then the evidence base should increase.
13 Increase the number of studies with children (ages 8 to 12) and adolescents (greater than 12 to 18 years). This patient population is increasing and needs to be adequately evaluated.

### Intervention

14 Establish a clear rationale for the dose used for augmenting agents.
15 Establish efficacy across a range of antidepressant classes with new add-on treatments for patients not responding to an antidepressant medication. The assumption among investigators in this field is that response and remission will be comparable regardless of the class of background medication; the clinical or neurobiological data to support this assumption should be confirmed or revisited.
16 Evaluate the potential benefits of CAM therapies, either as monotherapy or augmenting agents.
17 The concomitant use of CAM therapies (co-interventions) that have the potential to confound interventions should be restricted or monitored (as are other pharmacological agents).
18 Long-term benefits and harms of various add-on agents will be apparent only with long-term followup. There are few studies examining the optimal duration of various treatment strategies beyond the achievement of remission. Future studies should examine whether the short-term benefits of various approaches are sustained and whether the harms of various approaches are acceptable.

### Outcomes

19 Specifying primary and secondary outcomes.
20 Consider the inclusion of outcomes other than response or remission, but also include outcomes such as quality of life and speed of response.
21 Report the proportions of subjects who are classified as nonresponders (<20 percent) and partial responders (20 to 49 percent change from baseline) in addition to the sum of the proportion who did not achieve response.
22 Report the definition of adequate response and remission
23 Conform to CONSORT207 reporting standards for harms. As such, severe and serious events (including suicidality) should be defined a priori and the use of standardized instruments or terminology for reporting harms should be adopted. Long-term trials may be required to capture harms adequately.

### Other

24 Studies with a sufficient sample size to explore these potential subgroups (age, gender, baseline severity, ethnicity, and type of depression) should be considered.
25 Register within clinical trial registries in order to evaluate the potential for publication bias and selective outcome reporting. Researchers should endeavor to regularly update information reported within these registries.

Future recommendations for the development of CPGs for adults, children, and adolescents should include the following:

1. A clear definition of inadequate response for both pharmacological and nonpharmacological treatments and standardized methods for establishing this in real world settings.
2. The addition of patient representation in the CPG development process.
3. Greater clarity with regards to recommended actions and the link with the evidence. Clinicians using the CPGs should be clear when evidence is insufficient.
4. Clear identification of when the recommendations are based on best practice recommendations (as when the evidentiary base is insufficient or weak) relative to when the evidence is sufficient.
5. The impact of contextual factors, such as practice setting (inpatient versus outpatient) or type of clinican (e.g., primary care practitioner, psychiatrist).