# Forms

Title and Abstract Level I

Title & Abstract Level 2

Full Text Screening, Level 3

Level 4 Data Extraction -Primary Studies (General Information)(Groupin)

Data Extraction, Primary Study-Harm (Grouping)

Quality Assessment for Primary Studies Rater #1 (Grouping)

Quality Assessment for Primary Studies Rater #2 (Grouping)

Data Extraction - Primary Study - outcome (Grouping)

Level 4 - Data Extraction Guidelines & Recommendations

Level 5: Quality Assessment Tools for Guidelines and Recommendations: AGREE II instrument for Guidelines

Level 5: Quality Assessment Tools for Guidelines and Recommendations: AGREE II instrument for Guidelines