# Search Strategy

## OVID-Medline

April 13 2011

1. dysthm*.tw.
2. (subclinical adj2 depressi*).tw.
3. (subsyndromal adj2 depressi*).tw.
4. (subthreshold adj2 depressi*).tw.
5. (subdiagnostic adj2 depressi*).tw.
6. Depression/
7. depressive disorder/ or depressive disorder, major/ or dysthymic disorder/
8. or/1–7
9. serotonin uptake inhibitors/ or citalopram/ or fluoxetine/ or fluvoxamine/ or paroxetine/ or sertraline/
10. (citalopram or celexa or cipramil or dalsan or recital or emocal or sepram or seropram).mp.
11. (escitalopram or es citalopram or lexapro or cipralex or esertia).mp.
12. (fluoxetine or prozac or fontex or seromex or seronil or sarafem or fluctin or fluox or lovan).mp.
13. (fluvoxamine or luvox or fevarin or faverin or dumyrox or favoxil or movox).mp.
14. (paroxetine or paxil or seroxat or sereupin or aropax or deroxat or rexetin or xetanor or paroxat).mp.
15. (sertraline or zoloft or lustral or serlain).mp.
16. ssri?.mp.
17. selective serotonin reuptake inhibit*.tw.
18. symbyax.mp.
19. or/9–18
20. Drug Resistance/
21. treatment failure/
22. Retreatment/
23. ((difficult or hard) adj3 treat).tw.
24. augment*.tw.
25. nonrespon*.tw.
26. non-respon*.tw.
27. switch*.tw.
28. ((insufficient or inadequate or incomplete) adj3 respon*).tw.
29. (ssri? adj3 (resist* or fail* or respon* or refractory)).tw.
30. (partial adj3 respon*).tw.
31. ((combination or adjunct*) adj3 (therap* or drug? or treat*)).tw.
32. ((treat* or therapy or drug) adj4 (resist* or fail*)).tw.
33. ((treatment resistant or refractory) adj3 depressi*).tw.
34. or/20–32
35. 8 and 34
36. 35 or 33
37. 8 and 19
38. 36 or 37
39. *depression/ or *depressive disorder/ or *depressive disorder, major/ or *dysthymic disorder/
40. or/1–5
41. 39 or 40
42. 5-Hydroxytryptophan/
43. phototherapy/
44. light therapy.tw.
45. exp Exercise/ae, th [Adverse Effects, Therapy]
46. exp Exercise Therapy/
47. exp Acupuncture Therapy/
48. exp Massage/
49. Relaxation Therapy/
50. exp vitamins/
51. Hypericum/
52. john* wort.tw.
53. deplin.tw.
54. methylfolate.tw.
55. Folic Acid/
56. S-Adenosylmethionine/
57. “SAM-e”.tw.
58. exp Fatty Acids, Omega-3/
59. Cognitive Therapy/
60. Crocus/
61. Tryptophan/
62. exp Inositol/
63. or/42–62
64. 41 and 63
65. (harm? or adverse or “side effect?”).tw.
66. (adjunct* or augment*).tw.
67. 65 or 66
68. 41 and 67
69. exp *antidepressive agents/ae, to [Adverse Drug Reaction, Drug Toxicity]
70. 68 or 69
71. 38 or 64 or 70
72. animals/ not (animals/ and humans/)
73. 71 not 72
74. (comment or editorial).pt.
75. 73 not 74
76. review.pt,sh.
77. 75 and 76
78. meta-analysis.pt,ti,ab,sh.
79. (meta anal$ or metaanal$).ti,ab,sh.
80. ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ti.
81. ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ab.
82. ((pool$ or combined or combining) adj (data or trials or studies or results)).ti,ab.
83. (medline or embase or cochrane).ti,ab.
84. or/81–83
85. review.pt,sh.
86. 84 and 85
87. 78 or 86 or 80 or 79
88. 75 and 87
89. 77 not 88
90. 75 not 89
91. limit 90 to yr=“1980 -Current”
92. limit 91 to english language
93. 91 not 92

## OVID-Embase

April 13 2011

1. depression/ or agitated depression/ or atypical depression/ or dysthymia/ or endogenous depression/ or involutional depression/ or major depression/ or masked depression/ or melancholia/ or “mixed anxiety and depression”/ or “mixed depression and dementia”/ or organic depression/ or reactive depression/ or recurrent brief depression/
2. dysthm*.tw.
3. (subclinical adj2 depressi*).tw.
4. (subsyndromal adj2 depressi*).tw.
5. (subthreshold adj2 depressi*).tw.
6. (subdiagnostic adj2 depressi*).tw.
7. or/1–6
8. serotonin uptake inhibitor/ or citalopram/ or escitalopram/ or fluoxetine/ or fluoxetine plus olanzapine/ or fluvoxamine/ or paroxetine/ or sertraline/
9. ssri?.tw.
10. selective serotonin reuptake inhibit*.tw.
11. (citalopram or celexa or cipramil or dalsan or recital or emocal or sepram or seropram).mp.
12. (escitalopram or es citalopram or lexapro or cipralex or esertia).mp.
13. (fluoxetine or prozac or fontex or seromex or seronil or sarafem or fluctin or fluox or lovan).mp.
14. (fluvoxamine or luvox or fevarin or faverin or dumyrox or favoxil or movox).mp.
15. (paroxetine or paxil or seroxat or sereupin or aropax or deroxat or rexetin or xetanor or paroxat).mp.
16. (sertraline or zoloft or lustral or serlain).mp.
17. symbyax.mp.
18. or/8–17
19. Drug Resistance/
20. exp treatment failure/
21. Retreatment/
22. ((difficult or hard) adj3 treat).tw.
23. augment*.tw.
24. non-respon*.tw.
25. nonrespon*.tw.
26. switch*.tw.
27. ((insufficient or inadequate or incomplete) adj3 response).tw.
28. (ssri? adj3 (resist* or fail* or response or refractory)).tw.
29. (partial adj3 respon*).tw.
30. ((combination or adjunct*) adj3 (therap* or drug? or treat*)).tw.
31. ((treat* or therapy or drug) adj4 (resist* or fail*)).tw.
32. ((treatment resistant or refractory) adj3 depressi*).tw.
33. or/19–31
34. 7 and 33
35. 32 or 34
36. 7 and 18
37. 35 or 36
38. *depression/ or *agitated depression/ or *atypical depression/ or *dysthymia/ or *endogenous depression/ or *involutional depression/ or *major depression/ or *masked depression/ or *melancholia/ or *”mixed anxiety and depression”/ or *”mixed depression and dementia”/ or *organic depression/ or *reactive depression/ or *recurrent brief depression/
39. or/2–6
40. 38 or 39
41. exp *side effect/
42. (harm? or adverse or side effect?).tw.
43. 40 and 42
44. 41 or 42
45. 40 and 44
46. exp *antidepressant agent/ae, to [Adverse Drug Reaction, Drug Toxicity]
47. 45 or 46
48. 5 hydroxytryptophan/
49. exp vitamin/
50. exp Fatty Acids, Omega-3/
51. exp acupuncture/
52. exp exercise/
53. massage/
54. Relaxation Therapy/
55. phototherapy/
56. light therapy.tw.
57. Hypericum perforatum/
58. methylfolate.tw.
59. folic acid/
60. S-Adenosylmethionine/
61. SAM-e.tw.
62. (cbt or cognitive behavio?r therapy).tw.
63. cognitive behavior therapy/
64. inositol/
65. saffron/
66. crocus/
67. tryptophan/
68. exp diet therapy/
69. or/48–68
70. 40 and 69
71. (adjunct* or augment*).tw.
72. 40 and 71
73. 37 or 47 or 70 or 72
74. (editorial or note).pt.
75. 73 not 74
76. limit 75 to human
77. review.pt,sh.
78. 76 and 77
79. meta analysis/
80. meta-analysis.ti,ab.
81. (meta anal$ or metaanal$).ti,ab.
82. ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ti.
83. ((methodol$ or systematic$ or quantitativ$) adj3 (review$ or overview$ or survey$)).ab.
84. ((pool$ or combined or combining) adj (data or trials or studies or results)).ti,ab.
85. (medline or embase or cochrane).ti,ab.
86. or/83–85
87. review.pt,sh.
88. 86 and 87
89. or/79–82
90. 89 or 88
91. 76 and 90
92. 78 not 91
93. 76 not 92
94. limit 93 to yr=1980-current
95. limit 94 to english language

## Ovid-PsycINFO

April 13 2011

1. major depression/ or dysthymic disorder/ or endogenous depression/ or reactive depression/ or recurrent depression/ or atypical depression/ or “depression (emotion)”/
2. dysthm*.tw.
3. (subclinical adj2 depressi*).tw.
4. (subsyndromal adj2 depressi*).tw.
5. (subthreshold adj2 depressi*).tw.
6. (subdiagnostic adj2 depressi*).tw.
7. or/1–6
8. ((difficult or hard) adj3 treat).tw.
9. augmentation.tw.
10. nonrespon*.tw.
11. non-respon*.tw.
12. switch*.tw.
13. ((insufficient or inadequate or incomplete) adj3 response).tw.
14. (ssri? adj3 (resist* or fail* or response or refractory)).tw.
15. (partial adj3 response).tw.
16. ((combination or adjunct*) adj3 (therap* or drug? or treat*)).tw.
17. ((treat* or therapy or drug) adj4 (resist* or fail*)).tw.
18. or/8–17
19. 18 and 7
20. treatment resistant depression/
21. ((treatment resistant or refractory) adj3 depressi*).tw.
22. or/19–21
23. cognitive behavior therapy/ or cognitive therapy/
24. phototherapy/
25. “hydroxytryptophan (5-)”/
26. light therapy.tw.
27. exp exercise/
28. acupuncture/
29. massage/
30. exp relaxation therapy/
31. exp vitamins/ or vitamin therapy/
32. hypericum perforatum/
33. (S-Adenosylmethionine or SAM-e).tw.
34. folic acid/
35. fatty acids/
36. saffron.tw.
37. inositol.tw.
38. exp tryptophan/
39. or/23–38
40. serotonin reuptake inhibitors/ or citalopram/ or fluoxetine/ or fluvoxamine/ or paroxetine/
41. sertraline/
42. (citalopram or celexa or cipramil or dalsan or recital or emocal or sepram or seropram).mp.
43. (escitalopram or es citalopram or lexapro or cipralex or esertia).mp.
44. (fluvoxamine or luvox or fevarin or faverin or dumyrox or favoxil or movox).mp.
45. (fluoxetine or prozac or fontex or seromex or seronil or sarafem or fluctin or fluox or lovan).mp.
46. (paroxetine or paxil or seroxat or sereupin or aropax or deroxat or rexetin or xetanor or paroxat).mp.
47. (sertraline or zoloft or lustral or serlain).mp.
48. ssri?.mp.
49. selective serotonin reuptake inhibit*.mp.
50. symbyax.mp.
51. or/40–50
52. *major depression/ or *dysthymic disorder/ or *endogenous depression/ or *reactive depression/ or *recurrent depression/ or *treatment resistant depression/ or *”depression (emotion)”/
53. or/2–6
54. 52 or 53
55. (harm? or adverse or “side effect?”).tw.
56. adverse effects.id.
57. exp “side effects (treatment)”/
58. drug interactions/
59. exp toxicity/
60. (adjunct* or augment*).tw.
61. or/55–60
62. 39 or 61
63. 54 and 62
64. 7 and 51
65. 22 or 63 or 64
66. limit 65 to human
67. limit 66 to (“comment/reply” or editorial or encyclopedia entry or obituary or review-book or review-media or review-software & other)
68. 66 not 67
69. limit 68 to yr=“1980 -Current”
70. limit 69 to english language

### OVID-Cochrane Central Register of Controlled Trials

April 13 2011

1. dysthm*.tw.
2. (subclinical adj2 depressi*).tw.
3. (subsyndromal adj2 depressi*).tw.
4. (subthreshold adj2 depressi*).tw.
5. (subdiagnostic adj2 depressi*).tw.
6. Depression/
7. depressive disorder/ or depressive disorder, major/ or dysthymic disorder/
8. or/1–7
9. serotonin uptake inhibitors/ or citalopram/ or fluoxetine/ or fluvoxamine/ or paroxetine/ or sertraline/
10. (citalopram or celexa or cipramil or dalsan or recital or emocal or sepram or seropram).mp.
11. (escitalopram or es citalopram or lexapro or cipralex or esertia).mp.
12. (fluoxetine or prozac or fontex or seromex or seronil or sarafem or fluctin or fluox or lovan).mp.
13. (fluvoxamine or luvox or fevarin or faverin or dumyrox or favoxil or movox).mp.
14. (paroxetine or paxil or seroxat or sereupin or aropax or deroxat or rexetin or xetanor or paroxat).mp.
15. (sertraline or zoloft or lustral or serlain).mp.
16. ssri?.mp.
17. selective serotonin reuptake inhibit*.tw.
18. symbyax.mp.
19. or/9–18
20. Drug Resistance/
21. treatment failure/
22. Retreatment/
23. ((difficult or hard) adj3 treat).tw.
24. augment*.tw.
25. nonrespon*.tw.
26. non-respon*.tw.
27. switch*.tw.
28. ((insufficient or inadequate or incomplete) adj3 respon*).tw.
29. (ssri? adj3 (resist* or fail* or respon* or refractory)).tw.
30. (partial adj3 respon*).tw.
31. ((combination or adjunct*) adj3 (therap* or drug? or treat*)).tw.
32. ((treat* or therapy or drug) adj4 (resist* or fail*)).tw.
33. ((treatment resistant or refractory) adj3 depressi*).tw.
34. or/20–32
35. 8 and 34
36. 35 or 33
37. 8 and 19
38. 36 or 37
39. *depression/ or *depressive disorder/ or *depressive disorder, major/ or *dysthymic disorder/
40. or/1–5
41. 39 or 40
42. 5-Hydroxytryptophan/
43. phototherapy/
44. light therapy.tw.
45. exp Exercise/ae, th [Adverse Effects, Therapy]
46. exp Exercise Therapy/
47. exp Acupuncture Therapy/
48. exp Massage/
49. Relaxation Therapy/
50. exp vitamins/
51. Hypericum/
52. john* wort.tw.
53. deplin.tw.
54. methylfolate.tw.
55. Folic Acid/
56. S-Adenosylmethionine/
57. “SAM-e”.tw.
58. exp Fatty Acids, Omega-3/
59. Cognitive Therapy/
60. Crocus/
61. Tryptophan/
62. exp Inositol/
63. or/42–62
64. 41 and 63
65. (harm? or adverse or “side effect?”).tw.
66. (adjunct* or augment*).tw.
67. 65 or 66
68. 41 and 67
69. exp *antidepressive agents/ae, to [Adverse Drug Reaction, Drug Toxicity]
70. 68 or 69
71. 38 or 64 or 70
72. limit 71 to yr=“1980-Current”

### OVID-AMED

April 13 2011

1. depression/
2. dysthm*.tw.
3. (subclinical adj2 depressi*).tw.
4. (subsyndromal adj2 depressi*).tw.
5. (subthreshold adj2 depressi*).tw.
6. (subdiagnostic adj2 depressi*).tw.
7. or/1–6
8. antidepressive agents/
9. (citalopram or celexa or cipramil or dalsan or recital or emocal or sepram or seropram).mp.
10. (escitalopram or es citalopram or lexapro or cipralex or esertia).mp.
11. (fluvoxamine or luvox or fevarin or faverin or dumyrox or favoxil or movox).mp.
12. (fluoxetine or prozac or fontex or seromex or seronil or sarafem or fluctin or fluox or lovan).mp.
13. (paroxetine or paxil or seroxat or sereupin or aropax or deroxat or rexetin or xetanor or paroxat).mp.
14. (sertraline or zoloft or lustral or serlain).mp.
15. ssri?.mp.
16. selective serotonin reuptake inhibit*.tw.
17. or/8–16
18. 7 and 17
19. ((difficult or hard) adj3 treat).tw.
20. (adjunct* or augment*).tw.
21. nonrespon*.tw.
22. non-respon*.tw.
23. switch*.tw.
24. ((insufficient or inadequate or incomplete) adj3 response).tw.
25. (ssri? adj3 (resist* or fail* or response or refractory)).tw.
26. (partial adj3 response).tw.
27. ((combination or adjunct*) adj3 (therap* or drug? or treat*)).tw.
28. ((treat* or therapy or drug) adj4 (resist* or fail*)).tw.
29. or/19–28
30. 7 and 29
31. ((treatment resistant or refractory) adj3 depressi*).tw.
32. 30 or 31
33. cognitive behavior therapy/ or cognitive therapy/
34. phototherapy/
35. hydroxytryptophan.tw.
36. light therapy.tw.
37. exp exercise therapy/
38. exp acupuncture therapy/
39. massage/
40. exp relaxation/
41. exp vitamins/
42. hypericum perforatum/
43. (S-Adenosylmethionine or SAM-e).tw.
44. exp complementary therapies/
45. folic acid/
46. exp fatty acids/
47. crocus/
48. saffron.tw.
49. inositol.tw.
50. tryptophan/
51. or/33–50
52. 7 and 51
53. (harm? or adverse or “side effect?”).tw.
54. adverse effects/
55. or/53–54
56. 7 and 55
57. 18 or 32 or 52 or 56
58. limit 57 to (commentary or editorial or interview or news or notes)
59. 57 not 58
60. limit 59 to english
61. limit 60 to yr=“1980 -Current”

## EBSCO-CINAHL

S2 TX Hydroxytryptophan
S3 (MH “Therapeutic Exercise+”)
S4 (MH “Alternative Therapies+”)
S5 (MH “Massage+”)
S7 (MH “Simple Relaxation Therapy (Iowa NIC)”)
S8 (MH “St. John’s Wort”)
S9 “methylfolate”
S10 (MH “Folic Acid+”)
S11 (MH “S-Adenosylmethionine”)
S12 TX SAM-e
S13 (MH “Fatty Acids, Omega 3+”)
S14 (MH “Cognitive Therapy”)
S15 “saffron”
S16 (MH “Tryptophan”)
S17 (MH “Inositol”)
S18 S2 or S3 or S4 or S5 or S7 or S8 or S9 or S10 or S11 or S12 or S13 or S14 or S15 or S16 or S17
S19 (MM “Depression”)
S20 (MM “Depression, Reactive”)
S21 (MM “Dysthymic Disorder”)
S22 S19 or S20 or S21
S23 (S19 or S20 or S21) and (S18 and S22)
S24 Limiters - Publication Year from: 1980–2009
S25 S23 and S24
S26 Limiters - Publication Type: Accreditation, Advice and Referral Website, Anecdote, Audiovisual, Bibliography, Biography, Book, Book Chapter, Book Review, Cartoon, Code of Ethics, Commentary, Computer Program, Consumer/Patient Teaching Materials, Directories, Editorial, Exam Questions, Games, Individual Testimonial Website, Interview, Listservs, Masters Thesis, Obituary, Pamphlet, Pamphlet Chapter, Poetry, Software, Teaching Materials, Tracings, Website
S27 S25 NOT S26
S28 S27 Limiters - Language: English

## Grey Literature Search

The following sources were search using sensitive searches similar to the searches in bibliographic databases

- Regulatory Information
  FDA
  Health Canada
  Authorized Medicines for EU
- Clinical Trial Registries
  ClinicalTrials.gov
  Current Controlled Trials
  Clinical Study Results
  WHO Clinical Trials
- Abstracts and Conference Papers
  Conference Papers Index
  Scopus
- Grants and Federally Funded Research
  NIH RePORTER (a searchable database of federally funded biomedical research projects conducted at universities, hospitals, and other research institutions)
  HSRPROJ (a database providing access to ongoing grants and contracts in health services research)
- Other Miscellaneous Sources
  Hayes, Inc. Health Technology Assessment
  NY Academy of Medicine’s Grey Literature Index

In addition, the following websites were searched specifically for guidelines on depression treatment

http://www.guideline.gov/

http://guidance.nice.org.uk/

http://www.sign.ac.uk/

http://www.nhmrc.gov.au/publications/subjects/clinical.htm

http://www.nzgg.org.nz/

http://www.hc-sc.gc.ca/ahc-asc/legislation/guide-ld/index-eng.php