# Acknowledgments

The researchers at the McMaster Evidence-based Practice Center would like to acknowledge the following people for their contributions.

We are grateful to our Task Order Officers, Sonia Tyutyulkova for her support and guidance in developing this report, and Carmen Kelly for helping to finalize the project. Members of the Technical Expert Panel were instrumental in the formation of the parameters and goals of this review.

We would also like to thank those who worked so conscientiously—retrieving and screening citations, extracting data, preparing figures, and editing the report: Julianna Beckett, Bryan Cheeseman, Roxanne Cheeseman, Rashmi D’Mello, Henry Ebron, Mary Gauld, Suzanne Johansen, Sara Kaffashian, Dorothy Kendry, Jinhui Ma, Leah Macdonald, Wid Naima, Pam Ren, Rose Revelo, Maureen Rice, Catherine Salmon, Golnoush Taherzadeh, Leila Taherzadeh, and Leena Taji.