# Abbreviations

ACP: American College of Physicians
AHRQ: Agency for Healthcare Research and Quality
ASEX: Arizona Sexual Experience Scale
BDI: Beck Depression Inventory
CAM: complementary and alternative medicine
CANMAT: Canadian Network for Mood and Anxiety Treatments
CBT: cognitive behavioral therapy
CCT: controlled clinical trial
CDRS-R: Children’s Depression Rating Scale–Revised
CER: comparative effectiveness review
CGI: clinical global impressions
CPG: clinical practice guidelines
CYP 2D6: enzyme CYP 2D6
DBT: dialectical behavior therapy
DSHS: Department of State Health Services
DSM-IV: Diagnostic and Statistical Manual – 4^th^ edition
ECT: electroconvulsive therapy
FDA: U.S. Food and Drug Administration
GLAD-PC: Guidelines for Adolescent Depression in Primary Care
HAMD: Hamilton Depression Rating Scale
HAMD-17/21/31: 17 or 21 or 31 questions on the HAMD scale
HSRProj: Health Services Research Projects in Progress
IPT: interpersonal therapy
MADRS: Montgomery Asberg Depression Rating Scale
MDD: major depressive disorder
MDE: major depressive episode
mg/d: milligrams daily
NICE: National Institute of Clinical Excellence
PBO: placebo
PHQ-9: Patient Health Questionnaire 9 item
PICOT: Population, Intervention, Comparator, Outcome, Timeframe
QIDS-SR-16: Quick Inventory of Depressive Symptoms Self Report
QOL: quality of life
RCT: randomized controlled trial
rTMS: repetitive transcranial magnetic stimulation
SD: standard deviation
SNRI: Serotonin–norepinephrine reuptake inhibitors
SOE: strength of evidence
SSRI: selective serotonin reuptake inhibitors
STAR*D: Sequenced Treatment Alternatives to Relieve Depression
TADS: Treatment of Adolescents Study
TEP: technical expert panel
TORDIA: Treatment for Resistant Depression in Adolescents
UKU: Udvalg for Kliniske Undersøgelser (UKU) Side Effect Rating Scale
U.S.: United States
USPSTF: United States Preventive Services Task Force
VNS: vagal nerve stimulation
WHO: World Health Organization