# Results

From our primary database search for RCTs of treatments to prevent recurrent nephrolithiasis that reported clinical efficacy outcomes (Figure 2), we identified 1,141 references from MEDLINE^®^ and 2,770 references from Cochrane Central Register of Controlled Trials (CENTRAL), for a total of 3,004 unique references. Of these, we excluded 2,884 as ineligible during title and abstract review and 99 as ineligible during full-text review (Appendix B), leaving 21 that met eligibility criteria and were included. An additional seven references were identified by hand searching reference lists of included articles, systematic reviews, and clinical guidelines; all six met eligibility criteria and were included. Together, these sources generated 28 eligible RCTs of treatments to prevent recurrent nephrolithiasis (Figure 2).

Figure 2 Literature search flowchart

Figure 2. Literature search flowchart. This figure depicts the process by which articles were reviewed and compared against inclusion and exclusion criteria to create the list of 28 randomized controlled trials included in this review. Of 3,004 references identified during preliminary electronic database search, 2,884 were excluded after title and abstract review. The full text of the remaining 120 was reviewed and 99 additional references were excluded (most were not an RCT, or were not available in English), yielding 21 eligible trials. Handsearching yielded an additional 7 eligible trials.

We used Google Scholar to perform forward citation searching of key included RCTs and identified no additional published trials. We searched ClinicalTrials.gov for relevant registered and completed trials and identified 193 trials potentially meeting eligibility criteria. Of these, we excluded 179 as ineligible based on title review and nine as ineligible based on in-depth review. Of the five trials that appeared to meet study eligibility criteria, two were ongoing and had no results available (NCT01100580: increased fluid versus increased fluid plus low sodium; and NCT01349764: vitamin D supplementation versus control diet). We contacted authors of the three remaining, completed trials; one did not respond (NCT00004284: potassium citrate versus potassium phosphate), one reported that a final manuscript was under preparation (NCT00289120: cola versus control), and one informed us that final study results recently had been published (NCT01329042: potassium-sodium citrate versus no treatment). This article met eligibility criteria and was included. This brought the total number of eligible RCTs of treatments to prevent recurrent nephrolithiasis to 28, including eight dietary treatment studies and 20 pharmacological treatment studies. Twenty-six of the eligible RCTs were published in peer-reviewed English-language journals, while two were published as conference proceedings.40,50

To identify unpublished RCTs, we searched Web of Science for recent abstracts and conference proceedings, and we requested industry scientific information packets for relevant regulatory documents and reports of conducted trials. From Web of Science we identified 24 potentially relevant conference abstracts published since 2007. Of these, we excluded 17 as ineligible after title review and the rest after full abstract review. Our requests for industry scientific information packets to identify relevant regulatory documents and reports of conducted trials yielded no submissions.

From our supplemental MEDLINE^®^ search for additional RCTs and prospective cohort studies of pharmacological treatments to prevent recurrent nephrolithiasis that reported adverse events, we identified 703 references, of which 485 were not previously identified. Of these, we excluded 466 during title and abstract review and the rest during full text review.

## Key Question 1 In adults with a history of nephrolithiasis, do results of baseline stone composition and blood and urine chemistries predict the effectiveness of diet and/or pharmacological treatment on final health outcomes and intermediate stone outcomes, and reduce treatment adverse effects?

### Overview

The majority of trials reported mean baseline biochemistry values and/or prevalence of one or more biochemical abnormalities, most often based on 24-hour urine collections. Additional RCTs based participant eligibility on the presence or absence of such abnormalities. Though many trials did not specify how biochemical abnormalities were defined, especially for hyperoxaluria, definitions reported were roughly similar between studies. Almost no RCTs reported and compared subsequent stone recurrence outcomes between treatments in subgroups stratified by baseline biochemistry levels. In comparisons between studies, results were mixed regarding whether stone characteristics or baseline biochemical measures predicted the effectiveness of diet or pharmacological treatment relative to control in reducing risk of stone recurrence.

### Stone Composition

Dietary Therapy Trials. One dietary therapy RCT allowed entry of participants with all stone types.55 Otherwise, all were limited to individuals with calcium stones,42,46,51,53,54,56,57 most of which included only those with calcium oxalate stones.42,46,51,54,57 Consequently, we could not evaluate the effect of these dietary interventions in patients with other stone types.

Pharmacological Therapy Trials. All thiazide, allopurinol, and magnesium trials were limited to participants with calcium stones. Similarly, all AHA trials were performed in individuals with struvite stones, and all citrate trials but one that didn’t specify stone type and reported only change in stone size as an outcome63 were limited to participants with calcium stones. Consequently, we could not evaluate the effect of these interventions in patients with other stone types, including, notably, the effect of allopurinol in individuals with uric acid stones.

### Blood and Urine Chemistry

#### Hypercalciuria

Dietary Therapy Trials. Of five dietary trials that reported prevalence of hypercalciuria or based participant eligibility on the presence or absence of hypercalciuria,42,51,53,56,57 three defined it.51,57,75 Respectively, reported definitions were >300 mg/day,51 >300 mg/day in men or >250 mg/day in women,57 and >0.1 mmol/kg/day.56

In the one dietary RCT limited to individuals with hypercalciuria, participants randomized to normal to high calcium, low animal protein, and low sodium diet had a significant reduction in risk of composite stone recurrence versus those assigned a low calcium diet (20 vs. 38 percent, p=0.03).51 Adjustment for baseline characteristics, including urine calcium levels, did not significantly change these results.

In the one dietary RCT limited to participants without hypercalciuria, participants randomized to increased fluid intake had a significant reduction in risk of radiographically detected recurrent stones versus no treatment (8 vs. 56 percent, p<0.01),42 a result qualitatively similar to that reported from a single trial comparing increased fluid intake with no treatment in participants unselected with regard to hypercalciuria (12 vs. 27 percent composite stone recurrence, p=0.008).46 No trial evaluated any other dietary intervention in participants without hypercalciuria or in those who were unselected for hypercalciuria.

Pharmacological Therapy Trials. Of 12 pharmacological trials that reported prevalence of hypercalciuria or based participant eligibility on the presence or absence of hypercalciuria,37,41,43,45,47–50,52,58,59,64 eight defined it.37,41,45,47–49,52,64 Respectively, reported definitions were >300 mg/day (i.e., >7.5 mmol/day) in men and >250 mg/day (i.e., >6.2 mmol/day) in women,64≥300 mg/day in men and ≥250 mg/day in women or >4 mg/kg in either gender,37,47 >300 mg/day in men and >250 mg/day in women or >4 mg/kg or urine calcium/creatinine ratio >0.20 mg/dL in either gender,41 >300 mg/day,45 >6 mmol/day,49 >276 mg/day or >6 mmol/day,52 and >7.5 mmol/L/day in men and >6.25 mmol/L/day in women.48

In the one pharmacological RCT limited to individuals with hypercalciuria, participants randomized to thiazide had a significant reduction in risk of composite stone recurrence versus those assigned to control (RR, 0.33 [CI, 0.13 to 0.79]).41 This result did not differ significantly from those in trials of thiazide versus control that were not limited to participants with hypercalciuria (p=0.29 for interaction).47–50

Two pharmacological RCTs enrolled only individuals without hypercalciuria. The first such trial reported no significant reduction in risk of composite stone recurrence in participants randomized to allopurinol versus control (RR, 0.49 [CI, 0.19 to 1.23]).37 However, the estimate of effect did not differ significantly from that reported in a single study of allopurinol versus control in which participants with hypercalciuria were not excluded (RR, 0.61 [CI, 0.42 to 0.90])38(p=0.65 for interaction). The second trial limited to participants without hypercalciuria reported a significant reduction in composite recurrent stone risk in those randomized to citrate versus control (RR, 0.35 [CI, 0.16 to 0.75]),43 a result that did not differ significantly from results of two trials of citrate versus control that were not limited to participants without hypercalciuria (RR, 0.18 [CI, 0.07 to 0.44])44,45(p=0.27 for interaction).

Several trials reported results stratified by or adjusted for hypercalciuria status. One RCT reported no significant difference in risk of composite recurrent stone between participants randomized to thiazide alone versus thiazide plus citrate overall (32 vs. 30 percent, p>0.05), nor in the subgroup of individuals with hypercalciuria (7 vs. 19 percent, p=0.36).58 In a second trial, risk of composite stone recurrence in participants assigned thiazide and control, respectively, was 14 and 33 percent in the hypercalciuric subgroup (RR, 0.43 [CI, 0.10 to 1.81]) and 29 and 22 percent in the normocalciuric subgroup (RR, 1.29 [CI, 0.43 to 3.82])(p=0.23 for interaction between hypercalciuric and nonhypercalciuric subgroups).48 A third trial reported that the effect of thiazide versus control on time to composite stone recurrence and on number of patients with new stones did not significantly differ between patients who had baseline hypercalciuria versus those who had normocalciuria (p>0.25 for interaction between hypercalciuria and normocalciuria groups for both outcomes).49

#### Hyperoxaluria

Dietary Therapy Trials. Of four dietary trials that reported prevalence of hyperoxaluria or based participant eligibility on the presence or absence of hyperoxaluria,42,51,53,56 one defined hyperoxaluria (>500 micromol/day),51 but not the threshold for exclusion.51

We identified no dietary treatment RCTs limited to participants with hyperoxaluria. However, two dietary treatment RCTs were limited to individuals without hyperoxaluria. The first trial reported no risk difference for composite recurrent stones between participants randomized to high fiber versus low animal protein versus a control diet.56 No trial evaluated comparable interventions in participants not selected for the absence of hyperoxaluria. The second trial limited to individuals without hyperoxaluria reported a significant reduction in risk of radiographically detected recurrent stones in participants randomized to increased fluid intake versus no treatment (8 vs. 56 percent, p<0.01),42 a result qualitatively similar to that reported from a single trial that compared increased fluid intake versus no treatment in participants unselected with regard to hyperoxaluria (12 vs. 27 percent composite stone recurrence, p=0.008).46

In addition, one dietary treatment RCT adjusted results for baseline urine oxalate. In this study, participants randomized to a low animal protein, low sodium, and normal to high calcium diet were significantly less likely to have a recurrent composite stone outcome versus those assigned to a low calcium diet (20 vs. 38 percent, p=0.03). These results did not change significantly after adjustment for baseline characteristics, including urine oxalate.51 No trials reported results stratified by baseline urine oxalate level.

Pharmacological Therapy Trials. Of four pharmacological trials that reported prevalence of hyperoxaluria or based participant eligibility on the presence or absence of hyperoxaluria,43,52,58,64 two defined it.52,64 Respectively, reported definitions were >40 mg/day,64 and >46 mg/day or >0.48 mmol/L.52

In one pharmacological treatment RCT limited to participants with hyperoxaluria that also was just one year in duration, risk of symptomatic stone recurrence did not differ between the thiazide and control groups (RR, 1.04 [CI, 0.39 to 2.80]).52 By comparison, risk of composite stone recurrence was significantly reduced in individuals randomized to thiazide versus control in two longer trials that excluded participants with hyperoxaluria (RR, 0.48 [CI, 0.24 to 0.94]).47,50 We identified no additional pharmacological treatment RCTs limited to participants without hyperoxaluria.

In addition, one pharmacological treatment RCT adjusted results for baseline urine oxalate. This study reported a significant reduction in risk of composite stone recurrence in participants assigned to citrate versus control. Results were not significantly changed after adjustment for possible confounders including hyperoxaluria.44 No trials reported results stratified by baseline urine oxalate level.

#### Hyperuricosuria and/or Hyperuricemia

Dietary Therapy Trials. Of two dietary trials that reported prevalence of hyperuricosuria or hyperuricemia, or based participant eligibility on the presence or absence of hyperuricosuria or hyperuricemia,42,53 neither reported thresholds that defined abnormality.

We identified no dietary RCTs limited to participants with or without baseline hyperuricosuria or hyperuricemia, or that reported results adjusted for or stratified by baseline urine or blood uric acid level.

Pharmacological Therapy Trials. Of nine pharmacological trials that reported prevalence of hyperuricosuria or hyperuricemia, or based participant eligibility on the presence or absence of hyperuricosuria or hyperuricemia,37,38,43,45,47,49,52,58,64 seven reported thresholds that defined abnormality,37,38,45,47,49,52,64 Respectively, reported definitions of hyperuricosuria were ≥600 mg/day,45,64 >763 mg/day,52 >800 mg/day in men and >750 mg/day in women,37,47 and >3.5 mmol/day.49 Hyperuricemia was defined in one trial as >6 mg/dL38 and in one trial as >6.48 mg/dL.52

Two pharmacological RCTs were limited to individuals with either baseline hyperuricosuria37 or hyperuricemia.38 Both of these trials enrolled only participants with calcium stones and compared allopurinol versus control. In pooled results, those randomized to allopurinol had a significantly reduced risk of recurrent composite stones versus control (33.3 vs. 55.4 percent; RR, 0.59 [CI, 0.42 to 0.84]). In participants with baseline hyperuricosuria, time to first composite stone recurrence was significantly greater in those assigned to allopurinol versus control (33.3 vs. 27.4 months, p<0.05), while absolute rate of composite stone recurrence was 0.12 versus 0.26 stones per patient year in the allopurinol and control groups, respectively.37

By comparison, in participants unselected for urine or serum uric acid levels and randomized to allopurinol versus control, we identified no pharmacological trials that reported a composite recurrent stone outcome. However, in two trials reporting, rate of symptomatic stone recurrence in the allopurinol and control groups, respectively, was 0.54 versus 0.58,^39^ and 0.96 versus 0.66 stones per patient year.40

No pharmacological trials reported results stratified by baseline urine or blood uric acid level.

#### Hypocitraturia

Dietary Therapy Trials. The only dietary trial that reported prevalence of hypocitraturia or based participant eligibility on the presence or absence of hypocitraturia did not define it.53

We identified no dietary RCTs limited to participants with or without baseline hypocitraturia, or that reported results adjusted for or stratified by baseline urine citrate level.

Pharmacological Therapy Trials. Of six pharmacological trials that reported prevalence of hypocitraturia or based participant eligibility on the presence or absence of hypocitraturia,43,45,52,58,59,64 four defined it.43,45,52,64 Respectively, reported definitions were <273 mg/day,52 <320 mg/day,45,64 and <3.4 mmol/day.43

One pharmacological RCT was comprised entirely of participants with hypocitraturia, and those randomized to citrate versus control were significantly less likely to experience a composite stone recurrence outcome (RR, 0.35 [CI, 0.16 to 0.75]).43 These results did not differ significantly from results in pharmacological trials of citrate versus control that were not restricted to participants with hypocitraturia (p=0.27 for interaction).44,45 In addition, one pharmacological RCT that included a mix of hypocitraturic and normocitraturic participants and compared citrate versus control (overall RR, 0.20 [CI, 0.08 to 0.52]) reported that citrate’s benefit on stone recurrence was not limited to the fewer than 20 percent of study participants with hypocitraturia; however, numerical stratified results were not reported.44

#### Other Biochemical Measures

Dietary Therapy Trials. One dietary treatment trial reported a significantly lower risk of composite stone recurrence in participants randomized to a low animal protein, low sodium, and normal to high calcium diet versus a low calcium diet (20 vs. 38 percent, p=0.03). Results were not significantly changed by adjustment for baseline characteristics, including urine volume, sodium, and calcium-oxalate product.51 Otherwise, we identified no dietary RCT data addressing whether the effect of treatment on risk of recurrent stones differed according to baseline level of urine sodium, magnesium, phosphate, potassium, volume, pH, calcium-oxalate product, calcium-oxalate supersaturation, calcium-phosphate supersaturation, or uric acid supersaturation. No trials consisted entirely of participants with abnormal levels of any of these measures or reported results for stone recurrence stratified by any of these measures.

Pharmacological Therapy Trials. One pharmacological treatment trial reported a significant reduction in risk of composite stone recurrence in participants assigned to citrate versus control. The results were not significantly changed after adjustment for possible confounders including urine volume.44 Otherwise, we identified no pharmacological RCT data addressing whether the effect of treatment on risk of recurrent stones differed according to baseline level of urine sodium, magnesium, phosphate, potassium, volume, pH, calcium-oxalate product, calcium-oxalate supersaturation, calcium-phosphate supersaturation, or uric acid supersaturation. In no trials were all participants defined as having abnormal levels of any of these measures, and no trials reported results for stone recurrence stratified by any of these measures.

In one additional RCT, participants were randomized to an extensive biochemical evaluation and diet treatment tailored to address any biochemical abnormalities identified versus a limited biochemical evaluation and empiric diet treatment.53 However, the study did not report results comparing outcomes for different diets within any biochemical subgroup.

## Key Question 2 In adults with a history of nephrolithiasis, what is the effectiveness and comparative effectiveness of different dietary therapies on final health outcomes and intermediate stone outcomes?

### Overview

We found low strength of evidence (Table 1) that increased fluid intake to maintain urine output of >2 to 2.5 L/day significantly reduces risk of recurrent stones compared with a control diet. We found low strength of evidence that advice to reduce soft drink intake significantly reduces risk of recurrent stones compared with no treatment in men with high baseline soft drink consumption. We found low strength of evidence that decreased animal protein or increased fiber intake do not reduce risk of recurrent stones. We found low strength of evidence that an extensive biochemical evaluation followed by tailored diet treatment reduces risk of recurrent stones compared with a limited evaluation and empiric diet treatment. We found low strength of evidence that a multicomponent diet including normal to high calcium, low protein, and low sodium reduced risk of recurrent stones compared with a low calcium diet, but also low strength of evidence that a multi-component diet with low animal protein, high fruit, vegetables, and whole grains, increased bran and low purine increased risk of recurrent stones versus a control diet. We found no evidence regarding whether diets including increased calcium, low sodium, low oxalate, or low purine as isolated diet changes reduce risk of recurrent kidney stones. Results were based on trials conducted predominately in young to middle-aged men. Half of trials were performed in patients with only a single past calcium stone episode, including both trials of increased fluid intake versus no treatment, while the other half of trials included or were limited to participants with recurrent calcium stones. Nearly all studies relied on a composite definition of recurrent stone outcomes that included either symptomatic or radiographic recurrence. Few studies reported adherence. With the exception of one trial in which participants were recruited from primary care settings,57 study subjects appeared to have been recruited from urology or nephrology clinics or specialty stone centers.

Table 1 Strength of evidence for prevention of stone recurrence: Diet intervention trials

Intervention | Stone Recurrence Type | Number of Trials | Number of Randomized Subjects | Summary Statistics RR [95% CI] | Risk of Bias^*^ | Directness^**^ | Precision^†^ | Consistency^‡^ | Evidence Rating^††^
Increased fluid intake vs. control | Symptomatic | 0 | - | - | - | - | - | - | Insufficient
Increased fluid intake vs. control | Composite | 1 | 220 | 0.45 [0.24 to 0.84] | medium | direct | precise | NA | Low
Increased fluid intake vs. control | Radiographic | 1 | 21 | 0.15 [0.02 to 1.07] | medium | direct | imprecise | NA | Insufficient
Increased oligomineral water intake vs. increased tap water intake | Symptomatic | 0 | - | - | - | - | - | - | Insufficient
Increased oligomineral water intake vs. increased tap water intake | Composite | 0 | - | - | - | - | - | - | Insufficient
Increased oligomineral water intake vs. increased tap water intake | Radiographic | 1 | 384 | 0.73 [0.48 to 1.09] | medium | direct | imprecise | NA | Low
Reduced soft drink intake vs. control | Symptomatic | 1 | 1009 | 0.83 [0.71 to 0.98] | medium | direct | precise | NA | Low
Reduced soft drink intake vs. control | Composite | 0 | - | - | - | - | - | - | Insufficient
Reduced soft drink intake vs. control | Radiographic | 0 | - | - | - | - | - | - | Insufficient
Decreased animal protein intake vs. control | Symptomatic | 0 | - | - | - | - | - | - | Insufficient
Decreased animal protein intake vs. control | Composite | 1 | 115 | 1.00 [0.52 to 1.91] | medium | direct | imprecise | NA | Low
Decreased animal protein intake vs. control | Radiographic | 0 | - | - | - | - | - | - | Insufficient
Increased dietary fiber intake vs. control | Symptomatic | 0 | - | - | - | - | - | - | Insufficient
Increased dietary fiber intake vs. control | Composite | 1 | 120 | 1.18 [0.66 to 2.12] | medium | direct | imprecise | NA | Low
Increased dietary fiber intake vs. control | Radiographic | 0 | - | - | - | - | - | - | Insufficient
Multi-component diet (Borghi 2002)^‡‡^ vs. control | Symptomatic | 0 | - | - | - | - | - | - | Insufficient
Multi-component diet (Borghi 2002)^‡‡^ vs. control | Composite | 1 | 120 | 0.52 [0.29 to 0.95] | medium | direct | precise | NA | Low
Multi-component diet (Borghi 2002)^‡‡^ vs. control | Radiographic | 0 | - | - | - | - | - | - | Insufficient
Multi-component diet (Hiatt 1996) § vs. control | Symptomatic | 0 | - | - | - | - | - | - | Insufficient
Multi-component diet (Hiatt 1996) § vs. control | Composite | 1 | 99 | 5.88 [1.39 to 24.92] | medium | direct | precise | NA | Low
Multi-component diet (Hiatt 1996) § vs. control | Radiographic | 0 | - | - | - | - | - | - | Insufficient
Tailored diet^§§^ vs. empiric diet | Symptomatic | 0 | - | - | - | - | - | - | Insufficient
Tailored diet^§§^ vs. empiric diet | Composite | 1 | 242 | 0.32 [0.14 to 0.74] | medium | direct | precise | NA | Low
Tailored diet^§§^ vs. empiric diet | Radiographic | 0 | - | - | - | - | - | - | Insufficient

Abbreviations: CI = confidence intervals; NA = not applicable; RR = relative risk

* Risk of bias rated low, medium, or high based on whether the design and conduct of the studies for a given treatment comparison and outcome indicate good internal validity.

** Directness indicated whether results reflect a single, direct link between the intervention of interest and the outcome and was rated as either direct or indirect.

† Precision indicated the degree of certainty surrounding an effect estimate of a given outcome and was rated either precise or imprecise, with a precise estimate being one that allowed a clinically meaningful conclusion.

‡ Consistency indicated whether the included studies found a similar direction of effect and was rated consistent, inconsistent, or, in cases when only a single study was evaluated, unknown/not applicable.

†† Evidence was rated using the following grades: 1) high confidence indicated that further research is very unlikely to change the confidence in the estimate of effect, meaning that the evidence reflects the true effect; 2) moderate confidence denoted that further research may change our confidence in the estimate of effect and may change the estimate; 3) low confidence indicated that further research is very likely to have an important impact on the confidence in the estimate of effect and is likely to change the estimate, meaning there is low confidence that the evidence reflects the true effect; and 4) insufficient, indicating that the evidence was unavailable or did not permit a conclusion. Examples when evidence is available, but SOE may be graded as insufficient include when there is an unacceptably high risk of bias, or there is a major inconsistency that cannot be explained (e.g., 2 studies with the same risk of bias with opposite results and no clear explanation for the discrepancy). In addition, SOE may be graded as insufficient when data are too imprecise. This may be the case when the 95% CI is so wide that it cannot exclude either a clinically significant benefit or harm (e.g. lower CI bound 〈0.5 and upper CI bound >2).

‡‡ Borghi 2002 multicomponent diet (high calcium, low protein and low sodium intake) versus control diet (low calcium intake)

§ Hiatt 1996 multicomponent diet (low animal protein and high fiber intake) versus control diet

§§ Extensive laboratory evaluation followed by diet tailored to laboratory results versus limited laboratory evaluation followed by empiric diet (moderate intake of animal protein, sodium, and calcium; increased fiber; restricted oxalate)

### Study Characteristics

#### Study Design

Eight trials of dietary interventions met eligibility criteria (n=2294 participants, range 45 to 1009)42,46,51,53–57 (Appendix C, Table 1; Appendix F, Table 1). All trials were published in peer-reviewed English-language journals. All trials indicated that they were randomized, although only two reported an adequate method of random allocation.51,56 All trials used a parallel treatment group design. Treatment duration ranged from 19 to 60 months.

#### Treatment Groups

Among eligible trials, three compared treatment groups with regard to quantity or type of fluid intake (Appendix C, Table 1). One randomized participants to increase water intake to achieve >2 L/day urine volume versus no treatment (n=220) for 5 years,46 one randomized participants to increase fluid intake to achieve > 2.5 L/day urine volume versus no treatment (n=45) for 2 to 3 years,42 and a third randomized participants to consume 2 L/day water, as oligo-mineral water (15 mg/L calcium content) versus tap water (55 to 130 mg/L calcium content) (n=384).54 A fourth trial randomized men with baseline soft drink consumption > 160 mL/day to advice to refrain from drinking soft drinks versus no treatment (n=1009).55

Four eligible trials evaluated the efficacy of multicomponent dietary interventions versus control diets. The first trial randomized 99 participants to a diet with low animal protein (56–64 gm/day), high fruit, vegetables, and whole grains, increased bran (1/4 cup/day), and low purine (75 mg/day) versus a control diet for 2 years. Both groups were advised to consume two dairy servings (or calcium carbonate supplements) and six to eight glasses of liquid daily.57 In the second trial, 242 participants were randomized to a limited biochemical evaluation with general diet recommendations versus an extensive biochemical evaluation and diet tailored to identified abnormalities.53 Among participants who underwent the extensive evaluation, those identified with hypercalciuria were assigned restricted animal protein and 750 to 1000 mg/day of dietary calcium; those identified with hyperuricosuria or hyperuricemia were assigned a low-purine diet and restricted to 80 gm/day of meat products with one to two meatless days per week; those identified with hyperoxaluria were assigned restricted oxalate intake, regular dairy intake, lemons, and increased fiber intake; those identified with magnesium deficiency were assigned increased fiber, regular dairy intake, and high magnesium mineral water; and those identified with hypocitraturia were assigned restricted animal protein, one to two servings of lemons or orange juice per day, and increased fruit and vegetables. For the control group, the general diet recommendations included 750 to 1000 mg/day of calcium, 100 to 120 gm/day of animal protein, oxalate restriction, increased fiber intake, and “moderate” sodium intake. In a third trial, 120 men were randomized to normal to high dietary calcium (1200 mg/day), low animal protein (52 gm/day), and low sodium (50 mmol/day) versus a control diet including low calcium (400 mg/day) for 5 years. Both groups were advised to drink 2 to 3 liters of water per day and decrease oxalate intake.51 Last, in the fourth trial, 175 participants were randomized to a low protein diet (≤ 3 meat or fish servings per week and ≤ 100 g/day of milk products) versus high fiber diet (increase baseline fiber consumption 25 g/day by increasing fruit, fiber, and whole grain intake) versus no treatment.56

#### Outcome Measures

All trials presented results in terms of the proportion with any stone recurrence, including one that reported symptomatic stone recurrence,55 two that reported radiographic recurrence,42,54 and five that reported a composite recurrence outcome defined by either symptomatic stone passage or radiographic detection.46,51,53,56,57 In addition, one trial reported time to stone recurrence,46 and another reported rate of recurrent stones per patient year of followup.57 Last, one trial reported results for change in stone size, but did not report results separately by treatment group.56

### Participant Characteristics

#### Demographics

Trial participants were predominately young (mean 42 years, range 32 to 45; 7 trials reporting) and male (80.9 percent) (Appendix C, Table 1). Two trials were restricted to males.51,55 In the single trial that reported data on race, 77 percent of participants were Caucasian.57 Six trials were conducted in Europe and two in the United States.55,57 In nearly all trials, participants appeared to have been recruited from within a specialty stone center,46,51,54 urology clinic,53,55 or nephrology clinic.56 By contrast, in one trial members of the Kaiser Permanente Medical Care Program with a history of a single calcium oxalate stone were recruited from their primary clinics.57 One trial reported no participant recruitment source, but all had recently undergone shockwave lithotripsy and the authors were affiliated with the Department of Urology. Thus, it is likely that these individuals were recruited from a urology clinic setting.42

#### Medical History

Four trials reported baseline body mass index (BMI) or weight, with mean BMI 24.5 kg/m^2^ 56,57 and mean weight 71.5 kg46,51,56 (Appendix C, Table 1; Appendix F, Table 1). Two trials reported baseline renal function,51,56 with mean serum creatinine of 1.0 mg/dL and respective mean creatinine clearances of 88 mL/min/1.73m^2^ and 126 mL/min. One trial reported that no participants had urinary tract anatomic abnormalities.51 No eligible trials reported prevalence of diabetes, although one study excluded participants with undefined severe diabetes.54 No eligible trials reported prevalence of previous bariatric surgery, chronic kidney disease, solitary kidney, renal transplant, coronary artery disease, hypertension, or pregnancy. All but one trial excluded participants with conditions known to be associated with calcium nephrolithiasis.55

#### Stone History

Seven trials limited enrollment to participants with calcium stones, of which three were further restricted to those with pure calcium oxalate stones,42,46,51 while four allowed mixed calcium oxalate and calcium phosphate stones53,54,56,57 (Appendix C, Table 1). One trial included individuals with any stone type.55 Four trials included only participants with a single past stone episode;42,46,53,57 two trials included only participants with multiple past stone episodes;51,54 and two trials included both groups.55,56

Three trials included only participants who were stone free at baseline, based, respectively, on abdominal radiography alone,57 combined abdominal radiography and ultrasound,54 or combined ultrasound and excretory urography.46 In three trials that allowed entry of participants with residual stone fragments, 21 to 53 percent of participants had baseline stone fragments. Two of these studies determined presence of stone fragments based on combined abdominal radiography and ultrasound51,53 and one based on combined abdominal radiography, ultrasound and renal tomography.42 Two trials reported no data regarding the presence of residual stone fragments at baseline.55,56 Two trials included only participants previously treated with extracorporeal shock wave lithotripsy, with one requiring that all participants be stone free at baseline54 and the other reporting results in a subgroup that was stone free at baseline.42

#### Baseline Biochemistry

Among eight eligible diet studies, seven reported at least some baseline serum and/or urine biochemistry results42,46,51,53,54,56,57 (Appendix H, Table 1). All urine biochemistries were based on 24-hour urine collections.

Five trials reported the proportion of participants with hypercalciuria, including 0 percent,42 18 percent,57 38 percent,56 100 percent,51 and, finally, one trial in which 67 percent of participants in the multicomponent diet intervention group had hypercalciuria, but that reported no data for the control group.53 Two trials had no participants with hyperoxaluria,42,56 one trial included 18 percent of participants with mild hyperoxaluria,51 and a fourth trial reported that 18 percent of the multicomponent diet intervention group had hyperoxaluria.53 One trial had no participants with hyperuricosuria,42 while a second reported that 27 percent of the multicomponent diet intervention group had hyperuricosuria.53 Hypocitraturia (19 percent), hypomagnesuria (9 percent), hyperuricemia (10 percent), and hypomagnesemia (12 percent) each were reported only within the multicomponent diet intervention group from within a single trial that reported no data on the prevalence of these biochemical abnormalities in the control group.53

Six trials reported mean baseline values for at least some urine biochemistry measures (Appendix H, Table 1),46,51,53,54,56,57 though one trial reported these results only for the multicomponent dietary intervention group and not for the control group.53 All six trials reported urine calcium with a mean of 278 mg/24 hrs (range 204 to 451); other frequently reported baseline urine biochemistry results included mean oxalate 31 mg/24 hrs (range 29 to 41, n=5 trials), mean uric acid 596 mg/24 hrs (range 566 to 736, n=4 trials), mean sodium 4133 mg/24 hrs (range 3653 to 5379, n=4 trials), and mean citrate 565 mg/24 hrs (range 521 to 603, n=3 trials). Only one trial reported calcium-oxalate product,51 and two trials reported calcium-oxalate supersaturation.46,51 Five trials reported baseline urine volume, with a mean of 1.6 liters/24 hrs (range 1.0 to 2.4).46,51,53,54,56

### Study Quality

Among the eight eligible trials, one was rated good quality, five were rated fair quality, and two were rated poor quality (Appendix C, Table 7). Allocation concealment was adequate in two studies51,56 and unclear in the rest. Four of the eight trials masked outcome assessors to participant treatment assignment.51,55–57 Four trials performed intention to treat analysis.42,51,55,57 Six of the eight trials adequately reported withdrawals,42,51,54–57 which ranged from 0 to 58.3 percent.

#### Efficacy Outcomes Increased Fluid Intake Versus No Treatment

Stone Recurrence. Neither of two trials reported results for symptomatic stone recurrence; thus evidence is insufficient to directly address the effect of increased fluid intake on this outcome. In the single trial that reported composite stone recurrence, participants randomized to increased fluid intake to achieve urine volume > 2 L/day compared with no treatment were significantly less likely to experience stone recurrence (12.1 vs. 27.0 percent; RR, 0.45 [CI, 0.24 to 0.84])46 (Figure 3; Appendix D, Table 1). Consistent with these results, mean time to first recurrence was greater in the increased fluid group compared with no intervention (38.7 vs. 25.1 months, p=0.016) (Appendix E, Table 1a). In the single trial that reported radiographic stone recurrence, participants who were stone free after shockwave lithotripsy were randomized to increased fluid intake to achieve urine volume > 2.5 L/day versus no treatment. Eight percent of the increased fluid group experienced stone recurrence versus 55.6 percent of the no-treatment group (RR, 0.15 [CI, 0.02 to 1.07])42 (Figure 3). Although the magnitude of benefit appeared large, this result was not statistically significant, possibly because of the small sample size. Nevertheless, because of the wide confidence intervals we are unable to conclude if increased fluid intake reduces radiographic stone recurrence.

Figure 3 Risk of stone recurrence, increased fluid intake versus no treatment

Figure 3. Risk of stone recurrence, increased fluid intake versus no treatment. This figure depicts the risk of stone recurrence in patients assigned to increased fluid intake versus no treatment. One large study of 199 patients by Borghi 1996 found increased fluid significantly decreased risk of composite recurrence (assessed by either symptoms or radiographically such as X-ray) by 55% compared with no treatment (Risk ratio was 0.45 [95 % CI 0.24 to 0.84]). Incidence of recurrence was 12% for the increased fluid intake group versus 27% for no treatment. One small study of 21 patients by Sarica 1996 found increased fluid decreased risk of radiographic recurrence versus no treatment but the reduction was not statistically significant (Risk ratio was 0.15 [95% CI 0.02 to 1.07]). Incidence of recurrence was 8 % for the increased fluid intake group versus 56% for no treatment.

Other Clinical Outcomes. Neither of the two trials reported results for any other clinical health outcomes, including pain, urinary tract obstruction with acute renal failure, infection, procedure related morbidity, emergency room treatment or hospitalization related to stone recurrence, quality of life, or end-stage renal disease (Appendix E, Tables 1b–c).

Subgroup Results. Neither of the two trials reported efficacy outcomes within subgroups defined by demographic or comorbid characteristics or according to characteristics of stone history.

Adherence to Assigned Treatment. One of the two trials reported only that compliance was “good in the majority of the patients” assigned increased fluid intake, but provided no information regarding how compliance was defined.42 Further, it did not report any data regarding the percentage of participants assigned increased fluid intake who maintained the goal level of daily urine output or their mean daily urine volume. In the second trial, participants assigned increased fluid intake had a mean urine volume of 1.1 L/day at baseline, 2.1 L/day at 1 year, 2.3 L/day at 2 years, and >2.5 L/day at the 3 through 5 year followup points.46 By comparison, mean urine volume in the control group was 1.0 L/day at baseline, peaked at 1.3 L/day at 1 year, and otherwise remained similar to baseline at each followup point through 5 years. Followup urine volumes were available only in participants who had not withdrawn from the study.

#### Increased Oligomineral Water Intake Versus Increased Tap Water Intake

Stone Recurrence. In a single trial, all participants were assigned to drink >2 L of water per day, but were randomized to oligomineral water with 15 mg/L calcium versus tap water with 55 to 130 mg/L calcium content.54 Stone recurrence was defined based on radiographic detection only. Seventeen percent of those randomized to oligomineral water had stone recurrence versus 22.9 percent of those allocated to tap water (RR, 0.73 [CI, 0.48 to 1.09]) (Appendix D, Table 1).

Other Clinical Outcomes. This trial did not report results for any other clinical health outcomes (Appendix E, Tables 1b–c).

Subgroup Results. This trial did not report efficacy outcomes within subgroups defined by demographic or comorbid characteristics or according to characteristics of stone history.

Adherence to Assigned Treatment. This trial reported no adherence data.

#### Decreased Soft Drink Intake

Stone Recurrence. One trial, conducted in stone-forming participants with baseline soft drink consumption >160 ml per day, reported a 7 percent absolute reduction in self-reported, physician-confirmed renal colic episodes (i.e., symptomatic recurrence) in those randomized to advice to abstain from soft drink intake versus no intervention for 3 years (33.7 vs. 40.6 percent; RR, 0.83 [CI, 0.71 to 0.98])55 (Appendix D, Table 1). Total fluid intake was similar in both groups.

No data were reported for radiographic stone recurrence, a composite stone recurrence outcome, stone recurrence rate, change in stone size, or residual or stone fragment clearance (Appendix D, Table 1; Appendix E, Table 1a).

Other Clinical Outcomes. This trial reported no other clinical health outcomes (Appendix E, Tables 1b–c).

Subgroup Results. This trial reported that benefit appeared restricted to participants for whom the soft drink most frequently consumed at baseline was acidified solely by phosphoric acid (29.7 percent vs. 45.6 percent; RR, 0.65 [CI, 0.49 to 0.87], p=0.02 for interaction between baseline soft drink acidification types). The study reported no results within subgroups defined by baseline fructose consumption, demographic or comorbid characteristics, or according to characteristics of stone history.

Adherence to Assigned Treatment. The study determined that 43.1 percent of participants assigned to the low soft drink intake group were compliant at 6 months. Compliance was defined as self-report of drinking fewer than three 8-ounce glasses of soda (< 680 ml) per week during the most recent 6-month followup period. Reported compliance appeared constant over 3 years, though results were based only on participants who had not withdrawn from the study.

#### Multicomponent Dietary Interventions

Stone Recurrence. Three trials examined a multicomponent dietary intervention versus a control diet and reported conflicting results (Appendix D, Table 1; Appendix E, Table 1a).

In one trial that randomized participants to a low animal protein, high fiber, increased bran, and low purine diet versus a control diet for 2 years, and in which both groups were advised to increase fluid intake and consume regular dairy or supplemental calcium, 24.0 percent of participants randomized to the multicomponent diet had a composite stone recurrence versus 4.1 percent of those allocated to the control diet (p=0.004).57 Participants allocated to the multicomponent diet group also had a higher composite stone recurrence rate (7.1 vs. 1.2 per 100 person-years, p=0.06). The study reported neither radiographic nor symptomatic stone recurrence as isolated outcomes, nor results for stone fragment clearance or change in stone size.

In a second trial that randomized participants to a limited biochemical evaluation with general (empiric) diet recommendations versus an extensive metabolic evaluation and diet recommendations tailored to the findings of the biochemical evaluation, fewer participants randomized to the extensive evaluation and tailored diet had a composite stone recurrence (6.2 vs. 19.1 percent; RR, 0.32 [CI, 0.14 to 0.74]).53 The study reported no separate results for any biochemical abnormality subgroup or tailored diet type. The study also did not report radiographic or symptomatic stone recurrence as isolated outcomes, nor results for stone recurrence rate, stone fragment clearance, or change in stone size.

In a third trial that randomized participants to a diet including normal to high calcium, low animal protein, and low sodium versus a low calcium diet for 5 years, and in which both groups were advised to increase fluid and decrease oxalate intake, 20.0 percent of participants randomized to the multicomponent diet had a composite stone recurrence versus 38.3 percent of those allocated to the low calcium control diet (RR, 0.52 [CI, 0.29 to 0.95]).51 The study reported neither radiographic nor symptomatic stone recurrence as isolated outcomes and no results for stone recurrence rate, stone fragment clearance, or change in stone size.

Other Clinical Outcomes. None of the multicomponent diet intervention trials reported results for any other clinical health outcomes (Appendix E, Tables 1b–c).

Subgroups. In one trial,51 participants assigned a normal to high calcium, low animal protein, and low sodium diet versus a low calcium diet had a relative risk of stone recurrence of 0.81 (CI, 0.28 to 2.35) and 0.23 (CI, 0.08 to 0.67) in high-risk and low-risk subgroups, respectively (p=0.09 for comparison between risk subgroups). The study defined high-risk participants as those with five or more colic episodes in the year before randomization, 10 or more stones before randomization, or both, and all other study participants as low risk. Another trial that randomized participants to a low animal protein, high fiber, increased bran, and low purine diet versus a control diet reported a nonsignificantly greater rate of recurrent stones in a subgroup with lower mean protein intake (p=0.24 versus an unspecified comparison group).57

Adherence to Assigned Treatment. One of the three trials reported no information on adherence to assigned diet treatment.53 In a second trial, participants allocated to the multicomponent dietary intervention group (low animal protein, low purine, high fiber, increased fluid intake) reported significantly lower mean intake of dietary protein and purine at 6 months compared with those assigned increased fluid intake only.57 The relative reduction in protein intake appeared attenuated with further followup. Treatment groups did not differ in mean fiber intake at any point except 42 months, by which time analyses were based on only 61 percent of originally randomized subjects. The study did not report the number of participants who met recommended goals for protein, purine, fiber, and fluid intake. The third trial reported that three participants assigned to the multicomponent dietary intervention group withdrew because they didn’t want to continue the diet.51 The study further reported no difference in dietary compliance between treatment groups, though it neither defined compliance nor reported compliance data.

#### High Fiber Intake

Stone Recurrence. Only one trial compared a high fiber diet (increase baseline fiber consumption 25 g/day by increasing fruit, fiber, and whole grain intake) independent of other dietary interventions with a control diet.56 All study participants were advised to increase their water intake to > 2 L/day and to consume between 800–1000 mg/day of dietary calcium. As defined by a composite stone recurrence outcome, 63.0 percent of those randomized to high fiber intake had recurrent stones versus 47.8 percent of controls (RR, 1.18 [CI, 0.66 to 2.12]) (Appendix D, Table 1). The study reported neither radiographic nor symptomatic stone recurrence as isolated outcomes, nor results for stone recurrence rate or stone fragment clearance. Change in stone size was reported in three participants who had an asymptomatic increase of >50 percent, but authors did not report to which treatment group these participants were randomized (Appendix E, Table 1a).

Two additional trials assigned participants to high fiber as part of a multicomponent diet intervention versus a control diet.53,57 Results for these studies were mixed, with the group assigned the multicomponent diet intervention containing high fiber experiencing a lower risk of recurrent stones in one trial53 and a higher risk in one trial.57

Other Clinical Outcomes. None of the trials examining high fiber intake reported results for any other clinical health outcomes (Appendix E, Tables 1b–c).

Subgroups. None of the trials examining high fiber intake reported efficacy outcomes within subgroups defined by demographic or comorbid characteristics or according to characteristics of stone history.

Adherence to Assigned Treatment. Among participants randomized to a high fiber diet, 23.3 percent withdrew from the study during followup because of the assigned diet. By comparison, 15 percent of participants randomized to the control diet withdrew because of the assigned diet (p=0.25 between treatment groups). In addition, the study dietician assessed adherence every 4 months via participant phone interviews, during which the dietician also reinforced assigned dietary recommendations. Among participants assigned a high-fiber diet, mean fiber intake increased from 17 g/day at baseline to a peak of 27 g/day at 1 year (p<0.01 vs. baseline) and 23 g/day at 4 years (p<0.01 vs. baseline). By comparison, mean fiber intake in the control diet group was 17 g/day at baseline and did not change during followup. These results appeared to be derived from only those participants who had not withdrawn from the study.

#### Low Animal Protein Intake

Stone Recurrence. Only one trial compared a low animal protein diet (≤ 3 meat or fish servings per week and ≤ 100 g/day of milk products) independent of other dietary interventions with a control diet.56 All study participants were advised to increase their water intake to > 2 L/day and to consume between 800–1000 mg/day of dietary calcium. Results did not differ between treatment groups in risk of composite recurrent stones, at 47.8 percent in both (RR, 1.00 [CI, 0.52 to 1.91]) (Appendix D, Table 1).

Three additional trials assigned participants to low animal protein as part of a multicomponent diet intervention versus a control diet.51,53,57 Results for these studies were mixed, with the diet intervention group experiencing a lower risk of recurrent stones in two trials51,53 and a higher risk in one trial57 (Appendix D, Table 1).

Other Clinical Outcomes. No trial that evaluated low animal protein as an independent dietary intervention or as part of a multicomponent dietary intervention reported on other clinical health outcomes (Appendix E, Tables 1b–c).

Subgroups. Neither the trial that evaluated a low animal protein diet independent of other dietary interventions56 nor the trials that included low animal protein as part of a multicomponent dietary intervention reported efficacy outcomes within subgroups defined by demographic or comorbid characteristics or according to characteristics of stone history. In one trial,56 a subgroup of eight patients highly compliant with the low animal protein diet (decreased contribution of protein to total energy below 13 percent and significant decrease in 24-hour urea excretion) showed no difference in stone recurrence compared with the control group.

Adherence to Assigned Treatment. Of those assigned to low animal protein, 29.1 percent withdrew from the study during followup due to the diet. By comparison, 15 percent of participants randomized to the control diet withdrew due to the diet (p=0.07 between groups). In addition, based on phone interviews during which the study dietician assessed and encouraged adherence, participants assigned to low animal protein decreased mean total protein intake from 84 g/day at baseline (57 g/day animal protein) to 68 g/day at 1 year (38 g/day animal protein), a level that was maintained at 4 years (p<0.001 vs. baseline for both total protein and animal protein). By comparison, mean total protein intake in the control diet group was 84 g/day at baseline (55 g/day animal protein) and throughout followup. These results appeared to be derived from only those participants who had not withdrawn from the study. Followup urinary sulfate levels decreased from baseline at all points except 1 year in participants assigned a low animal protein diet. Within the subgroup of participants assigned a low animal protein diet who had baseline hypercalciuria, followup urine calcium and uric acid levels also decreased. No changes from baseline occurred in any of the followup urine biochemical measures in the control diet group.

#### Other Dietary Interventions

Stone Recurrence. No trials assessed the efficacy of diets with altered calcium, low sodium, low oxalate, or low purine independent of other diet changes. In one trial, fewer participants randomized to a multicomponent diet that included normal to high dietary calcium intake (1200 mg/day) had recurrent stones than the group assigned to a low dietary calcium (400 mg/day) control group51 (Appendix D, Table 1) In a single trial, participants randomized to a multicomponent diet that included low dietary sodium intake (50 mmol/day vs. usual care)51 were less likely to experience stone recurrence than those randomized to a control diet. Last, two trials that compared multicomponent dietary intervention trials that included low purine intake with control diets reported mixed results.53,57

Other Clinical Outcomes. None of the multicomponent diet intervention trials that include altered calcium, low sodium, low oxalate, or low purine reported results for any other clinical health outcomes (Appendix E, Tables 1b–c).

Subgroups. Because no trials assessed the efficacy of diets with altered calcium, low sodium, low oxalate, or low purine independent of other diet changes, there also are no efficacy data for these interventions within subgroups defined by demographic or comorbid characteristics or according to characteristics of stone history.

Adherence to Assigned Treatment. No trials assessed adherence to the diets.

## Key Question 3 In adults with a history of nephrolithiasis, what is the evidence that dietary therapies to reduce risk of recurrent stone episodes are associated with adverse effects?

### Overview

Withdrawals for any cause were low in trials evaluating increased fluid intake, but high in long-term trials evaluating low soft drink intake, high fiber, low animal protein, and multicomponent dietary interventions; other adverse events reporting was poor.

### Study Withdrawals and Adverse Events

Increased Fluid Intake Versus No Treatment. Withdrawals in the two trials that compared increased fluid intake to no treatment averaged 9.5 percent (range 0 to 10 percent) with similar proportions between intervention and control groups (Appendix G, Table 1). One trial reported zero withdrawals due to adverse events,42 and one trial reported no data on withdrawals due to adverse events.46 Neither trial reported any results regarding the number of participants with at least one adverse event or with any specific adverse event.

Increased Oligomineral Water Intake Versus Increased Tap Water Intake. The single trial that compared increased oligomineral water intake with increased tap water intake reported no withdrawals from either treatment group (Appendix G, Table 1). However, the study reported no results regarding the number of participants with at least one adverse event or with any specific adverse event.54

Decreased Soft Drink Intake. The single trial that compared decreased soft drink intake with no treatment reported that 8.7 percent of participants withdrew in the intervention group versus 5.5 percent in the control group55 (Appendix G, Table 1). In each group, two participants withdrew due to adverse events in each group, and two participants died. No information was reported regarding the circumstances of the deaths. The trials reported no other adverse events data.

Multicomponent Dietary Interventions. Withdrawals in the three multicomponent dietary intervention trials averaged 16.4 percent (range 14.2 to 23.5 percent) and were no greater in the multicomponent dietary intervention group than the control group in the two studies that reported those outcomes separately51,57 (Appendix G, Table 1). In the one trial reporting, withdrawals due to adverse events were 5.0 percent in the multicomponent dietary intervention group (hypertension, gout, and stroke each 1.7 percent) versus 11.7 percent in the control group (hypertension 11.7 percent).51 In addition, two participants (3.3 percent) in the control group died during the study.51

High Fiber Intake. A single trial comparing a high-fiber diet with a control diet independent of other dietary interventions reported 55.0 percent withdrawals in the treatment group versus 61.7 percent for the control group after 4 years56 (Appendix G, Table 1). This trial reported no data on withdrawals due to adverse events or regarding the number of participants with at least one adverse event or any specific adverse event.

Low Animal Protein Intake. The single trial that compared a low animal protein diet with a control diet independent of other dietary interventions reported 58.2 percent withdrawals in the low animal protein group versus 61.7 percent in the control group after 4 years56 (Appendix G, Table 1). This trial reported no data on withdrawals due to adverse events or regarding the number of participants with at least one and/or any specific adverse event.

## Key Question 4 In adults with a history of nephrolithiasis, what is the effectiveness and comparative effectiveness of different pharmacological therapies on final health outcomes and intermediate stone outcomes?

### Overview

In patients with multiple past calcium stones, we found moderate strength of evidence (Table 2) that treatment reduces risk of composite recurrent stones versus control for thiazide diuretics (RR, 0.53 [CI, 0.41 to 0.68], n=6 trials), citrate (RR, 0.26 [CI, 0.14 to 0.48], n=3 trials), and allopurinol (RR, 0.59 [CI, 0.42 to 0.84], n=2 trials). Among patients with a history of struvite stones, but no residual stones at baseline, we found insufficient strength of evidence that risk of radiographic stone recurrence was not significantly reduced in participants randomized to AHA versus placebo (RR, 0.81 [CI, 0.18 to 3.66], n=2 trials). We also found low strength of evidence that risk of a composite stone recurrence was nonsignificantly lower in individuals randomized to magnesium than in those assigned to placebo (RR, 0.65 [CI, 0.37 to 1.16], n=1 trial).

Table 2 Strength of evidence for prevention of stone recurrence: pharmacological intervention trials

Intervention | Stone Recurrence Type | Number of Trials | Number of Randomized Subjects | Summary Statistics, RR [95% CI] | Risk of Bias^*^ | Directness^**^ | Precision^†^ | Consistency^‡^ | Evidence Rating^††^
Thiazide vs. placebo or control | Symptomatic | 1 | 51 | 1.04 [0.39 to 2.80] | medium | direct | imprecise | NA | Insufficient
Thiazide vs. placebo or control | Composite | 6 | 387 | 0.53 [0.41 to 0.68] | medium | direct | precise | consistent | Moderate
Thiazide vs. placebo or control | Radiographic | 0 | - | - | - | - | - | - | Insufficient
Citrate vs. placebo or control | Symptomatic | 0 | - | - | - | - | - | - | Insufficient
Citrate vs. placebo or control | Composite | 4 | 250 | 0.25 [0.14 to 0.44] | medium | direct | precise | consistent | Moderate
Citrate vs. placebo or control | Radiographic | 1 | 50 | 0.95 [0.62 to 1.44] | medium | direct | imprecise | NA | Low
Allopurinol vs. placebo or control | Symptomatic | 1 | 72 | 0.36 [0.11 to 1.19] | medium | direct | imprecise | NA | Low
Allopurinol vs. placebo or control | Composite | 2 | 204 | 0.59 [0.42 to 0.84] | medium | direct | precise | consistent | Moderate
Allopurinol vs. placebo or control | Radiographic | 1 | 72 | 1.07 [0.16 to 7.10] | medium | direct | imprecise | NA | Insufficient
AHA vs. placebo or control | Symptomatic | 0 | - | - | - | - | - | - | Insufficient
AHA vs. placebo or control | Composite | 0 | - | - | - | - | - | - | Insufficient
AHA vs. placebo or control | Radiographic | 2 | 304 | 0.81 [0.18 to 3.66] | medium | direct | imprecise | consistent | Insufficient
Magnesium vs. placebo | Symptomatic | 0 | - | - | - | - | - | - | Insufficient
Magnesium vs. placebo | Composite | 1 | 82 | 0.65 [0.37 to 1.16] | medium | direct | imprecise | NA | Low
Magnesium vs. placebo | Radiographic | 0 | - | - | - | - | - | - | Insufficient
Thiazide plus citrate vs. thiazide | Symptomatic | 0 | - | - | - | - | - | - | Insufficient
Thiazide plus citrate vs. thiazide | Composite | 1 | 100 | 0.94 [0.52 to 1.68] | medium | direct | imprecise | NA | Low
Thiazide plus citrate vs. thiazide | Radiographic | 0 | - | - | - | - | - | - | Insufficient
Thiazide plus allopurinol vs. thiazide | Symptomatic | 0 | - | - | - | - | - | - | Insufficient
Thiazide plus allopurinol vs. thiazide | Composite | 1 | 50 | 0.79 [0.18 to 3.49] | medium | direct | imprecise | NA | Insufficient
Thiazide plus allopurinol vs. thiazide | Radiographic | 0 | - | - | - | - | - | - | Insufficient

Abbreviations: CI = confidence intervals; AHA = Acetohydroxamic acid; NA = not applicable; RR = relative risk

* Risk of bias was rated low, medium, or high based on whether the design and conduct of the studies for a given outcome or comparison indicate good internal validity.

** Directness indicated whether results reflect a single, direct link between the intervention of interest and the outcome and was rated as either direct or indirect.

† Precision indicated the degree of certainty surrounding an effect estimate of a given outcome and was rated either precise or imprecise, with a precise estimate being one that allowed a clinically meaningful conclusion.

‡ Consistency indicated whether the included studies found a similar direction of effect and was rated consistent, inconsistent, or, in cases when only a single study was evaluated, unknown/not applicable.

†† Evidence was rated using the following grades: (1) high confidence indicated that further research is very unlikely to change the confidence in the estimate of effect, meaning that the evidence reflects the true effect; (2) moderate confidence denoted that further research may change our confidence in the estimate of effect and may change the estimate; (3) low confidence indicated that further research is very likely to have an important impact on the confidence in the estimate of effect and is likely to change the estimate, meaning there is low confidence that the evidence reflects the true effect; and 4) insufficient, indicating that the evidence was unavailable or did not permit a conclusion. Examples when evidence is available, but SOE may be graded as insufficient include when there is an unacceptably high risk of bias, or there is a major inconsistency that cannot be explained (e.g., 2 studies with the same risk of bias with opposite results and no clear explanation for the discrepancy). In addition, SOE may be graded as insufficient when data are too imprecise. This may be the case when the 95% CI is so wide that it cannot exclude either a clinically significant benefit or harm (e.g. lower CI bound 〈0.5 and upper CI bound >2).

In trials that compared active treatments with each other, risk of composite stone recurrence was nonsignificantly higher in individuals randomized to magnesium than in those assigned to thiazide (RR, 2.06 [CI, 0.88 to 4.84], n=1 trial) (low strength of evidence). Further, the risk of a composite stone recurrence was not significantly different between individuals randomized to thiazide plus citrate versus thiazide alone (30.0 vs. 32.0 percent; RR, 0.94 [CI, 0.52 to 1.68]) (low strength of evidence), or between individuals randomized to thiazide plus allopurinol and those assigned to thiazide alone (12.5 vs. 15.8 percent; RR, 0.79 [CI, 0.18 to 3.49]) (insufficient strength of evidence).

### Thiazide Diuretic Monotherapy Versus Placebo or Control

#### Study Characteristics

Study Design. Seven trials met all eligibility criteria and randomized participants with nephrolithiasis (n=565, range 41 to 150) to a thiazide diuretic versus placebo (n=3 trials)47,49,52 or control treatment (n=4 trials)41,48,50,58 (Appendix C, Table 2; Appendix F, Table 2). All trials were published in peer-reviewed English-language journals except for one published in a conference proceedings.50 All trials indicated that they were randomized, although none reported an adequate method of random allocation of treatment assignment. All studies utilized a parallel group design, and three studies also compared historical pretreatment with post-treatment stone recurrence rates.41,47,48 Mean study duration was 35 months (mean or median range 12 months to 4 years) and all but two studies were at least 3 years.

Treatment Groups. Among the trials that compared thiazide with placebo or control, five (n=365 participants) utilized hydrochlorothiazide, including studies that assigned participants to fixed doses of 25 mg twice daily,49,50,52 50 mg once daily,58 and 50 mg twice daily48 (Appendix C, Table 2). One trial randomized 124 participants to chlorthalidone versus placebo,47 including treatment arms of 25 mg/day and 50 mg/day. In addition, one study randomized 75 participants to indapamide 2.5 mg/day versus control.41 Among the seven eligible trials, six reported dietary co-interventions in both treatment and control arms, including increased fluid intake in six studies,41,47–50,58 decreased oxalate intake in five studies,41,47–50 decreased sodium intake in three studies,41,47,49 decreased calcium intake in three studies,41,48,49 increased calcium intake in one study,47 decreased purine intake in two studies,41,49 and decreased animal protein intake in one study.47

Outcome Measures. Five trials reported a composite outcome of stone recurrence defined by either stone passage or removal or by radiographic stone detection by x-rays and/or ultrasounds that were scheduled every 6 to 12 months.41,47–49,58 In addition, one trial reported symptomatic stone recurrences only,52 and one trial did not state how it defined incident recurrent stones.50 No trials reported results for stones detected only by scheduled imaging, or for change in stone size.

#### Participant Characteristics

Demographics. The mean age of study participants was 45 years (range 35 to 48; n=6 trials), and men constituted 80 percent (range 61 to 88; n=6 trials) of all patients (Appendix C, Table 2; Appendix F, Table 2). In the single trial that reported data on race, 94 percent of participants were white.47 Six trials were conducted in Europe (78 percent of participants) and one in the United States.47 One trial recruited participants from general practice.49 No other trials reported information on study setting.

Medical History. No trials reported baseline weight, BMI, or the prevalence of obesity (Appendix C, Table 2). One trial included only participants with normal renal function and morphology,58 but no other studies reported inclusion, exclusion, or prevalence of participants with chronic kidney disease. In the single trial that reported baseline renal function, mean serum creatinine was 1.0 mg/dL.41 In one trial reporting, 27 percent of participants had a history of hypertension.41 All studies excluded patients with biochemical or other disorders that would predispose to stone disease. No eligible studies reported prevalence of previous bariatric surgery, solitary kidney, renal transplant, coronary artery disease, diabetes, or pregnancy. Several trials excluded participants with disorders that could predispose them to kidney stones, including exclusion of individuals with “endocrine disease,”58 with “secondary causes” of kidney stones,47 with primary hyperparathyroidism,52 and inclusion only of participants with “idiopathic” stones.41

Stone History. All studies included only individuals with recurrent calcium stones, with four studies further restricting enrollment to those with calcium oxalate stones41,47,50,58 (Appendix C, Table 2). Four trials required that stone episodes had occurred recently, ranging from at least one in the last47,49 two47,49 to 41 three41 years, to at least two in the past 3 years.58 One trial excluded participants with residual stones at baseline (ascertained by renal ultrasound and intravenous pyelography).41 A second trial included both participants with (47 percent) and without residual stones (ascertained by x-ray),47 while the remaining studies reported no information regarding baseline presence of residual stones.

Baseline Biochemistry. All seven eligible thiazide studies reported at least some baseline serum and/or urine biochemistry results (Appendix H, Table 2). Five trials based urine biochemistry measures on 24-hour urine collections, and two did not specify how urine was collected.50,58

Forty-seven percent of study participants had hypercalciuria (range 12 to 100, n=7 trials), including one study entirely comprising participants with hypercalciuria.41 Eleven percent of study participants had hyperoxaluria, including one study entirely comprising participants with hyperoxaluria,31 three that excluded individuals with hyperoxaluria,47,48,50 and one in which 2 percent of participants had hyperoxaluria.58 Twelve percent of study participants had hyperuricosuria (range 0 to 37, n=5 trials), including two trials that excluded participants with hyperuricosuria.48,50 Three trials reported on prevalence of hypocitraturia, including two that excluded participants with hypocitraturia48,50 and one in which 15 percent of participants had hypocitraturia.58

Five trials reported mean baseline values for at least some urine biochemistry measures. (Appendix H, Table 2)41,47–49,52 All trials reported urine calcium with a mean of 268 mg/24 hrs (range 185 to 384) in four trials and a calcium/creatinine ratio of 0.47 in one trial.48 Other frequently reported baseline results included mean oxalate 25 mg/24 hrs (range 21 to 44, n=4 trials), mean uric acid 677 mg/24 hrs (range 532 to 757, n=4 trials), mean sodium 4552 mg/24 hrs (range 3230 to 4719, n=3 trials), and mean citrate 468 mg/24 hrs (range 348 to 564, n=2 trials). Only one trial reported calcium-oxalate product52 and no trials reported calcium-oxalate supersaturation. Baseline urine volume was reported in four trials, with a mean of 1.61 liters/24 hrs (range 1.44 to 1.75).41,47,49,52

#### Study Quality

All seven eligible trials were rated fair quality (Appendix C, Table 8). Allocation concealment was unclear in all studies. Three trials reported that they were double-blinded,47,49,52 two were open label studies,41,50 and two reported no information on blinding.48,58 Four trials performed intention to treat analysis.48–50,58 All of the trials adequately reported withdrawals, which ranged from 0 to 46.3 percent.

#### Efficacy Outcomes

Stone Recurrence. Among the six trials that reported, pooled recurrence risk of composite stone outcome was significantly lower in individuals randomized to thiazide than to placebo or control treatment (24.9 vs. 48.5 percent; RR, 0.53 [CI, 0.41 to 0.68])41,47–50,58 (Figure 4; Appendix D, Table 2). Results were similar in analyses in which the trial published in a conference proceeding was excluded (25.4 vs. 62.3 percent; RR, 0.48 [CI, 0.24 to 0.94]), and all further results reported include all eligible thiazide trials. The single trial that reported results for symptomatic stone recurrence, for which followup was limited to 1 year, found no difference in risk of recurrence between individuals randomized to thiazide versus placebo (24.0 vs. 23.1 percent; RR, 1.04 [CI, 0.39 to 2.80])52 (Figure 5). Because the wide confidence intervals cannot exclude either a clinically significant benefit or harm, we judged the strength of this body of evidence as insufficient. No studies reported results for stone recurrence based on radiographic detection only.

Figure 4 Risk of composite stone recurrence, thiazide versus control treatment

Figure 4. Risk of composite stone recurrence, thiazide versus control treatment. This figure depicts the risk of composite stone recurrence in patients assigned to thiazide treatment versus control. Among the 6 studies totaling 447 patients represented in this forest plot, risk of composite recurrence was significantly reduced by 47% with thiazide therapy compared with control (Risk ratio was 0.53 [95% CI 0.41 to 0.68]). Incidence of recurrence was 25% for the thiazide group versus 48% for the control group.

Figure 5 Risk of symptomatic stone recurrence, thiazide versus control treatment

Figure 5. Risk of symptomatic stone recurrence, thiazide versus control treatment. This figure depicts the risk of radiographic stone recurrence in one study of patients assigned to thiazide versus control. The study by of 51 patients (Scholz 1982) found that the risk of radiographic recurrence was not significantly reduced with thiazide therapy compared with control (Risk ratio was was 1.04 [95% CI 0.39 to 2.80). Incidence of recurrence was 24% for the thiazide group versus 23% for the control group.

The one trial that reported stone recurrence rates presented results not by treatment groups as a whole, but only by subgroups within treatment groups48 (Appendix E, Table 2a). Stone recurrence rate appeared to drop in both treatment groups, without a greater reduction in those assigned to thiazide therapy. A second study reported a significant increase in time to stone recurrence from baseline among those treated with thiazide but among controls.49

Other Clinical Outcomes. One study reported a significantly lower risk of extracorporeal lithotripsy (8.0 vs. 26.0 percent, p=0.03) in participants randomized to thiazide compared with the placebo.58 No trials reported results for any other clinical health outcomes (Appendix E, Tables 2b–c).

Subgroup Results. For the composite stone recurrence outcome, risk versus placebo or control was significantly reduced in each thiazide studied, including hydrochlorothiazide (RR, 0.58 [CI, 0.44 to 0.76]),48–50,58 chlorthalidone (RR, 0.32 [CI, 0.14 to 0.73]),47 and indapamide (RR, 0.33 [CI, 0.13 to 0.79])41 (p=0.22 for interaction between thiazide types). In addition, there was no significant difference in risk of stone recurrence versus control based on total daily dose of hydrochlorothiazide (RR, 0.80 [CI, 0.31 to 1.90]) for 100 mg per day and (RR, 0.59 [CI, 0.45 to 0.77]) for 50 mg per day; p=0.50 for interaction)) or between trials that used 25 mg twice daily (RR, 0.63 [CI, 0.43 to 0.92]) and one that appeared to use 50 mg once daily (RR, 0.55 [CI, 0.38 to 0.81]) (p=0.66 for interaction). Similarly, efficacy for chlorthalidone 50 mg/day (RR, 0.29 [CI, 0.09 to 0.89]) was not significantly better than chlorthalidone 25 mg/day (RR, 0.35 [CI, 0.12 to 1.06]) (p=0.81 for interaction).

Thiazide treatment relative to placebo or control may be more effective in longer-term trials versus shorter term trials. In studies that reported a composite stone recurrence outcome, relative risk reduction in trials of at least 3 years (RR, 0.51 [CI, 0.39 to 0.66]) was not significantly greater than in a single 2-year trial (RR, 0.80 [CI, 0.34 to 1.90]) (p=0.32 for interaction between subgroups). By comparison, as noted above, a single 1-year trial found no difference in risk of symptomatic stone recurrence between treatment groups.52

Results also appeared similar to overall results in several additional subgroups defined by dietary co-interventions recommended to all treatment groups. These included five thiazide trials that advised all treatment groups to increase fluid and decrease oxalate intake alone or as part of a multicomponent dietary co-intervention (RR, 0.51 [CI, 0.37 to 0.70])(p=0.75 for interaction with single trial that reported no dietary co-intervention), and one trial that advised all treatment groups to increase dietary calcium as part of a multicomponent diet intervention (RR, 0.32 [CI, 0.14 to 0.73]).

None of the thiazide trials reported efficacy outcomes within subgroups defined by demographic or comorbid characteristics. Results in the single trial that reported recruitment of participants from a general practice setting (RR, 0.45 [CI, 0.19 to 1.09])49 were similar to overall results. With regard to subgroups defined by characteristics of participant stone history, results in the single trial restricted to participants without residual stones at baseline were similar to overall results (RR, 0.33 [CI, 0.13 to 0.79]).41 Because all participants in these trials had a history of recurrent calcium stones, no subgroup analyses for other stone types or for individuals who have experienced only one kidney stone were feasible.

Adherence to Assigned Treatment. One trial reported that compliance with medication was confirmed by regular pill counts, but compliance with diet instructions was not assessed. Further, approximately 15 percent of study participants discontinued the trial due to loss of interest.47 A second trial reported that no participants discontinued therapy during the trial, but didn’t report how adherence with thiazide treatment was monitored.48 The remaining five trials reported no information regarding adherence.

### Citrate Monotherapy Versus Placebo or Control

#### Study Characteristics

Study Design. Six trials met all eligibility criteria and randomized participants with nephrolithiasis (n=368, range 39 to 110) to citrate pharmacotherapy versus placebo (n=2 trials)43,44 or control treatment (n=4 trials)45,59,63,64 (Appendix C, Table 3). All trials were published in peer-reviewed English-language journals. All studies utilized a parallel group design, and two studies also compared historical pretreatment with post-treatment stone recurrence rates.43,59 Mean study duration was 25 months, with the mean or median duration ranging from 12 to 37 months (Appendix F, Table 3).

Treatment Groups. Among the trials that compared citrate with placebo or control, two utilized fixed potassium citrate doses of 60 mEq/day43,45 (Appendix C, Table 3). Three trials used sodium-potassium citrate, at 5–10 gm/day in one study,63 at 30 gm/day initially followed by adjustments to keep urine pH between 7.0 and 7.2 in a second study,59 and at 81 mEq/day in a third study.64 Last, one trial used magnesium-potassium citrate (42 mEq/day potassium, 21 mEq/day magnesium, and 63 mEq citrate).44 No trials assessed calcium citrate. Four trials reported dietary co-interventions in both treatment and control arms,43,45,59,64 always including increased fluid intake. In addition, one study further advised all participants to decrease oxalate, animal protein, and sodium intake,45 and one study advised all participants to decrease sodium intake.43

Outcome Measures. Four trials reported a composite outcome of stone recurrence defined by either stone passage or removal or by radiographic stone detection by x-rays and/or ultrasounds that were scheduled every 6 to 12 months.43–45,64 In addition, one trial reported results for recurrent stones detected only by scheduled imaging.59 No studies reported symptomatic stone recurrences only. One study reported results for radiographic change in stone size.63

#### Participant Characteristics

Demographics. The mean age of subjects was 47 years (range 42 to 55; n=5 trials), and men constituted 62 percent (range 44 to 78; n=6 trials) of all patients randomized (Appendix C, Table 3; Appendix F, Table 3). No trials reported data on race or ethnicity. Three trials were conducted in Europe (59 percent of participants),43,45,59 one in the United States (17 percent of participants),44 and two in Asia (24 percent of participants).63,64

Medical History. No trials reported baseline weight, BMI, or the prevalence of obesity (Appendix C, Table 3). Most trials excluded at least some participants with abnormal renal function and/or morphology, though exclusion criteria differed between studies. Two trials reported exclusion of participants with undefined abnormal kidney function or morphology, which were undefined in one trial45 and were based on an intravenous pyelography performed at least 8 weeks prior to baseline in the second trial.64 In addition, one trial excluded participants with serum creatinine greater than 1.8 mg/dl,44 one trial excluded individuals with serum creatinine of 4.0 mg/dl or greater,63 and one trial excluded those with undefined renal failure.43 No trials reported any measure of baseline renal function. All studies excluded patients with biochemical abnormalities or other conditions that would predispose to stone disease. One trial excluded participants with diabetes or who were pregnant.43 One trial excluded participants with coronary heart disease.63 Otherwise, no study reported prevalence of previous bariatric surgery, solitary kidney, renal transplant, coronary artery disease, diabetes, hypertension, or pregnancy.

Stone History. Three trials included only individuals with recurrent calcium oxalate stones,43,44,58,59 and one trial included only participants with a single calcium oxalate stone episode,45 and one trial included participants with either one or multiple past calcium stones64 (Appendix C, Table 3). By comparison, one trial reported no information regarding whether participants had single or multiple past stone episodes or their past stone composition.63 Four trials required that stone episodes had occurred recently. One was limited to patients who had undergone extracorporeal shock wave lithotripsy (ESWL) or percutaneous nephrolithotomy (PCNL) 8 weeks earlier, with only the subgroup who were stone free considered eligible for this review.64 Other trials required that participants had at least one stone episode in the last 2^44^ to 3^59^ years, to at least two episodes in the last 2 years.43 One study was limited to participants with residual stones, which had to be a minimum of 10 mm in diameter as ascertained by ultrasound alone.63 Two other trials included 38 percent45 and 72 percent44 participants with residual stones, ascertained by x ray plus ultrasound or x ray alone, respectively.

Baseline Biochemistry. Five of six eligible citrate studies reported at least some baseline serum and/or urine biochemistry results43–45,59,64 (Appendix H, Table 3). All of these trials based urine biochemistry measures on 24-hour urine collections.

Twenty percent of participants had hypercalciuria (range 0 to 44, n=3 trials),43,45,59 including one study in which individuals with hypercalciuria were excluded.43 Sixty-three percent had hypocitraturia (range 38 to 100, n=3 trials),43,45,59 including one study in which only individuals with hypocitraturia were included.43 Eighteen percent of participants had hyperuricosuria in one trial reporting.45 No trials reported on prevalence of hyperoxaluria.

Three trials reported baseline urine citrate measurements (Appendix H, Table 3), including two that reported means of 365 mg/24hrs,43 and 567 mg/24 hrs,44 respectively, and one that reported 1.2 mmol/liter but provided no results for urine volume.59 Otherwise, only one trial reported results for mean baseline urine calcium (257 mg/24 hrs), mean urine oxalate (36 mg/24 hrs), mean urine uric acid (708 mg/24 hrs), mean urine sodium (3865 mg/24 hrs), mean urine volume (1.86 liters/24 hrs), and mean urine calcium-oxalate product (1.59) (Appendix H, Table 3).44 No trials reported calcium-oxalate supersaturation.

Study Quality. Among the six eligible trials, one was rated good quality,44 and the remainder fair (Appendix C, Table 8). Allocation concealment was adequate in one study44 and unclear in the rest. Two trials reported that they were double-blinded,44,39 two others reported that the outcomes assessor was blinded,45,63 and two reported no information on blinding.59,64 One trial performed intention to treat analysis.44 Five of the trials adequately reported withdrawals, ranging from 14.6 to 35.9 percent, while one did not report withdrawals separately for the eligible participants who were stone free at baseline.64

#### Efficacy Outcomes

Stone Recurrence. In four trials that reported a composite stone recurrence outcome,43–45,64 pooled recurrence risk was significantly lower in individuals randomized to citrate than to either placebo or control (11.1 vs. 52.3 percent; RR, 0.25 [CI, 0.14 to 0.44]) (Figure 6; Appendix D, Table 3). In the single trial that reported results for radiographic stone recurrence only, risk did not differ between individuals randomized to citrate versus control (RR, 0.95 [CI, 0.62 to 1.44])59 (Figure 7). No studies reported results for stone recurrence based on symptomatic detection only.

Figure 6 Risk of composite stone recurrence, citrate versus control treatment

Figure 6. Risk of composite stone recurrence, citrate versus control treatment. This figure depicts the risk of composite stone recurrence in patients assigned to citrate treatment versus control. Four studies totaling 197 patients are represented in this forest plot. Risk of composite recurrence was significantly reduced by 75% with citrate therapy compared with control (Risk ratio was 0.25 [95% CI 0.14 to 0.44]). Incidence of recurrence was 11% for the citrate group versus 52% for the control group.

Figure 7 Risk of radiographic stone recurrence, citrate versus control treatment

Figure 7. Risk of radiographic stone recurrence, citrate versus control treatment. This figure depicts the risk of radiographic stone recurrence in one study of patients assigned to citrate versus control. The study by Hofbauer 1994 of 38 patients found that the risk of radiographic recurrence was not significantly reduced with thiazide therapy compared to control (Risk ratio was was 0.95 [95 percent confidence intervals 0.62 to 1.44). Incidence of recurrence was 69 percent for the citrate group versus 73 percent for the control group.

Two studies reported stone recurrence rates (Appendix E, Table 3a), with one noting a significant improvement with citrate therapy (0.1 stones/yr vs. 1.1 stones/yr, p<0.001),43 and the other noting no difference between citrate and control (0.7 stones/yr vs. 0.9 stones/yr, p=0.65).59 A single study that reported change in stone size found no significant difference between participants randomized to citrate versus Orthosiphon grandiflorus extract in the percentage reduction per year in stone diameter at 18 months (38.5 vs. 40.9 percent).63

Other Clinical Outcomes. One study reported that in participants with stone recurrence, spontaneous stone passage was significantly more likely to be painless in those assigned to citrate versus placebo (56 vs. 4 percent, p=0.001).59 No trials reported results for any other clinical health outcomes (Appendix E, Tables 3b–c).

Subgroup Results. For the composite stone recurrence outcome, results appeared similar by type of citrate, including for potassium citrate (RR, 0.22 [CI, 0.04 to 1.21], n=2 trials),43,45 potassium-magnesium citrate (RR, 0.20 [CI, 0.08 to 0.52], n=1 trial),44 and potassium-sodium citrate (RR, 0.18 [CI, 0.03 to 1.26], n=1 trial)64(p=0.99 for interaction). Both trials that used potassium citrate used similar doses (60 mEq/day and flexible dosing of 30 to 60 mEq/day) making it impossible to determine whether efficacy differed by dose.

Efficacy of citrate treatment relative to control appeared similar in short- and longer-term trials. Recurrence risk was significantly reduced both in the two studies that lasted at least 2 years (RR, 0.28 [CI, 0.15 to 0.51])43,44 and in two studies that lasted 1 year (RR, 0.13 [CI, 0.03 to 0.62])64,45(p=0.36 for interaction).

Again for the composite stone recurrence outcome, results appeared similar to overall results in several additional subgroups defined by dietary co-interventions recommended to all treatment groups. These included three citrate trials in which all treatment groups were advised to increase fluid (RR, 0.28 [CI, 0.13 to 0.59]),43,45,64 in two cases as part of a multicomponent dietary co-intervention (p=0.94 for interaction with trials not reporting instructions to increase fluid intake). One of these multicomponent dietary trials also advised participants to reduce sodium intake (RR, 0.35 [CI, 0.16 to 0.75]),43 and the other advised them to reduce sodium, oxalate, and animal protein intake (RR, 0.06 [CI, 0.00 to 0.97]).45

None of the citrate trials reported efficacy outcomes within subgroups defined by demographic or comorbid characteristics. With regard to subgroups defined by characteristics of participant stone history, a single trial found a significant reduction in recurrent stone risk in participants with only a single past stone episode and who had no residual stones (RR, 0.06 [CI, 0.00 to 0.97]).45 Because all participants in these trials had a history of calcium stones, subgroup analyses by stone composition was not possible.

Adherence to Assigned Treatment. One trial reported no information regarding adherence.63 Among trials that reported adherence, one reported median compliance by pill count of 89 percent in the citrate group and 87 percent in the placebo group, with 81 percent of the citrate group and 73 percent of the placebo group being more than 70 percent compliant.44 A second trial categorized participants who took an average of fewer than six of 12 scheduled study tablets per day as noncompliant, and reported 29 percent noncompliance for participants assigned to citrate and 28 percent for those assigned to placebo.43 A third study reported that four participants were excluded from analyses due to “reluctance to receive medication” and that compliance with citrate as determined by urinary citrate and potassium levels was “good in all patients.”45 A fourth study reported only that one participant was excluded from analyses due to “unsatisfactory compliance with medication.”64 Last, a study that assessed treatment compliance using participant urinary pH self-monitoring reported that 12 percent of control group participants “refused to comply with regular follow-ups” and 25 percent of citrate group participants “were not followed up due to noncompliance.”59 It was not clear whether “refused regular followups” referred to pH monitoring, study visits, or other measures.

### Allopurinol Monotherapy Versus Placebo or Control

#### Study Characteristics Study Design

Four trials met all eligibility criteria and randomized participants with nephrolithiasis (n=240, range 15 to 132) to allopurinol monotherapy versus placebo37,40 or control38,39 (Appendix C, Table 4). All trials but one were published in peer-reviewed English-language journals except for one published in a conference proceedings.40 All studies utilized a parallel group design and also compared historical pretreatment with post-treatment stone recurrence rates. Study duration was reported as 24 and 36 months in two studies,37,40 and up to 60 months in two other studies.38,39

#### Treatment Groups

All trials utilized an allopurinol dosage of 300 mg/day throughout the treatment period except for one in which participants assigned allopurinol were prescribed 300 mg/day for 1 week, then 100 mg/day for the remainder of the study38 (Appendix C, Table 4). Three of the four trials reported dietary co-interventions in both treatment and control arms, always including increased fluid intake.37,38,40 In addition, one study further advised all participants to decrease calcium and purine intake.40 A second study advised all participants to take sodium bicarbonate as needed to keep urine pH above 6.5, a co-intervention investigators stated was to prevent the theoretical formation of xanthine stones.38

#### Outcome Measures

Two trials reported a composite outcome of stone recurrence defined either by stone passage or removal or by radiographic stone detection.37,38 One of these trials scheduled x rays every 12 months and excluded participants who had symptomatic stone recurrences less than 6 months after baseline from analyses.37 The second trial reported no type or frequency of the radiographic imaging used for identification of incident stones.38 In addition, three trials reported symptomatic stone recurrences only,37,39,40 and one reported results for recurrent stones detected by scheduled radiographic imaging.37 One study reported results for radiographic growth in stone size.37

#### Participant Characteristics

Demographics. In single studies reporting, the mean age of subjects was 48 years37 and men constituted 100 percent of all patients39 (Appendix C, Table 4). No study reported race or ethnicity.

Medical History. In a single trial reporting,37 baseline BMI was 27.8 kg/m^2^(Appendix C, Table 4). One trial excluded participants with renal failure,37 but no other studies reported inclusion, exclusion, or prevalence of participants with chronic kidney disease, or reported a baseline measure of renal function. Two studies limited inclusion to individuals without biochemical abnormalities or other secondary causes that would predispose to stone disease.37,39 An additional trial excluded participants on uricosuric medications.38 No study reported prevalence of previous bariatric surgery, solitary kidney, renal transplant, coronary artery disease, diabetes, hypertension, or pregnancy.

Stone History. All trials were limited to participants with recurrent stones comprised entirely or predominately of calcium oxalate (Appendix C, Table 4). Three trials required that stone episodes had occurred recently, including at least one in the last 2 years,37 at least four in the past 3 years,38 and an average of at least two stones per year for the last 3 years.40 One trial included both participants with (47 percent) and without residual stones (ascertained by x-ray),37 while the remaining studies reported no information regarding baseline presence of residual stones.

Baseline Biochemistry. Three of four eligible allopurinol studies reported at least some baseline serum and/or urine biochemistry results;37,38,40 the fourth trial reported that testing was performed but reported no results39 (Appendix H, Table 4). Two trials based urine biochemistry measures on 24-hour urine collections,37,40 and the others did not specify.

One trial excluded participants with hypercalciuria,37 and no other trials reported prevalence of hypercalciuria. One trial included only participants with hyperuricosuria,37 another included only participants with hyperuricemia,38 and no other studies reported the prevalence of either condition. No studies reported prevalence of hyperoxaluria, hypocitraturia, or any other baseline biochemical abnormality.

Two trials reported mean baseline values for at least some urine biochemistry measures. (Appendix H, Table 4).37,40 Mean urine calcium was 221 mg/24 hrs (range 201 to 224), mean urine uric acid was 874 mg/24 hrs (range 470 to 975), mean serum uric acid was 5.8 mg/dl (range 4.4 to 6.1), and mean urine volume was 1.66 liters/24 hrs (range 1.37 to 1.74). No trials reported calcium-oxalate product, calcium-oxalate supersaturation, or uric acid supersaturation.

#### Study Quality

All four eligible trials were rated fair quality (Appendix C, Table 8). Allocation concealment was adequate in one study37 and unclear in the rest. Three trials reported that they were double-blinded,37,38,40 and one reported no information on blinding.39 None of the trials performed intention to treat analysis. Two of the trials adequately reported withdrawals.37,38 Two additional studies reported preliminary results in a portion of randomized participants and were unclear regarding whether any participants not included in the analyses had withdrawn.39,40 Withdrawals in the studies ranged from 16.7 to 47.0 percent.

#### Efficacy Outcomes

Stone Recurrence. In the two trials that reported a composite stone recurrence outcome, we found moderate strength of evidence that recurrence risk was significantly lower in individuals randomized to allopurinol than in those assigned to placebo (33.3 vs. 55.4 percent; RR, 0.59 [CI, 0.42 to 0.84])37,38 (Figure 8; Appendix D, Table 4). In one study reporting, we found low strength of evidence that allopurinol does not reduce risk of recurrent symptomatic stones versus control (10.3 vs 29.0 percent; RR, 0.36 [CI, 0.11 to 1.19]) (Figure 9), and insufficient strength of evidence that allopurinal does not reduce risk of recurrent radiographic stones (RR, 1.07 [CI, 0.16 to 7.10]) (Figure 10).37 Results for radiographic stones were judged insufficient because of the small number of recurrent stone events and because the wide confidence intervals could not exclude either a clinically significant benefit or harm. These results were reported only in peer-reviewed allopurinol trials.

Figure 8 Risk of symptomatic stone recurrence, allopurinol versus control treatment

Figure 8. Risk of symptomatic stone recurrence, allopurinol versus control treatment. This figure depicts the risk of symptomatic stone recurrence in one study of patients assigned to allopurinol versus control. The study by Ettinger 1986 of 60 patients found that the risk of symptomatic recurrence was not significantly reduced with thiazide therapy compared to control (Risk ratio was was 0.36 [95 percent confidence intervals 0.11 to 1.19). Incidence of recurrence was 10 percent for the allopurinol group versus 25 percent for the control group.

Figure 9 Risk of composite stone recurrence, allopurinol versus control treatment

Figure 9. Risk of composite stone recurrence, allopurinol versus control treatment. This figure depicts the risk of composite stone recurrence in patients assigned to allopurinol versus control. Two studies totaling 152 patients are represented in this forest plot. Risk of composite recurrence was significantly reduced by 41% with citrate therapy compared to control (Risk ratio was 0.59 [95 percent confidence intervals 0.42 to 0.84]). Incidence of recurrence was 33 percent for the allopurinol group versus 55 percent for the control group.

Figure 10 Risk of radiographic stone recurrence, allopurinol versus control treatment

Figure 10. Risk of radiographic stone recurrence, allopurinol versus control treatment. This figure depicts the risk of radiographic stone recurrence in one study of patients assigned to allopurinol versus control. The study by Ettinger 1986 of 60 patients found that the risk of radiographic recurrence was significantly reduced with allopurinol therapy compared with control (Risk ratio was was 0.53 [95% CI 0.29 to 0.99). Incidence of recurrence was 31% for the allopurinol group versus 58% for the control group.

Results were inconsistent in the three trials that reported stone recurrence rates (Appendix E, Table 4a), perhaps related to differences in the type of stone recurrence they reported. The absolute rate of stone recurrence appeared lower in participants assigned to allopurinol versus control in one study that reported a rate of composite stone recurrence (0.12 vs. 0.26 stones per patient year),37 but not in two studies that reported a rate of symptomatic stone recurrence (0.54 vs. 0.58,^39^ and, in the only allopurinol trial published as a conference proceeding, 0.96 vs. 0.66 stones per patient year;40 none of these studies reported a test for statistical significance. One trial also reported a significant increase in time to first composite stone recurrence in participants assigned allopurinol versus placebo (33.3 vs. 27.4 months, p<0.05).37

Other Clinical Outcomes. No trials reported results for any other clinical health outcomes (Appendix E, Tables 4b–c).

Subgroup Results. Regarding dosage, a single study that dosed allopurinol at 100 mg/day rather than 300 mg/day throughout all but the first week of the treatment period38 found better results for allopurinol versus control (RR, 0.61 [CI, 0.42 to 0.90]) and appeared similar to the overall results.

Regarding study duration, reduction in composite stone recurrence risk appeared similar between a single trial of up to 5 years duration (RR, 0.61 [CI, 0.42 to 0.90])38 and in a single study of 2 years in duration (RR, 0.49 [CI, 0.19 to 1.23]).37

Regarding dietary co-interventions, all composite stone recurrence results were derived from trials that assigned participants in both treatment and control groups to increased fluid intake. A single allopurinol monotherapy trial in which additional dietary co-interventions were instituted (reduced calcium and purine intake), found no difference in the rate of symptomatic stone recurrence between treatment groups.40

None of the allopurinol trials reported efficacy outcomes within subgroups defined by demographic or comorbid characteristics. With regard to subgroups defined by characteristics of participant stone history, all participants in these trials had a history of recurrent calcium stones, thus we could not perform subgroup analyses by stone composition and number of past stone episodes.

Adherence to Assigned Treatment. One trial reported 88 percent compliance for allopurinol and 89 percent compliance for placebo as ascertained by pill counts conducted every 3 months.37 A second trial reported that pill counts were performed prior to issuance of each new medication refill, but provided no count results.38 The remaining three studies reported no information regarding adherence.

### Acetohydroxamic Acid Versus Control

#### Study Characteristics

Study Design. Three trials met all eligibility criteria and randomized participants with recurrent struvite kidney stones (n=343, range 39 to 210) to acetohydroxamic acid (AHA) versus placebo60–62 (Appendix C, Table 5). All trials were published in peer-reviewed English-language journals. All studies utilized a parallel group design and ranged in duration from up to 24 months to up to 32 months. Mean study duration was reported in two trials as 18 months.61,62

Treatment Groups. Two trials dosed AHA at 15 mg/kg/day,61,62 while the third trial utilized 500 to 1000 mg/day depending on participant weight and renal function60 (Appendix C, Table 5). One trial treated all participants in both groups with suppressive antibiotics throughout the study,62 while the other trials left use of antibiotics to the discretion of the physician.

Outcome Measures. All studies reported a radiographic definition of stone recurrence based on abdominal x-rays every 3 to 12 months, though one trial reported results only for the AHA group and not for the control group. All studies also reported the outcome of stone growth, defined variably as an increase from baseline in stone area of at least 10 percent,60 at least 25 percent,61 or at least 100 percent.62 Though none of the trials reported results for symptomatic stone recurrence, one reported an outcome for participants who underwent surgery for obstruction or infection. No trials reported a composite recurrent stone outcome, defined as occurrence of either radiographic or symptomatic stones.

#### Participant Characteristics

Demographics. The mean age of participants was 49 years (range 48 to 49; n=2 trials), and men constituted 77 percent (range 18 to 100; n=3 trials) of all patients (Appendix C, Table 5; Appendix F, Table 5). No trial reported information on race or ethnicity. All trials were conducted in the United States.

Medical History. In a single trial reporting, baseline weight was 76.3 kg60 (Appendix C, Table 5). In two trials reporting, 85 percent of participants had a history of spinal cord injury, including all individuals in one trial60 and half the participants in a second trial.61 In two trials reporting, 50 percent of participants had undergone prior supravesical diversion (range 18 to 64).61,62 In one trial, 8 percent of participants had a history of neurogenic bladder. All studies excluded patients with significant renal insufficiency, with the cutpoints ranging from serum creatinine ≥2.5 mg/dL61 to ≥3 mg/dL.60,62 However, only one trial reported a baseline measure of renal function, with a mean serum creatinine of 1.0 mg/dL.60 Two trials included only participants considered not to be candidates for surgical stone removal.60,61 One trial excluded participants who were pregnant. Otherwise, no study reported prevalence of previous bariatric surgery, solitary kidney, renal transplant, coronary artery disease, diabetes, or hypertension.

Stone History. All trials were limited to participants with struvite stones in the setting of chronic urea-splitting urinary tract infections (Appendix C, Table 5). Two trials reported inclusion of only participants with multiple past stone episodes,61,62 while the third trial reported no information on the number of past stones.60 In the two trials reporting, residual stone fragments were present in 88 percent (by excretory urogram)60 and 89 percent (by x ray)61 of participants, respectively.

Baseline Biochemistry. Although two of the three trials reported that they measured multiple urine chemistries from baseline 24-hour urine collections, neither reported any of these results.60,62 The third trial reported that baseline urine chemistries were not measured.61

#### Study Quality

We rated all three trials as fair quality (Appendix C, Table 8). Allocation concealment was adequate in two studies60,62 and unclear in one.61 All three trials reported that they were double-blinded. Only one of three trials performed intention to treat analysis.61 All of the trials adequately reported withdrawals, which ranged from 30.0 to 69.1 percent.

#### Efficacy Outcomes

Stone Recurrence. Two trials reported radiographic stone recurrence,60,61 and among participants with no residual stones at baseline, recurrence occurred in 13.3 percent of those randomized to AHA compared with 20 percent of those assigned to placebo (RR, 0.81 [CI, 0.18 to 3.66]) (Figure 11; Appendix D, Table 5). We judged strength of evidence for this comparison and outcome as insufficient because of the small number of recurrent stone events and because the wide confidence intervals could not exclude either a clinically significant benefit or harm. No trials reported results for symptomatic stone recurrence, but one reported that two participants assigned to the placebo group and none assigned to AHA underwent surgery for obstruction or infection.62 No trials reported results for composite stone recurrence or for stone recurrence rate.

Figure 11 Risk of radiographic stone recurrence, acetohydroxamic acid versus control treatment

Figure 11. Risk of radiographic stone recurrence, acetohydroxamic acid versus control treatment. This figure depicts the risk of radiographic stone recurrence in two small studies of patients assigned to acetohydroxamic acid versus control. Analysis of the 2 trials totaling 38 patients found that the risk of radiographic recurrence was not significantly reduced with acetohydroxamic acid therapy compared with control (Risk ratio was was 0.81 [95% CI 0.18 to 3.66). Incidence of recurrence was 13% for the acetohydroxamic acid group versus 20% for the control group.

All trials reported results for stone growth (Appendix E, Table 5a). One study reported a significantly lower risk of a >100 percent increase in stone area in participants randomized to AHA versus those assigned placebo (0 percent vs. 39 percent, p=0.008).62 A second study reported a significantly lower risk of a >25 percent increase in stone area (19.0 vs. 50.0 percent, p<0.05).61 By comparison, a third study reported a significantly lower risk of >10 percent increase in stone area at 1 year (33.3 vs. 60.5 percent, p=0.017) but not at 2 years (41.7 vs. 60.0 percent, p=0.26), with some participants in both treatment groups reaching this endpoint at 1 year and thus excluded from the 2-year analyses.60 Last, one trial reported no significant difference in stone fragment clearance between AHA and placebo after either 1 or 2 years.60

Other Clinical Outcomes. None of the trials reported results for any other clinical health outcomes (Appendix E, Tables 5b–c).

Subgroup Results. Due to the small number of study participants for whom data were reported for recurrent stones in both AHA and control treatment groups, no subgroup analyses were performed.

Adherence to Assigned Treatment. One trial defined compliance by whether fewer than 20 percent of the pills prescribed at the previous study visit remained at the next study visit; compliance during the study ranged from 79 to 91 percent in the AHA group and from 84 to 94 percent in the placebo group.60 One trial reported only that few if any participants in the treatment group received their medications 100 percent of the time, but that close monitoring resulted in a high (>80 percent) degree of compliance.61 The third trial reported that compliance was verified by pill counts and urine screening for AHA, and that participants determined by either measure to be taking less than 50 percent of their medication were withdrawn from the study. Although 16 percent of participants assigned to AHA and 5 percent of those assigned to placebo were not included in analyses after 7 to 10 months of treatment because of noncompliance, the study did not report compliance over its full duration.62

### Magnesium Monotherapy Versus Placebo or Active Treatment

#### Study Characteristics

Study Design. One trial met all eligibility criteria and randomized participants with recurrent kidney stones to magnesium (n=51) versus placebo (n=31) versus thiazide diuretic (n=42)37,47 (Appendix C, Table 6). This study was published in a peer-reviewed English-language journal. It utilized a parallel group design and also compared historical pretreatment with post-treatment stone recurrence rates. Study duration was 36 months.

Treatment Groups. This trial included two different magnesium hydroxide fixed-dose groups (650 mg/day and 1300 mg/day), two different thiazide fixed-dose groups (chlorthalidone 25 mg/day and 50 mg/day), and a placebo group (Appendix C, Table 6). Participants in all treatment and placebo groups were instructed to follow a dietary co-intervention, consisting of drinking sufficient fluid to achieve a urine output of 2L/day, and restricting dietary salt, animal protein, and high oxalate foods. They further were instructed to increase intake of cereal fiber, avoid vitamin C, and consume two or fewer dairy servings/day.

Outcome Measures. This trial reported a composite outcome of stone recurrence defined by either passage of a previously unrecognized stone at least 3 months after baseline or radiographically detected stone growth or detection of a new stone as ascertained by annual x-ray.

#### Participant Characteristics

Demographics. Participant mean age was 47 years, and men constituted 88 percent of all patients (Appendix C, Table 6). Ninety-four percent of study participants were categorized as white, and the study was conducted in the United States.

Medical History. This trial reported no information on baseline BMI or weight (Appendix C, Table 6). In addition, it did not report inclusion or exclusion based on renal function, prevalence of participants with chronic kidney disease, or any measure of baseline renal function. Participants with secondary causes of kidney stones were excluded. Otherwise, the study reported no information on baseline prevalence of bariatric surgery, solitary kidney, renal transplant, coronary artery disease, diabetes, hypertension, or pregnancy.

Stone History. This trial was limited to participants with recurrent stones predominately comprising calcium oxalate (Appendix C, Table 6). Participants must have had at least one stone in the past 2 years and at least two stones in the past 5 years. The study included both participants with (47 percent) and without residual stones (ascertained by x-ray).

Baseline Biochemistry. Urine biochemistry measures were based on 24-hour urine collections. Among participants randomized to magnesium or placebo, 35 percent had hypercalciuria and 32 percent had hyperuricosuria. Mean baseline urine calcium was 252 mg/24 hrs, mean oxalate was 26 mg/24 hrs, mean uric acid was 758 mg/24 hrs, mean magnesium was 94 mg/24 hrs, and mean urine volume was 1.66 liters/24 hrs (Appendix H, Table 5).

Among participants randomized to magnesium or thiazide, 40 percent had hypercalciuria and 41 percent had hyperuricosuria. Mean baseline urine calcium was 274 mg/24 hrs, mean oxalate was 25 mg/24 hrs, mean uric acid was 797 mg/24 hrs, mean magnesium was 94 mg/24 hrs, and mean urine volume was 1.74 liters/24 hrs.

The study reported neither prevalence of baseline hyperoxaluria or hypocitraturia nor mean baseline citrate or sodium levels.

#### Study Quality

We rated the single magnesium trial as fair quality (Appendix C, Table 8). Because the study assigned treatment based on medical record number but used identical appearing tablets for magnesium and placebo, the adequacy of allocation concealment was unclear. The trial was double-blinded, but performed no intention to treat analysis. Withdrawals were adequately reported as 19.5 percent.

#### Efficacy Outcomes

Stone Recurrence. Risk of a composite stone recurrence was nonsignificantly lower in individuals randomized to magnesium than in those assigned to placebo (29.4 vs. 45.2 percent) (RR, 0.65 [CI, 0.37 to 1.16]) (Figure 12; Appendix D, Table 6).

Figure 12 Risk of composite stone recurrence, magnesium versus placebo treatment

Figure 12. Risk of composite stone recurrence, magnesium versus placebo treatment. This figure depicts the risk of radiographic stone recurrence in one study of patients assigned to magnesium versus control. The study by Ettinger 1988 of 82 patients found that the risk of radiographic recurrence was not significantly reduced with magnesium therapy compared with control (Risk ratio was was 0.65 [95% CI 0.37 to 1.16). Incidence of recurrence was 29% for the magnesium group versus 45% for the control group.

Risk of composite stone recurrence was nonsignificantly higher in individuals randomized to magnesium than in those assigned to thiazide (29.4 vs. 14.3 percent) (RR, 2.06 [CI, 0.88 to 4.84]).

This study reported no results for symptomatic stones, radiographically detected stones, stone recurrence rate, or stone growth as isolated outcomes (Appendix D, Table 6; Appendix E, Table 6a).

Other Clinical Outcomes. This trial did not report results for any other clinical health outcomes (Appendix E, Tables 6b–c).

Subgroup Results. The effect of magnesium on risk of recurrent stones relative to placebo and relative to thiazide appeared similar at 650 mg/day and 1300 mg/day. Compared wth 45.2 percent of individuals assigned to placebo and 14.3 percent of individuals assigned to thiazide who experienced a recurrent stone, the proportion with a recurrent stone was 26.7 percent in the magnesium 650 mg/day group (p=0.15 vs. placebo and p=0.20 vs. thiazide) and 33.3 percent in the 1300 mg/day group (p=0.41 vs. placebo and p=0.08 vs. thiazide), respectively.

This study reported no efficacy outcomes within subgroups defined by demographic or comorbid characteristics, or by characteristics of stone history.

Adherence to Assigned Treatment. The study reported that medication compliance was assessed by regular pill counts, but reported no results of these assessments.

### Thiazide Diuretic plus Citrate Versus Thiazide Monotherapy

#### Study Characteristics

Study Design. One trial met all eligibility criteria and randomized participants with recurrent kidney stones (n=100) to thiazide plus citrate versus thiazide monotherapy58 (Appendix C, Tables 2–3). This trial was published in a peer-reviewed English-language journal. It utilized a parallel group design. Mean study duration was 36 months.

Treatment Groups. Participants were randomized to hydrochlorothiazide 50 mg/day plus potassium citrate 20 mEq/day versus hydrochlorothiazide 50 mg/day monotherapy (Appendix C, Tables 2–3). The study reported no information regarding dietary co-interventions, including whether all participants were advised to increase fluid intake.

Outcome Measures. This trial reported a composite outcome of stone recurrence defined either by stone passage or removal or by radiographic stone detection by x-rays scheduled every 6 months. The study reported no results for recurrent symptomatic stones, for recurrent stones detected only by scheduled radiographic imaging, or for change in stone size.

#### Participant Characteristics

Demographics. The study included participants between 18 and 65 years of age, but reported no mean or median age (Appendix C, Tables 2–3). Nor did the study report information on gender distribution, race, or ethnicity. It was conducted in Europe.

Medical History. The study reported no information on baseline weight, BMI, or the prevalence of obesity (Appendix C, Tables 2–3). It excluded participants with undefined abnormal kidney function or morphology, but reported no measure of baseline renal function. The study also excluded patients with biochemical abnormalities or other conditions that would predispose to stone disease, but did not report prevalence of previous bariatric surgery, solitary kidney, renal transplant, coronary artery disease, diabetes, hypertension, or pregnancy.

Stone History. This trial included only individuals with recurrent calcium oxalate stones, including at least two stones in the past 3 years (Appendix C, Tables 2–3). The study did not report whether participants had residual stones.

Baseline Biochemistry. The study did not report how the urine utilized for biochemical measurements was collected. Among participants randomized to thiazide plus citrate versus thiazide alone, 35 percent had hypercalciuria, 15 percent had hypocitraturia, 4 percent had hyperuricosuria, and 1 percent had hyperoxaluria (Appendix H, Tables 2–3). No mean levels were reported for any baseline urine biochemical measure or for urine volume.

#### Study Quality

We rated the study as fair quality (Appendix C, Table 8). Allocation concealment was unclear and the study reported no information regarding blinding. However, the study performed intention to treat analysis and reported that there were no withdrawals.

#### Efficacy Outcomes

Stone Recurrence. The risk of a composite stone recurrence did not differ significantly between individuals randomized to thiazide plus citrate versus thiazide alone (30.0 vs. 32.0 percent; RR, 0.94 [CI, 0.52 to 1.68]) (Appendix D, Tables 2–3). The study reported no results for recurrent symptomatic stones, for recurrent stones detected only by scheduled radiographic imaging, or for change in stone size (Appendix E, Tables 2a and 3a).

Other Clinical Outcomes. This study reported no difference in risk of extracorporeal lithotripsy between treatment groups, at 8.0 percent in both. This study reported results for no other clinical health outcomes (Appendix E, Tables 2b–c and 3b–c).

Subgroup Results. This trial reported no efficacy outcomes within subgroups defined by treatment duration, participant demographic or comorbid characteristics, or by characteristics of stone history. Because the study did not describe any dietary co-interventions, subgroup analyses based on these factors were not feasible.

Adherence to Assigned Treatment. This study reported no adherence information.

### Thiazide Diuretic plus Allopurinol Versus Thiazide Monotherapy

#### Study Characteristics

Study Design. One trial met all eligibility criteria and randomized participants with nephrolithiasis (n=50) to a thiazide diuretic plus allopurinol versus thiazide diuretic monotherapy41 (Appendix C, Tables 2 and 4). This study was published in a peer-reviewed English-language journal. While it reported that it was randomized, it did not report an adequate method of random allocation of treatment assignment. The study utilized a parallel group design, but also compared historical pretreatment with post-treatment stone recurrence rates. Mean study duration was 36 months.

Treatment Groups. This study randomized 50 participants to indapamide 2.5 mg/day plus allopurinol 300 mg/day versus indapamide 2.5 mg/day alone (Appendix C, Tables 2 and 4). In addition, participants in both treatment groups were advised to increase fluid intake, and to decrease dietary intake of oxalate, sodium, calcium, and purine.

Outcome Measures. This trial reported a composite outcome of stone recurrence defined either by stone passage or removal or by radiographic stone detection by x-rays scheduled every 6 to 12 months. The study reported no results for recurrent symptomatic stones, for recurrent stones detected only by scheduled radiographic imaging, or for change in stone size.

#### Participant Characteristics

Demographics. The mean age of study participants was 46 years and men constituted 78 percent of all patients randomized (Appendix C, Tables 2 and 4). The study reported no data for ethnicity or race. It was conducted in Europe.

Medical History. Mean baseline weight was 72.8 kg (Appendix C, Tables 2 and 4). Participants were neither included nor excluded based on presence of chronic kidney disease and its prevalence was not reported. Mean serum creatinine was 1.0 mg/dL. The study excluded participants with disorders that could predispose them to kidney stones, limiting enrollment to participants with “idiopathic” stones. Otherwise, it did not report prevalence of previous bariatric surgery, solitary kidney, renal transplant, coronary artery disease, diabetes, or pregnancy.

Stone History. The study included only individuals with recurrent calcium oxalate stones, including at least one in the past 3 years (Appendix C, Tables 2 and 4). It excluded participants with residual stones at baseline (ascertained by renal ultrasound and intravenous pyelography).

Baseline Biochemistry. The study based urine biochemistry measures on 24-hour urine collections. The study enrolled only participants with hypercalciuria and reported no information on the baseline prevalence of hyperoxaluria, hyperuricosuria, or hypocitraturia. Mean baseline urine calcium was 412 mg/24 hrs, mean oxalate was 31 mg/24 hrs, mean uric acid was 731 mg/24 hrs, mean sodium was 4828 mg/24 hrs, mean citrate was 521 mg/24 hrs (range 348 to 564, n=2 trials), and mean baseline urine volume was 1.88 liters/24 hrs (Appendix H, Table 2). The study indicated that it obtained results for calcium-oxalate supersaturation, calcium-phosphate supersaturation, and uric acid supersaturations, but it did not report them.

#### Study Quality

This study was rated fair quality (Appendix C, Table 8). Allocation concealment was unclear and the study was conducted as open label. Analysis was not conducted as intention to treat. Withdrawals were adequately reported as 14 percent.

#### Efficacy Outcomes

Stone Recurrence. Risk of composite stone recurrence did not differ between the thiazide plus allopurinol group and the thiazide only group (12.5 vs. 15.8 percent; RR, 0.79 [CI, 0.18 to 3.49]) (Appendix D, Tables 2 and 4). We judged strength of evidence for this comparison and outcome as insufficient because of the small number of recurrent stone events and because the wide confidence intervals could not exclude either a clinically significant benefit or harm. This study reported no results for symptomatic stone recurrence, recurrence based only radiographic detection, recurrence rates, or stone growth (Appendix D, Tables 2 and 4; Appendix E, Tables 2a and 4a).

Other Clinical Outcomes. This study reported no results for any other clinical health outcomes (Appendix E, Tables 2b–c and 4b–c).

Subgroup Results. This trial reported no efficacy outcomes within subgroups defined by participant demographic or comorbid characteristics, or by characteristics of stone history. Because all participants in this trial had a history of recurrent calcium stones and received the same dietary co-intervention, no subgroup analyses by these factors were feasible.

Adherence to Assigned Treatment. This study reported no adherence information.

## Key Question 5 In adults with a history of nephrolithiasis, what is the evidence that pharmacological therapies to reduce risk of recurrent stone episodes are associated with adverse effects?

### Overview

Adverse effects assessed by withdrawals and withdrawals due to adverse effects were widely variable between trials, even for studies of the same pharmacological treatments. Other adverse events reporting was poor. We identified virtually no additional withdrawal or adverse events data comparing pharmacological treatment with control or placebo treatment from RCTs of 3 to less than 12 months in duration to prevent stone recurrence, those that reported only biochemical efficacy data, or from prospective cohort studies.

### Thiazide Diuretics Versus Placebo or Control

In seven eligible RCTs of at least 1 year in duration, 17 percent (range 0 to 59) of participants randomized to thiazide withdrew versus 8 percent (range 0 to 38) of those assigned to placebo or control41,47–50,52,58 (Appendix G, Table 2). Eight percent (range 0 to 29) of participants randomized to thiazide withdrew due to adverse events versus 1 percent (range 0 to 4) of those assigned to placebo or control. Four of seven studies reported adverse events as a composite outcome.47,49,50,52 Adverse events in these different composite measures included orthostatic reactions, gastrointestinal upset, erectile dysfunction, fatigue and muscle symptoms, though no two studies reported the same list. Otherwise, no individual adverse event (e.g., hypokalemia, hypotension) was reported in more than a single individual in any trial.

We identified no additional withdrawal or adverse events data comparing thiazide diuretics with control or placebo from RCTs of 3 to less than 12 months in duration to prevent stone recurrence, RCTs of 3 months or longer that reported only biochemical efficacy data, or from prospective cohort studies of 3 months or longer.

### Citrates Versus Placebo or Control

In five eligible RCTs of at least 1 year in duration, 25 percent of randomized participants withdrew, and 7 percent withdrew due to adverse events43–45,59,63 (Appendix G, Table 3). Among the four of these trials that reported results separately by treatment group, 36 percent (range 21 to 48) of participants randomized to citrate withdrew versus 20 percent (range 8 to 31) of those assigned to placebo or control.43,44,59,63 Further, 15 percent (range 7 to 21) of participants randomized to citrate withdrew due to adverse events versus 2 percent (range 0 to 3) of those assigned to placebo or control. In two trials reporting, incidence of any adverse event occurred in 24 percent of participants randomized to citrate versus in none of those assigned to placebo or control.59,63 Four trials reported incidence of gastrointestinal complaints, which occurred in 26 percent (range 16 to 42) of participants randomized to citrate and 17 percent (range 0 to 39) of those assigned to placebo or control.43–45,59

We identified no additional withdrawal or adverse events data comparing citrates with control or placebo treatment from RCTs of 3 to less than 12 months in duration to prevent stone recurrence, RCTs of 3 months or longer that reported only biochemical efficacy data, or from prospective cohort studies of 3 months or longer.

### Allopurinol Versus Placebo or Control

Among four eligible RCTs of at least one year in duration,37–40 two reported withdrawals, in which 31 percent (range 19 to 37) of participants randomized to allopurinol withdrew versus 42 percent (range 14 to 57) of those assigned to placebo37,38 (Appendix G, Table 4). In data limited to these same two trials, 4 percent (range 3 to 6) of participants randomized to allopurinol withdrew due to adverse events versus 8 percent (range 6 to 9) of those assigned to placebo. No trials reported incidence of any adverse event, and only two reported specific adverse events. Reported adverse events included rash in two or fewer participants per treatment group in two trials,37,38 and, in one trial, acute gout in 5 percent and leukopenia in 2 percent of the allopurinol group, but not reported in the placebo group.38

In one additional prospective study that compared allopurinol with control, but in which it was unclear whether participants were randomly assigned, withdrawals were reported in 6 percent of those treated with allopurinol but no withdrawal data were reported for the control group.76 Similarly, this study reported rash in 6 percent of participants in the allopurinol group but did not report whether rash occurred in the control group. We identified no additional withdrawal or adverse events data comparing allopurinol with control or placebo treatment from RCTs of 3 to less than 12 months in duration to prevent stone recurrence, RCTs of 3 months or longer that reported only biochemical efficacy data, or from prospective cohort studies of 3 months or longer.

### Acetohydroxamic Acid Versus Placebo

In three eligible RCTs of at least one year in duration, 59 percent (range 30 to 64, n=3 trials) of participants randomized to AHA withdrew versus 46 percent (range 31 to 73, n=2 trials) of those assigned to placebo60,61 (Appendix G, Table 5). While all three trials reported withdrawals due to adverse events in participants randomized to AHA (range 10 to 27 percent), only two of them reported withdrawals due to adverse events in those randomized to placebo (5 to 6 percent).60,61 All three trials reported results for incidence of any adverse event, which occurred in 64 percent (range 45 to 78) of participants randomized to AHA compared with 32 percent (range 5 to 49) of those assigned to placebo. Anemia and headache were each reported in two trials, with anemia occurring in 2 to 25 percent of AHA participants and in 0 to 12 percent of those assigned to placebo,60,61 and headache occurring in 5 to 9 percent of AHA participants,60,61 and, in the only study reporting, in 4 percent of those assigned placebo.61 Additional adverse events reported included alopecia (9 vs. 2 percent in 1 trial),61 tremulousness (25 percent, reported only for the AHA group in 1 trial),62 deep vein thrombosis (16 percent, reported only for the AHA group in 1 trial),62 and phlebitis (2 percent in both treatment groups, reported in 1 trial).61

We identified no additional withdrawal or adverse events data comparing acetohydroxamic acid with control or placebo treatment from RCTs of 3 to less than 12 months in duration to prevent stone recurrence, RCTs of 3 months or longer that reported only biochemical efficacy data, or from prospective cohort studies of 3 months or longer.

### Magnesium Versus Placebo

In the single eligible RCT of at least 1 year in duration, 18 percent of participants randomized to magnesium withdrew versus 17 percent of those assigned placebo47 (Appendix G, Table 6). Thirteen percent of participants randomized to magnesium 1300 mg/day withdrew due to adverse events (all due to diarrhea) versus 3 percent of those assigned to placebo (all due to gastrointestinal upset). The study did not report any withdrawals due to adverse events in the magnesium 650 mg/day group. The study did not report the proportion of participants with any or with specific types of adverse events, overall or by treatment group.

We identified no additional withdrawal or adverse events data comparing magnesium with control or placebo treatment from RCTs of 3 to less than 12 months in duration to prevent stone recurrence, RCTs of 3 months or longer that reported only biochemical efficacy data, or from prospective cohort studies of 3 months or longer.

### Thiazide Plus Citrate

In a single eligible RCT, there were no withdrawals in either the thiazide plus citrate or thiazide treatment groups (Appendix G, Tables 2–3). The study did not report results for adverse events.

We identified no additional withdrawal or adverse events data comparing thiazide plus citrate with thiazide or control treatment from RCTs of 3 to less than 12 months in duration to prevent stone recurrence, RCTs of 3 months or longer that reported only biochemical efficacy data, or from prospective cohort studies of 3 months or longer.

### Thiazide Plus Allopurinol

In a single eligible RCT, withdrawals were reported in 4 percent of participants randomized to thiazide plus allopurinol, 24 percent of those assigned to thiazide, and 16 percent of those assigned to control (Appendix G, Tables 2 and 4). Withdrawals due to adverse events were reported in no participants randomized to thiazide plus allopurinol, 8 percent of those assigned to thiazide, and none of those assigned to control. The study did not report results for adverse events in participants randomized to thiazide plus allopurinol or to control. Hypokalemia and hypotension each were reported in one participant in the thiazide group.

We identified no additional withdrawal or adverse events data comparing thiazide plus citrate with thiazide or control treatment from RCTs of 3 to less than 12 months in duration to prevent stone recurrence, RCTs of 3 months or longer that reported only biochemical efficacy data, or from prospective cohort studies of 3 months or longer.

## Key Question 6 In adults with a history of nephrolithiasis being treated to prevent stone recurrence, do results of followup blood and urine biochemistry measures predict final health outcomes and intermediate stone outcomes?

### Overview

Although many RCTs reported results of followup biochemistry measures, most often based on 24-hour urine collections, none reported and compared subsequent stone recurrence outcomes between treatments stratified by followup biochemistry levels or by changes in these measures from pretreatment baseline. Therefore, eligible RCTs provided no direct data regarding whether followup biochemistry measures prospectively predict the effectiveness of ongoing treatment in preventing later stone recurrence.

However, RCT followup biochemistry data and recurrent stone outcomes data reported for treatment groups as a whole suggest that decreased urine calcium-oxalate supersaturation, uric acid supersaturation, and calcium-phosphate supersaturation might be able to predict reduced risk of subsequent stones with increased fluid intake46 and with at least one studied multicomponent diet intervention.51 As none of the eligible pharmacological RCTs reported followup urine supersaturation levels, no RCT data exist for whether changes in these measures may predict reduced risk of recurrent stones with drug treatment. Data from both diet and pharmacological RCTs suggest that followup urine calcium may have limitations as a predictor of stone recurrence. Though the association of a decline in urine calcium with reduced recurrent stone risk may be greatest in patients randomized to thiazide treatment, even in these trials the significantly reduced urine calcium in two trial control groups suggests its limited specificity.41,48 Further, its improvement only in the subgroup of participants with baseline hypercalciuria in one trial may be indicative of regression to the mean.48,65 We could not determine whether a reduction in serum or urine uric acid levels may be able to predict allopurinol effectiveness in reducing stone recurrence.37

### Dietary Therapy Trials

Five eligible RCTs that compared an intervention diet with a control diet reported both followup urine biochemistry measures (range 1 week to 12 months) and recurrent stone outcomes (Appendix H, Table 1).46,51,53,56,57 Among these, one trial that compared increased fluid intake with no treatment and reported a reduction in composite stone recurrence after 5 years of followup also reported significantly increased urine volume and significantly decreased urine calcium-oxalate supersaturation and uric acid supersaturation at one year versus baseline in the increased fluid intake group only.46 In addition, calcium-phosphate supersaturation was significantly decreased only in the increased fluid group at all followup time points from 2 to 5 years after baseline. These data suggest that changes in these urine measures might predict risk of subsequent recurrent stones.

A trial that compared a low animal protein diet with a high fiber diet and a control group showed no significant change from baseline in urinary volume, or urine calcium, oxalate, citrate or sodium in any of the three treatment groups.56 Another trial compared a low animal protein, low sodium, and normal to high calcium diet versus a low calcium diet.51 This study reported a greater reduction versus baseline in levels of urinary sodium, oxalate, calcium-oxalate product, and calcium-oxalate supersaturation in participants assigned the multicomponent diet than in those assigned a low calcium diet. There was no difference in the change from baseline between treatment groups in urinary calcium or urine volume. Next, a trial that compared a diet low in animal protein and purine, and high in fiber and bran with a usual diet reported no difference between treatment groups in followup urine volume, calcium, oxalate or uric acid.57 These three trials were heterogeneous in their interventions, stone outcomes and followup urine biochemistries except that all reported no change in followup urine calcium or urine volume. The one trial that reported a significant reduction in recurrent stones with the intervention diet was the only trial that reported reductions in followup urine oxalate, sodium, calcium-oxalate product, and calcium-oxalate supersaturation.51 The two trials that reported no reduction in stone recurrence56 and an increase in risk of stone recurrence,57 respectively, both reported no change in followup urine oxalate and neither reported results for urine calcium-oxalate product or any urine supersaturation measure. Collectively, these trials suggest that for these diet interventions followup urine calcium is unlikely to be a useful predictor of stone recurrence and reductions in urine oxalate, calcium-oxalate product, and calcium-oxalate supersaturation might better predict reduced risk of subsequent recurrent stones.

Last, a trial that compared an extensive biochemical evaluation and tailored diet with a limited evaluation and empiric diet reported that the tailored diet group had an increase compared with baseline in urine calcium and magnesium, and no change in urine oxalate, citrate, and urine volume.53 Because the tailored diet group followup urine biochemistries were derived from participants assigned a heterogeneous mix of diet instructions, with no followup biochemistry data reported separately by biochemical or dietary subgroups, and no followup biochemistry data reported for the control group, it was not possible to correlate the reported urine changes with stone outcomes.

Since a reduction in stone recurrence did not occur in all trials that reported an increase in urine citrate, the value of this followup biochemical measure for predicting reduced stone recurrence with citrate or control treatment is unknown.

No trials reported results for recurrent stones outcomes as a function of the followup level or the change from baseline in any biochemistry measure.

### Pharmacological Therapy Trials

#### Thiazide Versus Placebo or Control

Six eligible RCTs that compared thiazide with placebo or control reported both followup urine biochemistry measures (range 6 to 24 months) and recurrent composite or radiographic stone outcomes (Appendix H, Table 2).41,48,49,52,58 Among these six trials, five reported significantly reduced urinary calcium at followup in participants assigned to thiazide,41,47,49,52,58 and the other trial reported a significant reduction in followup urinary calcium only in the subgroup of thiazide participants that had high baseline urine calcium.48 Though thiazides also significantly reduced risk of recurrent composite calcium stones, it is uncertain whether a reduction in urine calcium in treated patients will predict future reduction in risk of stone recurrence. No trials reported whether differences in followup urine calcium levels within the thiazide treatment group participants were associated with differences in risk of recurrent stones. Further, one of these six thiazide trials reported a significant reduction in urinary calcium in participants assigned to its control group overall,41 and a second trial reported a significant reduction only in the subgroup of controls that had high baseline urine calcium.48 These results suggest that a reduction in urine calcium is a nonspecific marker and could represent regression to the mean, a statistical group phenomenon in which a variable initially measured as extreme (e.g., hypercalciuria) tends to be closer to average on remeasurement.65 The only trial that reported followup results for urine calcium-oxalate product found a significant reduction from the baseline level in both thiazide and placebo treatment groups.52 No other followup biochemistry measure reported was consistently changed from baseline in these trials, though none of the trials reported followup results for calcium-oxalate supersaturation or calcium-phosphate supersaturation.

#### Citrate Versus Placebo or Control

Three eligible RCTs that compared citrate with placebo or control reported both followup urine biochemistry measures (range 3 to 36 months) and recurrent composite or radiographic stone outcomes (Appendix H, Table 3).43,44,59 However, none reported results for recurrent stones outcomes as a function of the followup level or the change from baseline in any biochemistry measure. All trials reported significantly increased urine citrate at followup in participants randomized to citrate, but not in those assigned to control treatment. One trial that utilized potassium-magnesium-citrate also reported increased followup levels of urine potassium, magnesium and oxalate in the citrate group only,44 and another trial that utilized potassium citrate reported an increased followup level of urine potassium and pH, again in the citrate group only.43 Though no followup biochemistry measure other than urine citrate was reported in all three citrate trials (and urine calcium-oxalate supersaturation, uric acid supersaturation, or calcium-phosphate supersaturation were not reported in any trials), among results reported, no other urine biochemistry measure was changed from baseline in any trial citrate group. Further, no trial reported a significant change in any followup biochemical measure in its control group. While citrate treatment consistently increased urinary citrate levels, the three trials were inconsistent in stone recurrence outcomes, with two trials reporting a significant reduction in composite stone recurrence versus control (pooled RR, 0.26 [CI, 0.14 to 0.48])43,44 and the third reporting no difference in risk of radiographic stone recurrence versus control (RR, 0.95 [CI, 0.62 to 1.44]).59 Since a reduction in stone recurrence did not occur in all trials that reported an increase in urine citrate, accuracy of an increase in urinary citrate for predicting reduced stone recurrence with citrate or control treatment is unknown. From the limited data available, we could not determine whether this pattern was in part attributable to differences in the baseline prevalence of hypocitraturia between trials.

#### Allopurinol Versus Placebo or Control

Two eligible RCTs that compared allopurinol with placebo or control reported both followup blood and/or urine biochemistry measures and recurrent composite stone outcomes (Appendix H, Table 4).37,40 Both trials were limited to participants with calcium stones. In one trial, relative to placebo, participants randomized to allopurinol had a significant reduction after 3 months in serum and urine uric acid levels but not in urine calcium.37 In 24 months followup, this study also reported a nonsignificant reduction in risk of recurrent composite stones (RR, 0.49 [CI, 0.19 to 1.23]). In a second trial that collected followup biochemistry measures every 3 months but didn’t indicate the time at which those reported were collected, there was no significant difference between treatment groups in followup serum uric acid, urine calcium, or urine uric acid levels.40 In 36 months followup, the rate of recurrent composite stones was not lower in the allopurinol group (0.96 per person year) than the placebo group (0.66 per person year). Considering both trials, we could not determine whether a reduction in uric acid levels might predict allopurinol effectiveness in reducing stone recurrence.

#### Acetohydroxamic Acid Versus Placebo

None of the three AHA trials reported followup blood and/or urine biochemistry measures.

#### Magnesium Versus Placebo

The one eligible RCT that compared magnesium with placebo reported both followup urine biochemistry measures and recurrent composite stone outcomes (Appendix H, Table 5).47 Participants randomized to magnesium had a significant increase in mean urine magnesium level at 24 months (148 vs. 97 mg/24 hrs, p<0.001) compared with no significant change from baseline in the placebo group. There was no change from baseline to followup in either treatment group in mean urine calcium, oxalate, or uric acid levels. In 36 months followup, the trial reported no significant difference in risk of composite recurrent stones between participants in the magnesium and placebo treatment groups overall. It did not report stone recurrence results for the period after the first reported followup biochemistry measurements, let alone compared between treatments or stratified by followup magnesium levels or by changes in magnesium levels from pretreatment baseline.