# References

1 Pearle MS, Calhoun EA, Curhan GC. Urologic diseases in America project: urolithiasis. J Urol. Mar. 2005;173(3):848-57. [pmid: 15711292].
2 Stamatelou KK, Francis ME, Jones CA, et al. Time trends in reported prevalence of kidney stones in the United States: 1976–1994. Kidney International. May. 2003;63(5):1817-23. [pmid: 12675858].
3 Penniston KL, McLaren ID, Greenlee RT, et al. Urolithiasis in a rural Wisconsin population from 1992 to 2008: narrowing of the male-to-female ratio. J Urol. May. 2011;185(5):1731-6. [pmid: 21420112].
4 Scales CD Jr, Curtis LH, Norris RD, et al. Changing gender prevalence of stone disease. J Urol. Mar. 2007;177(3):979-82. [pmid: 17296391].
5 Lieske JC, Pena de la Vega LS, Slezak JM, et al. Renal stone epidemiology in Rochester, Minnesota: an update. Kidney International. Feb. 2006;69(4):760-4. [pmid: 16518332].
6 Boyce CJ, Pickhardt PJ, Lawrence EM, et al. Prevalence of urolithiasis in asymptomatic adults: objective determination using low dose noncontrast computerized tomography. J Urol. Mar. 2010;183(3):1017-21. [pmid: 20092842].
7 Uribarri J, Oh MS, Carroll HJ. The first kidney stone. Ann Intern Med. Dec. 15. 1989;111(12):1006-9. [pmid: 2688503].
8 Saigal CS, Joyce G, Timilsina AR. Direct and indirect costs of nephrolithiasis in an employed population: opportunity for disease management?. Kidney International. Oct. 2005;68(4):1808-14. [pmid: 16164658].
9 Moe OW. Kidney stones: pathophysiology and medical management. Lancet. Jan. 28. 2006;367(9507):333-44. [pmid: 16443041].
10 Wagner CA, Mohebbi N. Urinary pH and stone formation. J Nephrol. Nov–Dec. 2010;23(Suppl 16):S165-9. [pmid: 21170875].
11 Levy FL, Adams-Huet B, Pak CY. Ambulatory evaluation of nephrolithiasis: an update of a 1980 protocol. American Journal of Medicine. Jan. 1995;98(1):50-9. [pmid: 7825619].
12 Attanasio M. The genetic components of idiopathic nephrolithiasis. Pediatr Nephrol. Mar. 2011;26(3):337-46. [pmid: 20563734].
13 Curhan GC, Willett WC, Knight EL, et al. Dietary factors and the risk of incident kidney stones in younger women: Nurses’ Health Study II. Arch Intern Med. Apr. 26. 2004;164(8):885-91. [pmid: 15111375].
14 Curhan GC, Willett WC, Rimm EB, et al. A prospective study of dietary calcium and other nutrients and the risk of symptomatic kidney stones. New England Journal of Medicine. Mar. 25. 1993;328(12):833-8. [pmid: 8441427].
15 Curhan GC, Willett WC, Speizer FE, et al. Comparison of dietary calcium with supplemental calcium and other nutrients as factors affecting the risk for kidney stones in women. Ann Intern Med. Apr. 1. 1997;126(7):497-504. [pmid: 9092314].
16 Taylor EN, Stampfer MJ, Curhan GC. Dietary factors and the risk of incident kidney stones in men: new insights after 14 years of follow-up. J Am Soc Nephrol. Dec. 2004;15(12):3225-32. [pmid: 15579526].
17 Taylor EN, Curhan GC. Fructose consumption and the risk of kidney stones. Kidney International. Jan. 2008;73(2):207-12. [pmid: 17928824].
18 Mollerup CL, Vestergaard P, Frokjaer VG, et al. Risk of renal stone events in primary hyperparathyroidism before and after parathyroid surgery: controlled retrospective follow up study. BMJ. Oct. 12. 2002;325(7368):807. [pmid: 12376441].
19 Taylor EN, Stampfer MJ, Curhan GC. Obesity, weight gain, and the risk of kidney stones. JAMA. Jan. 26. 2005;293(4):455-62. [pmid: 15671430].
20 Taylor EN, Stampfer MJ, Curhan GC. Diabetes mellitus and the risk of nephrolithiasis. Kidney International. Sep. 2005;68(3):1230-5. [pmid: 16105055].
21 Kramer HM, Curhan G. The association between gout and nephrolithiasis: the National Health and Nutrition Examination Survey III, 1988–1994. American Journal of Kidney Diseases. Jul. 2002;40(1):37-42. [pmid: 12087559].
22 Ciacci C, Spagnuolo G, Tortora R, et al. Urinary stone disease in adults with celiac disease: prevalence, incidence and urinary determinants. J Urol. Sep. 2008;180(3):974-9. [pmid: 18639267].
23 Fink HA, Akornor JW, Garimella PS, et al. Diet, fluid, or supplements for secondary prevention of nephrolithiasis: a systematic review and meta-analysis of randomized trials. European Urology. Jul. 2009;56(1):72-80. [pmid: 19321253].
24 Pearle MS, Roehrborn CG, Pak CY. Meta-analysis of randomized trials for medical prevention of calcium oxalate nephrolithiasis. Journal of Endourology. Nov. 1999;13(9):679-85. [pmid: 10608521].
25 Escribano J, Balaguer A, Pagone F, et al. Pharmacological interventions for preventing complications in idiopathic hypercalciuria. Cochrane Database of Systematic Reviews. 2009;(1):CD004754. [pmid: 19160242].
26 Kairaitis L. Caring for Australians with Renal I. The CARI guidelines. Kidney stones: prevention of recurrent calcium nephrolithiasis. Nephrology. Feb. 2007;12(Suppl 1):S11-20. [pmid: 17316271].
27 Mattle D, Hess B. Preventive treatment of nephrolithiasis with alkali citrate--a critical review. Urological Research. May. 2005;33(2):73-9. [pmid: 15875173].
28 Becker G. Caring for Australians with Renal I. The CARI guidelines. Kidney stones: cystine stones. Nephrology. Feb. 2007;12(Suppl 1):S4-10. [pmid: 17316277].
29 Becker G. Caring for Australians with Renal I. The CARI guidelines. Kidney stones: uric acid stones. Nephrology. Feb. 2007;12(Suppl 1):S21-5. [pmid: 17316272].
30 Turk C KT, Petrik A, Sarica K, Straub M, Steitz C. Guidelines on Urolithiasis. March. 2011. www.uroweb.org/professional-resources/guidelines/.
31 Schulz KF, Grimes DA. Allocation concealment in randomised trials: defending against deciphering. Lancet. Feb. 16. 2002;359(9306):614-8. [pmid: 11867132].
32 Higgins JP, Green S. Cochrane Handbook for Systematic Reviews of Interventions, Version 5.1.0. Collaboration TC. 5.1.0 ed. 2011.
33 Santaguida PR. PR McMaster Quality Assessment Scale of Harms (McHarm) for primary studies: manual for use of the McHarm. Hamilton, Canada. McMaster University. 2011.
34 RevMan RMcpV. Copenhagen. The Nordic Cochrance Centre of the Cochrane Collaboration. 2008.
35 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
36 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health Care Program. Journal of Clinical Epidemiology. May. 2010;63(5):513-23. [pmid: 19595577].
37 Ettinger B, Tang A, Citron JT, et al. Randomized trial of allopurinol in the prevention of calcium oxalate calculi. New England Journal of Medicine. Nov. 27. 1986;315(22):1386-9. [pmid: 3534570].
38 Smith MJ. Placebo versus allopurinol for renal calculi. Journal of Urology. Jun. 1977;117(6):690-2. [pmid: 875139].
39 Robertson WG PM, Sepby PL, Williams RE, Clark P, Chisholm GD. A multicentre trial to evaluate three treatments for recurrent idiopathic calcium stone disease - a preliminary report. Plenum Press. 1986.
40 Miano L, Petta S, Galatioto GP, et al. A placebo controlled double-blind study of allopurinol in severe recurrent idiopathic renal lithiasis. Schwille PO, Smith LH, Robertson WG, Vahlensieck W, editors. Urolithiasis and Related Clinical Research. New York. Plenum Press. 1985:521-4.
41 Borghi L, Meschi T, Guerra A, et al. Randomized prospective study of a nonthiazide diuretic, indapamide, in preventing calcium stone recurrences. Journal of Cardiovascular Pharmacology. 1993;22(Suppl 6):S78-86. [pmid: 7508066].
42 Sarica K, Inal Y, Erturhan S, et al. The effect of calcium channel blockers on stone regrowth and recurrence after shock wave lithotripsy. Urological Research. Jun. 2006;34(3):184-9. [pmid: 16463053].
43 Barcelo P, Wuhl O, Servitge E, et al. Randomized double-blind study of potassium citrate in idiopathic hypocitraturic calcium nephrolithiasis. Journal of Urology. Dec. 1993;150(6):1761-4. [pmid: 8230497].
44 Ettinger B, Pak CY, Citron JT, et al. Potassium-magnesium citrate is an effective prophylaxis against recurrent calcium oxalate nephrolithiasis. Journal of Urology. Dec. 1997;158(6):2069-73. [pmid: 9366314].
45 Soygur T, Akbay A, Kupeli S. Effect of potassium citrate therapy on stone recurrence and residual fragments after shockwave lithotripsy in lower caliceal calcium oxalate urolithiasis: a randomized controlled trial. Journal of Endourology. Apr. 2002;16(3):149-52. [pmid: 12028622].
46 Borghi L, Meschi T, Amato F, et al. Urinary volume, water and recurrences in idiopathic calcium nephrolithiasis: a 5-year randomized prospective study. Journal of Urology. Mar. 1996;155(3):839-43. [pmid: 8583588].
47 Ettinger B, Citron JT, Livermore B, et al. Chlorthalidone reduces calcium oxalate calculous recurrence but magnesium hydroxide does not. Journal of Urology. Apr. 1988;139(4):679-84. [pmid: 3280829].
48 Ala-Opas M, Elomaa I, Porkka L, et al. Unprocessed bran and intermittent thiazide therapy in prevention of recurrent urinary calcium stones. Scandinavian Journal of Urology & Nephrology. 1987;21(4):311-4. [pmid: 2832935].
49 Laerum E, Larsen S. Thiazide prophylaxis of urolithiasis. A double-blind study in general practice. Acta Medica Scandinavica. 1984;215(4):383-9. [pmid: 6375276].
50 Ahlstrand, editor. Prophylactic treatment of calcium stone formers with hydrochlorothiazide and magnesium. 1995. Edsbruk. Akademitryck AB.
51 Borghi L, Schianchi T, Meschi T, et al. Comparison of two diets for the prevention of recurrent stones in idiopathic hypercalciuria. New England Journal of Medicine. Jan. 10. 2002;346(2):77-84. [pmid: 11784873].
52 Scholz D, Schwille PO, Sigel A. Double-blind study with thiazide in recurrent calcium lithiasis. J Urol. 1982:903-7. [pmid: 7176047].
53 Kocvara R, Plasgura P, Petrik A, et al. A prospective study of nonmedical prophylaxis after a first kidney stone. BJU International. Sep. 1999;84(4):393-8. [pmid: 10468751].
54 Di Silverio F, Ricciuti GP, D’Angelo AR, et al. Stone recurrence after lithotripsy in patients with recurrent idiopathic calcium urolithiasis: Efficacy of treatment with Fiuggi water. European Urology. 2000:145-8. [pmid: 10705191].
55 Shuster J, Jenkins A, Logan C, et al. Soft drink consumption and urinary stone recurrence: a randomized prevention trial. Journal of Clinical Epidemiology. Aug. 1992;45(8):911-6. [pmid: 1624973].
56 Dussol B, Iovanna C, Rotily M, et al. A randomized trial of low-animal-protein or high-fiber diets for secondary prevention of calcium nephrolithiasis. Nephron. 2008;110(3):c185-94. [pmid: 18957869].
57 Hiatt RA, Ettinger B, Caan B, et al. Randomized controlled trial of a low animal protein, high fiber diet in the prevention of recurrent calcium oxalate kidney stones. American Journal of Epidemiology. Jul. 1. 1996;144(1):25-33. [pmid: 8659482].
58 Fernández-Rodríguez A, Arrabal-Martín M, García-Ruiz MJ, et al. The role of thiazides in the prophylaxis of recurrent calcium lithiasis. Actas urologicas espanolas. 2006:305-9. [pmid: 16749588].
59 Hofbauer J, Hobarth K, Szabo N, et al. Alkali citrate prophylaxis in idiopathic recurrent calcium oxalate urolithiasis--a prospective randomized study. British Journal of Urology. Apr. 1994;73(4):362-5. [pmid: 8199822].
60 Griffith DP, Khonsari F, Skurnick JH, et al. A randomized trial of acetohydroxamic acid for the treatment and prevention of infection-induced urinary stones in spinal cord injury patients. Journal of Urology. Aug. 1988;140(2):318-24. [pmid: 3294442].
61 Griffith DP, Gleeson MJ, Lee H, et al. Randomized, double-blind trial of Lithostat (acetohydroxamic acid) in the palliative treatment of infection-induced urinary calculi. European Urology. 1991;20(3):243-7. [pmid: 1726639].
62 Williams JJ, Rodman JS, Peterson CM. A randomized double-blind study of acetohydroxamic acid in struvite nephrolithiasis. New England Journal of Medicine. Sep. 20. 1984;311(12):760-4. [pmid: 6472365].
63 Premgamone A, Sriboonlue P, Disatapornjaroen W, et al. A long-term study on the efficacy of a herbal plant, Orthosiphon grandiflorus, and sodium potassium citrate in renal calculi treatment. Southeast Asian Journal of Tropical Medicine & Public Health. Sep. 2001;32(3):654-60. [pmid: 11944733].
64 Lojanapiwat B, Tanthanuch M, Pripathanont C, et al. Alkaline citrate reduces stone recurrence and regrowth after shockwave lithotripsy and percutaneous nephrolithotomy. International Braz J Urol. Sep–Oct. 2011;37(5):611-6. [pmid: 22099273].
65 Trochim W. Regression to the Mean. The Research Knowledge Base. Methods SR, editor. 2nd Edition. 2006.
66 Curhan GC, Willett WC, Speizer FE, et al. Twenty-four-hour urine chemistries and the risk of kidney stones among women and men. Kidney International. Jun. 2001;59(6):2290-8. [pmid: 11380833].
67 Curhan GC, Willett WC, Rimm EB, et al. Prospective study of beverage use and the risk of kidney stones. American Journal of Epidemiology. Feb. 1. 1996;143(3):240-7. [pmid: 8561157].
68 Curhan GC, Willett WC, Speizer FE, et al. Beverage use and risk for kidney stones in women. Ann Intern Med. Apr. 1. 1998;128(7):534-40. [pmid: 9518397].
69 Coll DM, Varanelli MJ, Smith RC. Relationship of spontaneous passage of ureteral calculi to stone size and location as revealed by unenhanced helical CT. AJR Am J Roentgenol. Jan. 2002;178(1):101-3. [pmid: 11756098].
70 Segura JW, Preminger GM, Assimos DG, et al. Ureteral Stones Clinical Guidelines Panel summary report on the management of ureteral calculi. The American Urological Association. J Urol. Nov. 1997;158(5):1915-21. [pmid: 9334635].
71 Gillen DL, Worcester EM, Coe FL. Decreased renal function among adults with a history of nephrolithiasis: a study of NHANES III. Kidney International. Feb. 2005;67(2):685-90. [pmid: 15673317].
72 Vupputuri S, Soucie JM, McClellan W, et al. History of kidney stones as a possible risk factor for chronic kidney disease. Ann Epidemiol. Mar. 2004;14(3):222-8. [pmid: 15036227].
73 Preminger GM, Tiselius H-G, Assimos DG, et al. 2007 guideline for the management of ureteral calculi. Journal of Urology. Dec. 2007;178(6):2418-34. [pmid: 17993340].
74 Juni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: empirical study. Int J Epidemiol. Feb. 2002;31(1):115-23. [pmid: 11914306].
75 Dussol B, Saveanu A, Rotily M, et al. Effects of low-animal protein or high-fiber diets on urine composition in calcium nephrolithiasis. [abstract no: PUB452]. J Am Soc Nephrol. 2004:857a.
76 Fellstrom B, Backman U, Danielson BG, et al. Allopurinol treatment of renal calcium stone disease. Br J Urol. 1985:375-9. [pmid: 4027505].