# Methods

## Topic Refinement

The nominator of this topic proposed questions addressing the effectiveness and harms of dietary and medical treatments for prevention of recurrent kidney stones. We drafted Key Questions with input from representatives of the nominating organization. We discussed the Key Questions and project scope with a panel of key informants including researchers and clinicians (urology, nephrology, and dietary), patients, and payers. Based in part on their input, we submitted a revised Key Question document for Agency for Healthcare Research and Quality (AHRQ) approval. AHRQ then posted this document on the Effective Health Care (EHC) Web site for 4 weeks for public comment.

## Comparative Effectiveness Review

After reviewing public comments with AHRQ and the nominator, we incorporated them as appropriate in a draft protocol. We then reviewed the draft protocol with a Technical Expert Panel (TEP) of researchers, clinicians, and representatives from the American Urological Association and the American College of Physicians. Based on TEP feedback, including on the relevance and scope of the review, we revised and finalized the protocol (including the Key Questions and proposed project methods) that ultimately was approved and posted by AHRQ on the EHC Web site.

## Criteria for Inclusion/Exclusion of Studies in the Review

We developed criteria for inclusion and exclusion of studies based on patient populations, interventions, outcome measures, and evidence relevant to the Key Questions.

## Population(s)

For all Key Questions, we restricted eligibility to studies published in full text in English that enrolled adults age 18 years or older with a history of one or more [underlined: past] kidney stone episodes. We excluded studies of children, and those that addressed acute pain management and treatment to promote expulsion of ureteral stones. Eligible studies could include patients with or without residual stones or stone fragments. In order to distinguish the effect of secondary prevention from lithotripsy, we excluded studies comprising participants who had undergone lithotripsy within 90 days prior unless participants were documented as stone free at baseline.

## Interventions

### Diet

For Key Questions 2 and 3, we restricted the review to studies that evaluated individual diet interventions (e.g., intake of fluids, calcium, animal protein, sodium, fruit and fiber, purine, oxalate, potassium, soft drinks, citrus, others) or multicomponent diets. We also included empiric dietary interventions as well as those tailored according to patient demographics, comorbid conditions, baseline diet, baseline urine or blood biochemical testing, and/or stone type.

### Pharmacological

For Key Questions 4 and 5, we restricted the review to studies that evaluated pharmacological agents currently approved by the U.S. FDA and available in the United States for prescription (e.g., hydrochlorothiazide, chlorthalidone, indapamide, potassium citrate, potassium magnesium citrate, sodium citrate, allopurinol, magnesium hydroxide, acetohydroxamic acid). We also considered as eligible trials of over-the-counter medications and supplements available in the United States and those that combined diet, pharmacological, over-the-counter, and/or supplement interventions.

For Key Questions 1 and 6, all of the above interventions were eligible.

### Comparators

For all Key Questions, eligible studies could have compared active treatment with placebo, usual care/no treatment, or with other active treatments, including combination treatment and comparisons versus the same active treatment at varying dosages. Active pharmacological comparators were restricted to those currently approved by the U.S. FDA or available over the counter in the United States.

### Outcomes

For Key Questions 1, 2, 4, and 6, we considered final clinical health outcomes as the most important measures of treatment benefit, including symptomatic stone recurrence, pain, urinary tract obstruction with acute renal failure, infection, morbidity related to treatment for a recurrent stone, emergency room visits or hospitalizations for treatment of recurrent stones (e.g., for renal colic, acute renal failure), quality of life (general or urologic), and end-stage renal disease.

Also for Key Questions 1, 2, 4, and 6, intermediate stone outcomes were considered the next most important measures of treatment benefit, including composite stone recurrence (combination of symptomatic recurrence or radiographically detected recurrence), stone recurrence detected only by scheduled radiographic imaging, and change in stone size.

For Key Questions 3 and 5, adverse effects included any reported by eligible trials (e.g., nausea, diarrhea, hypokalemia, weight change, hyperlipidemia, and hyperglycemia).

Measures of treatment adherence were those reported by the individual trials (e.g., self-report questionnaire, pill count, or as estimated by follow-up urine biochemical measures).

### Timing

Eligible studies had to include followup of at least 12 months for final clinical health outcomes (e.g., stone recurrence), intermediate stone outcomes, and adherence, and at least 3 months for adverse effects. We felt that followup of fewer than 12 months would not likely be sufficient for treatments to impact recurrent stone outcomes, and that shorter trials would more likely focus on treatments to assist in stone expulsion. However, we considered 3 months sufficient for most treatment-related adverse effects to manifest.

### Setting

We included studies conducted in all settings, including primary care, urology clinics, nephrology clinics, dietician clinics, or other specialty stone clinics. There were no geographic restrictions.

### Other Eligibility Criteria

For the Key Questions related to effectiveness, we limited eligibility to randomized control trials (RCTs) meeting the PICOTS criteria and published in full text and in English. We first applied the same requirements to the Key Questions related to adverse effects; however, these sources offered very limited adverse effects data. Thus, for pharmacological treatments we expanded eligibility to RCTs of nephrolithiasis of at least 3 months in duration that reported only blood or urine biochemical outcome measures but not final clinical health outcomes or intermediate stone outcomes. Further, we included prospective observational studies of at least 3 months in duration in cohorts of at least 100 patients being treated for secondary prevention of kidney stones. We did not evaluate these additional types of studies for adverse effects of dietary treatments under the assumptions that we were unlikely to find diet studies with similar compositions to those of eligible trials; that dietary adverse effects seemed low; and that the likelihood of finding reported adverse effects in lower quality diet studies was low.

Although limiting trials to those published in English is not ideal, previous research has documented little bias in systematic reviews limiting trials of medical treatments to those published in English.74

## Searching for the Evidence: Strategies for Identifying Relevant Studies

We identified evidence for this review by searching relevant bibliographic databases, abstracts and conference proceedings, and trial registries. The primary bibliographic database search utilized MEDLINE^®^ (January 1948 through the third week of November 2011) and the Cochrane Central Register of Controlled Trials (CENTRAL) (through the fourth quarter of 2011) to identify RCTs of treatments to prevent recurrent nephrolithiasis (Appendix A). Bibliographic database searches were supplemented by hand searching reference lists of included studies, previous systematic reviews, and relevant clinical guidelines. With Google Scholar, we performed forward citation searching of key included RCTs. We updated the literature search while the draft report was under public and peer review.

We searched several sources to identify unpublished RCTs, including ClinicalTrials.gov for relevant registered and completed trials, Web of Science for abstracts and conference proceedings, and industry scientific information packets for relevant regulatory documents and reports of conducted trials. Identified studies were then qualitatively evaluated and compared with published RCTs to assess potential outcomes-reporting bias.

## Data Abstraction and Data Management

We screened identified studies in two stages. First, two independent investigators reviewed titles and abstracts, marking them “include,” “exclude,” or “full text needed” if a determination could not be made based on available information. We resolved the few differences in triage by group discussion. For all articles not excluded during the first stage, two investigators acting as primary and secondary abstractors/evaluators then assessed the full text for eligibility and extracted and verified data respectively into pretested tables for abstraction and evidence. Extracted data fields included: author; publication year; subject inclusion and exclusion criteria; intervention and control regimens; followup duration; participant baseline demographics, comorbidities, urine and blood test results; stone characteristics; followup urine and blood test results; and event rates for final health outcomes, intermediate outcomes, adverse events, and adherence.

## Assessment of Methodological Quality of Individual Studies

Primary and secondary abstractors/evaluators also reviewed each included RCT for quality using criteria recommended by the Cochrane Collaboration. These criteria included an assessment of the risk of bias within each study by specifically evaluating: (1) adequacy of allocation concealment;31 (2) blinding methods (participant, investigator, and/or outcome assessor); (3) data completeness (inclusion of all randomized participants in outcomes analyses, i.e., intention-to-treat); and (4) whether reasons for dropouts/attrition were reported (to judge whether those reasons could be related to outcomes and were balanced between treatment groups.32 Based on this evaluation, we assigned studies individual ratings of good, fair, or poor (Appendix C, Tables 7–8). A rating of good generally indicated that the trial reported adequate allocation concealment, blinding, analysis by intention-to-treat, and that reasons for dropouts/attrition were reported. We rated studies as poor if the method of allocation concealment was inadequate or not defined, blinding was not defined, analysis by intention-to-treat was not utilized, and reasons for dropouts/attrition were not reported and/or there was a high rate of attrition. We used a subset of questions from the McHarm Scale to evaluate the quality of RCTs and observational cohort studies reporting adverse events.33 We resolved discrepancies in quality ratings by group discussion.

## Data Synthesis

We qualitatively synthesized and summarized extracted study data in evidence summary tables relevant to the Key Questions. We performed a quantitative meta-analysis of all main interventions and primary outcomes when the patient populations, interventions, and outcomes were clinically comparable. We analyzed data using Review Manager (RevMan) version 5.1 software.34 We used random effects models to generate pooled estimates of relative risks and 95 percent confidence intervals. We summarized statistical heterogeneity by using the I^2^ statistic (50 percent indicates moderate heterogeneity and 75 percent or greater indicates high heterogeneity.35

For analyses of pharmacological treatments, results were presented for each pharmacological class as a whole and separately for individual agents. We explored the feasibility of performing subgroup analyses for treatment efficacy and adverse events outcomes according to the following prespecified factors: patient demographic and comorbid characteristics (age, gender, race, baseline chronic kidney disease, obesity, pregnancy, solitary kidney, urinary tract anatomic abnormality, past bariatric surgery, history of renal transplant, or other comorbid conditions [e.g., cardiovascular disease, diabetes, gout, hypertension, heart failure]); baseline diet characteristics (intake of fluids, calcium, animal protein, sodium, fruit and fiber, purine, oxalate, potassium, soft drinks); baseline stone characteristics (stone composition, frequency of past stone episodes, severity of past stone episodes, past shock-wave lithotripsy, or presence of residual stones/fragments); baseline biochemical measures from blood (uric acid, calcium, albumin, creatinine, potassium, bicarbonate) or urine (pH, volume, uric acid, oxalate, calcium, citrate, creatinine, sodium); study duration (e.g., 2 or more years versus <2 years); patient treatment adherence; followup blood and urine biochemical measures; and study quality.

## Strength of Evidence for Key Questions

We evaluated the overall strength of RCT evidence regarding the efficacy of diet and pharmacological treatments for preventing key stone recurrence outcomes (Key Questions 2 and 4) using methods developed by AHRQ and the EHC Program.36 We did not formally rate strength of evidence for adverse effects (Key Questions 3 and 5) because results for specific and any adverse effects outcomes were so infrequently and heterogeneously reported. We did not formally rate strength of evidence for whether baseline or followup labs predict treatment outcomes (Key Questions 1 and 6) because data were scarce, indirect and did not seem to fit within the AHRQ framework for strength of evidence rating.

We evaluated strength of evidence based on four required domains: (1) risk of bias (i.e., whether, based on study design and conduct, the studies for a given outcome or comparison have good internal validity; the risk of bias was rated low, medium, or high); (2) consistency (i.e., whether the included studies found a similar direction of effect; consistency was rated consistent, inconsistent, or, in cases when only a single study was evaluated, unknown/not applicable); (3) directness (i.e., reflecting a single, direct link between the intervention of interest and the outcome; directness was rated as either direct or indirect); and (4) precision (i.e., the degree of certainty surrounding an effect estimate of a given outcome; precision was rated either precise or imprecise, with a precise estimate being one that allowed a clinically meaningful conclusion). Examples when evidence is available, but strength of evidence may be graded as insufficient include when there is an unacceptably high risk of bias, or there is a major inconsistency that cannot be explained (e.g., 2 studies with the same risk of bias with opposite results and no clear explanation for the discrepancy). In addition, strength of evidence may be graded as insufficient when data are too imprecise. This may be the case when the 95% CI is so wide that it cannot exclude either a clinically significant benefit or harm (e.g. lower CI bound 〈0.5 and upper CI bound >2).

The evidence was rated using the following grades: (1) high confidence indicated that further research is very unlikely to change the confidence in the estimate of effect, meaning that the evidence reflects the true effect; (2) moderate confidence denoted that further research may change our confidence in the estimate of effect and may change the estimate; (3) low confidence indicated that further research is very likely to have an important impact on the confidence in the estimate of effect and is likely to change the estimate, meaning there is low confidence that the evidence reflects the true effect; and (4) insufficient, indicating that the evidence was unavailable or did not permit a conclusion. An overall rating of high strength of evidence implied that the included studies were RCTs with a low risk of bias with consistent, direct, and precise domains.

## Assessing Applicability

We determined applicability of studies according to the PICOTS format. While some conditions that affect applicability of studies were used as exclusion criteria (i.e., short followup times), other study characteristics that could affect applicability were noted in evidence tables when possible by the study abstractors/evaluators. These characteristics included: non–U.S. settings; specialty clinic versus primary care settings; narrow study eligibility criteria; stone recurrence rates different from those described by population studies of nephrolithiasis; and drugs or dosages not typically used in current practice.