# Future Research Recommendations

Table 3 summarizes the areas needing future research based on the gaps identified in this review.

Table 3 Future research recommendations

Research Gaps | Future Research Recommendations
General Issues
- Efficacy results for most trials were driven by nonclinical outcomes (radiographic stones only, radiographic stones included as part of composite stones outcome, and/or stone growth).; - Though numerous trials report stone growth as a treatment outcome, consensus is lacking on the clinical importance of this outcome or on a threshold for what constitutes clinically meaningful stone growth.; - Other than stone recurrence, there was minimal trial reporting of clinical outcomes.; - Followup duration in some trials may have been too short to observe treatment effects.; - Inconsistent imaging modalities and testing frequencies were used to ascertain recurrent stones and stone growth.; - Inconsistent imaging modalities were used to exclude baseline residual stones, increasing the risk that studies using less sensitive modalities labeled a stone missed by baseline imaging a new stone during treatment followup.; - Modeling studies to estimate the benefits and harms of different kidney stone evaluation, treatment and followup strategies were outside the scope of this report. | - Prospective observational studies should identify patients with asymptomatic stone growth (using sensitive and standardized detection methods, and including different thresholds to define stone growth), radiographic stone recurrence (again using sensitive and standardized detection methods) and/or asymptomatic stone passage and follow them untreated for several years for symptomatic stone recurrence to help determine whether and under what circumstances these measures are appropriate surrogates for this symptomatic stone recurrence.; - RCTs should use symptomatic stones as the primary outcome, or if using composite stone recurrence as the primary outcome, they also should separately report symptomatic and radiographic stones.; - RCTs should enroll patients with asymptomatic stone growth above some absolute stone size or growth rate threshold(s), randomize them to intervention vs. observation/watchful waiting, and assess the relative clinical benefits/harms of these treatment strategies, including the number of required interventions and associated complications.; - In addition to stone recurrence, RCTs should report other clinical outcomes, including pain, urinary tract obstruction with acute renal failure, infection, procedure related morbidity, emergency room treatment and/or hospitalization related to stone recurrence, quality of life, and/or end-stage renal disease. Studies also should report the laboratory and radiographic testing participants undergo, including their cumulative radiation exposure.; - RCTs should be long-term, with possibly standardized minimum followup durations for ascertaining symptomatic, composite, and radiographic stone outcomes, and stone growth respectively.; - RCTs should use standard imaging modalities to ascertain presence of baseline residual stones as well as standard modalities and testing frequencies to ascertain incident radiographic stones and stone growth.; - Modeling studies should be performed to estimate the effectiveness, cost-effectiveness and harms of different kidney stone evaluation, treatment and followup strategies vs. a control strategy to prevent stone recurrence. Models should account for treatment efficacy and harms, treatment adherence, and costs and adverse effects of baseline and followup biochemistries and imaging procedures, among other factors.
Key Question 1. Do baseline stone composition and blood and urine chemistries predict effectiveness of treatments used to prevent stone recurrence?
- Almost no RCTs reported and compared stone recurrence outcomes between treatments stratified by baseline biochemistry levels. In comparisons between studies, there was limited evidence that baseline biochemical measures other than hyperuricosuria or hyperuricemia (allopurinol) predicted the effectiveness of diet or pharmacological treatment vs. control in reducing risk of stone recurrence.; - Regarding stone composition, there was no RCT evidence for efficacy of any treatment to prevent recurrent uric acid or cystine stones, and minimal RCT evidence for efficacy of AHA in preventing recurrent struvite stones.; - A substantial minority of RCTs reported no information on baseline biochemistry measures. Many trials that reported prevalence or based participant eligibility on the presence or absence of such abnormalities did not report how biochemical abnormalities were defined. Though definitions of biochemical abnormalities utilized in trials reporting appeared roughly similar, they were not standardized.; - Increased risk for stone recurrence conferred by biochemical abnormalities appears continuous and not defined by a specific threshold; this may need to be accounted for in evaluations of treatment efficacy as a function of baseline biochemistries.; - In patients with hyperuricosuric or hyperuricemic calcium stones, it is unknown whether allopurinol is more effective in preventing stone recurrence than other treatments.; - No RCTs were limited to patients with calcium phosphate stones, and no trials that included such patients reported stratified results for this patient subgroup.; - It is uncertain whether citrate treatment is more effective in preventing stone recurrence in patients with hypocitraturia than in those without or unselected for hypocitraturia.; - In patients with hypocitraturia, it is uncertain whether citrate is more effective in preventing stone recurrence than other treatments.; - It is uncertain whether thiazide treatment is more effective in preventing stone recurrence in patients with hypercalciuria than in those without or unselected for hypercalciuria. | - RCTs for prevention of recurrent uric acid stones should compare dietary purine restriction, allopurinol or alkalinization therapy vs. control.; - RCTs for prevention of recurrent cystine stones should compare dietary (e.g., increased fluid, low sodium) and pharmacological interventions (e.g., penicillamine, captopril, tiopronin, others) vs. control.; - RCTs for prevention of recurrent struvite stones (and prevention of pyelonephritis and impaired renal function) should compare AHA with and without concomitant antibiotics vs. control.; - RCTs for prevention of recurrent calcium phosphate stones should compare citrate and/or thiazide vs. control. These studies may consist entirely of patients with this stone type or may report stratified results for this stone subgroup.; - Additional RCTs should be performed, not just in patients with or without defined biochemical abnormalities (which should be standardized across trials and consistently reported), but results also should be reported stratified by different prespecified levels of specific biochemistry measures that are standardized across trials.; - Additional RCTs should evaluate effectiveness and harms of single and/or multicomponent biochemistry screening strategies followed by a comparison of different diet and/or pharmacological treatment strategies (e.g., targeted treatment or empiric treatment or control) with adequate power for clinical outcomes.
Key Question 2. What is the effectiveness and comparative effectiveness of different dietary therapies to reduce stone recurrence and improve other clinical outcomes?
- Evidence is limited regarding efficacy of individual dietary components for preventing stone recurrence.; ○ Does low dietary calcium increase recurrent stone risk? Does higher dietary calcium lower risk?; ○ Does low animal protein lower or increase recurrent stone risk?; - The efficacy of multicomponent diet trials for preventing stone recurrence is uncertain (variable composition of multicomponent diets between trials; inconsistent results); - It is unknown whether the efficacy of diet therapies differs as a function of participant characteristics.; ○ Does efficacy of increased fluid intake differ between patients with single vs. multiple past stone episodes? | - RCTs should be performed comparing individual diet components vs. control for preventing stone recurrence (e.g., low animal protein, low sodium, normal-high calcium, low purine, high fiber, low oxalate).; - In addition to reporting overall results, dietary RCTs should report stone recurrence outcomes for any important clinical subgroups included (e.g., gender, single vs. multiple past stone episodes, obesity, diabetes, gout).
Key Question 3. What are the adverse effects of dietary therapies used to reduce risk of recurrent stone episodes?
- There is limited adverse event data from intervention studies that utilized either individual dietary components or multicomponent diets.; - There is limited adverse event data from multicomponent diet studies, and making general conclusions about adverse events associated with multicomponent diets is limited because multicomponent differed between trials. | - RCTs should collect and completely report predefined adverse events in all randomized participants (e.g., any, serious adverse effects, adverse effects causing withdrawal, predefined specific adverse effects).; - Prospective cohort studies should be performed in patients [underlined: being initiated] on diet treatment for stone prevention, again collecting and completely reporting predefined adverse events in all study participants.
Key Question 4. What is the effectiveness and comparative effectiveness of different pharmacological therapies to reduce stone recurrence and improve other clinical outcomes?
- It is unclear if there is a best empiric pharmacological treatment to prevent stone recurrence.; - The optimal thiazide dosing regimen (i.e., dose, frequency) to prevent stone recurrence is uncertain.; - It is uncertain whether the effectiveness of potassium-magnesium-citrate formulation available in U.S. (much smaller dose per pill) is comparable to that used in the trial included in this review.; - The most effective treatment to prevent stone recurrence in patients with hyperuricosuric calcium stones is uncertain (e.g., allopurinol vs. thiazides).; - There are no RCT data on efficacy of allopurinol in preventing stone recurrence in patients with uric acid stones.; - The importance of adjuvant suppressive antibiotic therapy in patients with struvite stones being treated with AHA is uncertain.; - It is uncertain whether magnesium reduces stone recurrence in patients with calcium stones, overall or in those with hypomagnesuria.; - It is unclear if any combination therapy is more effective in preventing stone recurrence than thiazide, citrate or allopurinol monotherapy, in patients unselected for stone type and biochemical abnormality or within specific subgroups.; - All eligible monotherapy trials since 1988 have studied only previously studied drugs. | - RCTs should compare thiazide vs. citrate to prevent stone recurrence in patients unselected for stone or biochemical characteristics.; - RCTs should compare different thiazide dosing regimens (e.g., HCTZ 12.5 mg/day vs. 12.5 mg twice daily vs. 25 mg/day) for prevention of stone recurrence.; - RCTs should compare different thiazide agents (i.e., HCTZ, chlorthalidone, indapamide) for prevention of stone recurrence.; - Additional RCTs should compare thiazide and citrate combination treatment vs. monotherapy to prevent stone recurrence.; - RCTs should compare AHA vs. control in patients with struvite stones and report recurrent stones (and other clinical outcomes including pyelonephritis and acute kidney injury), with a factorial design involving additional randomization to suppressive antibiotic treatment or no antibiotics.; - RCTs should compare magnesium vs. control to prevent stone recurrence in patients with hypomagnesuria.; - RCTs are needed of novel treatment strategies to prevent stone recurrence (e.g., febuxostat, pyridoxine, fish oil, oxalobacter formigenes and other probiotics, others). Better understanding is needed regarding kidney stone pathogenesis to help develop potential new preventive treatments, including the possible identification of molecular markers of stone disease.
Key Question 5. What are the adverse effects of pharmacological therapies used to reduce risk of recurrent stone episodes?
- Adverse events reporting is poor (e.g., incomplete, not reported separately by treatment group, not clearly prespecified) in RCTs of patients being treated to prevent stone recurrence; minimal additional data are available from prospective observational studies of patients with kidney stones. | - RCTs should collect and completely report predefined adverse events including effects on comorbid conditions as well as any adverse events, serious adverse events, adverse events causing withdrawal, and any withdrawals in all randomized participants.; - Prospective cohort studies should be performed in patients being started on pharmacological treatment for stone prevention, again collecting and completely reporting predefined adverse events in all study participants.
Key Question 6. Do results of followup blood and urine biochemistry tests collected after initiation of treatment predict treatment effectiveness in preventing stone recurrence?
- No RCTs or prospective observational studies reported stone recurrence outcomes collected completely subsequent to post-baseline measurements of biochemistries.; - Participants assigned to active treatment in one fluid trial46 and one multicomponent diet trial51 had a significant decline from baseline in urine calcium-oxalate supersaturation, uric acid supersaturation, and calcium-phosphate supersaturation measured at 1 year or later, as well as significant reductions in risk of recurrent stones vs, their respective control groups over a 5-year followup. However, these studies did not examine stone recurrence risk as a function of followup or change in urine supersaturation levels (and no pharmacological trials even reported followup urine supersaturation levels). | - RCTs should report and correlate/stratify the effect of diet and/or pharmacological treatment vs control on risk of recurrent stones (preferably symptomatic stones) in patients subsequent to measurement of post-baseline biochemistries, including urine calcium, calcium-oxalate supersaturation, uric acid supersaturation, calcium-phosphate supersaturation, and others.; - Studies could adjust stone recurrence outcomes by results for change in or followup level of biochemistry measure.; - Prospective cohort studies should report and correlate the risk of recurrent symptomatic stones in patients subsequent to measurement of post-baseline biochemistries.

Abbreviations: AHA=acetohydroxamic acid; HCTZ=hydrochlorothiazide; RCT=randomized controlled trial