# Peer Reviewers

John Lieske, M.D.

Mayo Clinic

Rochester, MN

Tanveer P. Mir, M.D., M.A.C.P.

Long Island Jewish Medical Center

Long Island, NY

Glenn M. Preminger, M.D.

Duke University Medical Center

Durham, NC

Roswitha Siener, Ph.D.

University of Bonn

Bonn, Germany