# Technical Expert Panel

John R. Asplin, M.D.

Litholink Corporation

Chicago, IL

Dean Assimos, M.D.

Wake Forest College

Winston Salem, NC

Gary Curhan, M.D., Sc.D.

Harvard University

Boston, MA

Apostolos P. Dallas, M.D.

Carilion Clinic

Roanoke, VA

Margaret Pearle, M.D.

Southwestern Texas

Dallas, TX

Kristina Penniston, Ph.D.

University of Wisconsin

Madison, WI