# Key Informants

Gary C. Curhan, M.D., Sc.D.

Harvard University

Boston, MA

Keith E. Folkert, M.D., M.H.A.

Blue Cross and Blue Shield of Minnesota

Eagan, MN

Jim Lipka

Columbia Heights, MN

Margaret S. Pearle, M.D., Ph.D.

University of Texas Southwestern Medical School

Dallas, TX

Kristina L. Penniston, Ph.D.

University of Wisconsin School of Medicine and Public Health

Madison, WI

Jyme H. Schafer, M.D., M.P.H.

Centers for Medicare & Medicaid Services

Baltimore, MD

Jeffery A. Wesson, M.D., Ph.D.

Medical College of Wisconsin

Milwaukee, WI