# Errata

## March 27, 2013

In response to late comments to the AHRQ comparative effectiveness review, the authors clarified the criteria for assessing individual study quality, and re-evaluated the individual study quality and strength of evidence grading in the report.

The authors rated the risk of bias as low, medium, or high based on whether the design and conduct of the studies for a given treatment comparison and outcome indicated good internal validity. This resulted in the following changes in individual study quality: (1) the Borghi 2002 study comparing low protein/low sodium/high calcium diet to low calcium diet was assessed as “good” quality, rather than “fair” quality; (2) the Kovcara 1999 study comparing evaluation and tailored diet to limited evaluation and uniform diet was assessed as “poor” quality” rather than “fair” quality; and (3) the Borghi 1996 study comparing increased fluid intake to control was assessed as “poor” rather than “fair” quality.

The authors also clarified how they assessed the four domains for judgment of the strength of evidence for each grade (high, moderate, low and insufficient). Five strength of evidence grades were reassessed as insufficient rather than low for the following recurrent nephrolithiasis outcomes and comparisons: increased fluid vs. no treatment for radiographic recurrence, thiazides vs. placebo for symptomatic recurrence, allopurinol vs. placebo for radiographic recurrence, AHA vs. placebo radiographic for recurrence, and thiazide + allopurinol vs. thiazide for composite recurrence.

These decisions are reflected in the executive summary, full report and appendixes. The comments and full response to comments are included in the updated Disposition of Comments table.

## May 16, 2013

The authors corrected the reported number of subjects in studies for Table 1 (Strength of evidence for prevention of stone recurrence: diet intervention trials) and Table 2 (Strength of evidence for prevention of stone recurrence: pharmacological intervention trials) to consistently and accurately reflect the number of randomized trial subjects. This correction did not affect any of the analyses or conclusions of this report.