# References

1 Dussol B, Iovanna C, Rotily M, et al. A randomized trial of low-animal-protein or high-fiber diets for secondary prevention of calcium nephrolithiasis. Nephron. 2008;110(3):c185-94. [pmid: 18957869].
2 Sarica K, Inal Y, Erturhan S, et al. The effect of calcium channel blockers on stone regrowth and recurrence after shock wave lithotripsy. Urological Research. Jun. 2006;34(3):184-9. [pmid: 16463053].
3 Borghi L, Schianchi T, Meschi T, et al. Comparison of two diets for the prevention of recurrent stones in idiopathic hypercalciuria. New England Journal of Medicine. Jan. 10. 2002;346(2):77-84. [pmid: 11784873].
4 Di Silverio F, Ricciuti GP, D’Angelo AR, et al. Stone recurrence after lithotripsy in patients with recurrent idiopathic calcium urolithiasis: Efficacy of treatment with Fiuggi water. European Urology. 2000:145-8. [pmid: 10705191].
5 Kocvara R, Plasgura P, Petrik A, et al. A prospective study of nonmedical prophylaxis after a first kidney stone. BJU International. Sep. 1999;84(4):393-8. [pmid: 10468751].
6 Borghi L, Meschi T, Amato F, et al. Urinary volume, water and recurrences in idiopathic calcium nephrolithiasis: a 5-year randomized prospective study. Journal of Urology. Mar. 1996;155(3):839-43. [pmid: 8583588].
7 Hiatt RA, Ettinger B, Caan B, et al. Randomized controlled trial of a low animal protein, high fiber diet in the prevention of recurrent calcium oxalate kidney stones. American Journal of Epidemiology. Jul. 1. 1996;144(1):25-33. [pmid: 8659482].
8 Shuster J, Jenkins A, Logan C, et al. Soft drink consumption and urinary stone recurrence: a randomized prevention trial. Journal of Clinical Epidemiology. Aug. 1992;45(8):911-6. [pmid: 1624973].
9 Fernández-Rodríguez A, Arrabal-Martín M, García-Ruiz MJ, et al. The role of thiazides in the prophylaxis of recurrent calcium lithiasis. Actas urologicas espanolas. 2006:305-9. [pmid: 16749588].
10 Ahlstrand, editor. Prophylactic treatment of calcium stone formers with hydrochlorothiazide and magnesium. 1995. Edsbruk. Akademitryck AB.
11 Borghi L, Meschi T, Guerra A, et al. Randomized prospective study of a nonthiazide diuretic, indapamide, in preventing calcium stone recurrences. Journal of Cardiovascular Pharmacology. 1993;22(Suppl 6):S78-86. [pmid: 7508066].
12 Ettinger B, Citron JT, Livermore B, et al. Chlorthalidone reduces calcium oxalate calculous recurrence but magnesium hydroxide does not. Journal of Urology. Apr. 1988;139(4):679-84. [pmid: 3280829].
13 Ala-Opas M, Elomaa I, Porkka L, et al. Unprocessed bran and intermittent thiazide therapy in prevention of recurrent urinary calcium stones. Scandinavian Journal of Urology & Nephrology. 1987;21(4):311-4. [pmid: 2832935].
14 Laerum E, Larsen S. Thiazide prophylaxis of urolithiasis. A double-blind study in general practice. Acta Medica Scandinavica. 1984;215(4):383-9. [pmid: 6375276].
15 Scholz D, Schwille PO, Sigel A. Double-blind study with thiazide in recurrent calcium lithiasis. J Urol. 1982:903-7. [pmid: 7176047].
16 Lojanapiwat B, Tanthanuch M, Pripathanont C, et al. Alkaline citrate reduces stone recurrence and regrowth after shockwave lithotripsy and percutaneous nephrolithotomy. International Braz J Urol. Sep–Oct. 2011;37(5):611-6. [pmid: 22099273].
17 Soygur T, Akbay A, Kupeli S. Effect of potassium citrate therapy on stone recurrence and residual fragments after shockwave lithotripsy in lower caliceal calcium oxalate urolithiasis: a randomized controlled trial. Journal of Endourology. Apr. 2002;16(3):149-52. [pmid: 12028622].
18 Premgamone A, Sriboonlue P, Disatapornjaroen W, et al. A long-term study on the efficacy of a herbal plant, Orthosiphon grandiflorus, and sodium potassium citrate in renal calculi treatment. Southeast Asian Journal of Tropical Medicine & Public Health. Sep. 2001;32(3):654-60. [pmid: 11944733].
19 Ettinger B, Pak CY, Citron JT, et al. Potassium-magnesium citrate is an effective prophylaxis against recurrent calcium oxalate nephrolithiasis. Journal of Urology. Dec. 1997;158(6):2069-73. [pmid: 9366314].
20 Hofbauer J, Hobarth K, Szabo N, et al. Alkali citrate prophylaxis in idiopathic recurrent calcium oxalate urolithiasis—a prospective randomized study. British Journal of Urology. Apr. 1994;73(4):362-5. [pmid: 8199822].
21 Barcelo P, Wuhl O, Servitge E, et al. Randomized double-blind study of potassium citrate in idiopathic hypocitraturic calcium nephrolithiasis. Journal of Urology. Dec. 1993;150(6):1761-4. [pmid: 8230497].
22 Ettinger B, Tang A, Citron JT, et al. Randomized trial of allopurinol in the prevention of calcium oxalate calculi. New England Journal of Medicine. Nov. 27. 1986;315(22):1386-9. [pmid: 3534570].
23 Miano L, Petta S, Galatioto GP, et al. A placebo controlled double-blind study of allopurinol in severe recurrent idiopathic renal lithiasis. Schwille PO, Smith LH, Robertson WG, Vahlensieck W, editors. Urolithiasis and Related Clinical Research. New York. Plenum Press. 1985:521-4.
24 Robertson WG PM, Sepby PL, Williams RE, Clark P, Chisholm GD. A multicentre trial to evaluate three treatments for recurrent idiopathic calcium stone disease—a preliminary report. Plenum Press. 1986.
25 Smith MJ. Placebo versus allopurinol for renal calculi. Journal of Urology. Jun. 1977;117(6):690-2. [pmid: 875139].
26 Griffith DP, Gleeson MJ, Lee H, et al. Randomized, double-blind trial of Lithostat (acetohydroxamic acid) in the palliative treatment of infection-induced urinary calculi. European Urology. 1991;20(3):243-7. [pmid: 1726639].
27 Griffith DP, Khonsari F, Skurnick JH, et al. A randomized trial of acetohydroxamic acid for the treatment and prevention of infection-induced urinary stones in spinal cord injury patients. Journal of Urology. Aug. 1988;140(2):318-24. [pmid: 3294442].
28 Williams JJ, Rodman JS, Peterson CM. A randomized double-blind study of acetohydroxamic acid in struvite nephrolithiasis. New England Journal of Medicine. Sep. 20. 1984;311(12):760-4. [pmid: 6472365].
29 Fellstrom B, Backman U, Danielson BG, et al. Allopurinol treatment of renal calcium stone disease. British journal of urology. 1985:375-9. [pmid: 4027505].