# Baseline and Followup Urine Biochemical Measures Tables

Appendix H. Table 1 Followup urine biochemical measures for diet trials

Appendix H. Table 2 Followup urine biochemical measures for thiazide trials

Appendix H. Table 3 Followup urine biochemical measures for citrate trials

Appendix H. Table 4 Followup urine biochemical measures for allopurinol trials

Appendix H. Table 5 Followup urine biochemical measures for magnesium trials