# Withdrawals and Adverse Events Tables

Appendix G. Table 1 Withdrawals and adverse events for diet trials

Study | Any Study Withdrawals n/N (%) | | Any or Serious Adverse Events Leading to Study Withdrawal n/N (%) | | Subjects with at Least One Adverse Event n/N (%) | | Adverse Event: (describe) n/N (%) | | Adverse Event: (describe) n/N (%)
Study | Diet | Control | Diet | Control | Diet | Control | Diet | Control | Diet | Control
Dussol 2008^1^ | [underlined: Month 48] Low animal protein diet 32/55 (58.2%) High fiber diet 33/60 (55.0%) | [underlined: Month 48] 37/60 (61.7%) | NR | NR | NR | NR | NR | NR
Sarica 2006^2^ | 0/12 | 0/9 | 0/12 | 0/9 | NR | NR | NR | NR
Borghi 2002^3^ | Low protein/Na diet 8/60 (13.3) | Low calcium diet 9/60 (15.0) | Low protein/Na diet 3/60 (5.0) | Low calcium diet 7/60 (11.7) | NR | NR | HTN^†^ 1/60 (1.7) | HTN^†^ 7/60 (11.7) | Stroke^†^ 1/60 (1.7) Gout^†^ 1/60 (1.7) | Death (accidental) 2/60 (3.3)
Di Silverio 2000^4^ | Mineral H_2_0 calcium 15 mg/I 0/192 | Tap H_2_0 calcium 55–130 mg/l 0/192 | Mineral H_2_0 calcium 15 mg/I 0/192 | Tap H_2_0 calcium 55–130 mg/l 0/192 | NR | NR | NR | NR
Kocvara 1999^5^ | Not stated per arm, 35 patients (14%) not assessed at year 3 | | NR | NR | NR | NR | NR | NR
Borghi 1996^6^ | 11/99 (11.1) | 10/100 (10.0) | NR | NR | NR | NR | NR | NR
Hiatt 1996^7^ | 9/51 (17.6) | 15/51 (29.4) | NR | NR | NR | NR | NR | NR
Shuster 1992^8^ | 44/504 (8.7) | 28/505 (5.5) | 2/504 (0.4) | 2/505 (0.4) | NR | NR | Death 2/504 (0.4) | Death 2/505 (0.4)

Abbreviations: HTN= hypertension; Na = sodium; NR = not reported

† These results refer only to the number of participants who withdrew for these specific reasons. No data were reported on specific adverse effects that did not lead to study withdrawal.

Appendix G. Table 2 Withdrawals and adverse events for thiazide trials

Study | Any Study Withdrawals n/N (%) | | Any or Serious Adverse Events Leading to Study Withdrawal n/N (%) | | Subjects with at Least One Adverse Event n/N (%) | | Adverse Event: (describe) n/N (%) | | Adverse Event: (describe) n/N (%)
Study | Thiazide | Control | Thiazide | Control | Thiazide | Control | Thiazide | Control | Thiazide | Control
Fernández- Rodriguez, 2006^9^ | 0/50 | 0/50 | 0/50 | 0/50 | NR | NR | NR | NR
Ahlstrand, 1995^10^ | 10/17 (58.8) | 9/24 (37.5) | 5/17 (29.4) | 0/24 | NR | NR | Composite A^*^ 5/17 (29.4) | NR
Borghi, 1993^11^ | 6/25 (24.0) | Control 4/25 (16.0) Allopurinol 1/25 (4.0) | 2/25 (8.0) | Control 0/25 Allopurinol 0/25 | NR | NR | Hypotension 1^**^/25 (4.0) | NR | Severe hypokalemia 1^**^/25 (4.0) | NR
Ettinger, 1988^12^ | 17.7% due to loss of interest (not reported separately for each dose) and 22.6% and 18.9% due to AE for 25 and 50 mg dose groups, respectively | Placebo 16.7% MgOH_2_ 17.7% due to loss of interest (not reported separately for each dose) and 13.3% due to AE (1330 mg dose group only) | 25 mg 22.6% 50 mg 18.9% | Placebo 3.2% MgOH_2_ 1300 mg 13.3% | NR | NR | Composite B^*^ 25 mg 22.6% 50 mg 18.9% | GI upset Placebo 3.2% Diarrhea MgOH_2_ 1300 mg 13.3%
Ala-Opas, 1987^13^ | 0/28 | 0/45 | 0/28 | 0/45 | NR, “Side effects uncommon” | NR | NR | NR
Laerum, 1984^14^ | 2/25 (8.0) | 0/25 | 0/25 | 0/25 | 6/25 (24.0) | 2/25 (8.0) | Composite C^*^ 3/25 (12.0) | Composite C^*^ 2/25 (8.0) | Gout 1/25 (4.0) Hypokalemia 1/25 (4.0) Impotence 1/25 (4.0) | NR
Scholz, 1982^15^ | 2/25 (8.0) | 1/26 (3.8) | 2/25 (8.0) | 1/26 (3.8) | 13/25 (52.0) | 6/26 (23.1) | Composite D^*^ 11/25 (44.0) | Composite D^*^ 5/26 (19.2)

* Composite A = orthostatic reactions, dizziness, GI symptoms, muscle cramp, gout, and erectile dysfunction; Composite B = lassitude, fatigue, impotence, lightheadedness, or muscular symptoms; Composite C = minor adverse events such as slight fatigue and dyspepsia; Composite D = weariness, nausea, symptoms of hypotension.

** Patient removed from study.

Abbreviations: GI = gastrointestinal; MgOH_2_ = magnesium hydroxide; NR = not reported

Appendix G. Table 3 Withdrawals and adverse events for citrate trials

Study | Any Study Withdrawals n/N (%) | | Any or Serious Adverse Events Leading to Study Withdrawal n/N (%) | | Subjects with at Least One Adverse Event n/N (%) | | Adverse Event: Gastrointestinal Complaints n/N (%) | | Adverse Event: (describe) n/N (%)
Study | Citrate | Control | Citrate | Control | Citrate | Control | Citrate | Control | Citrate | Control
Lojanapiwat, 2011 16 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Fernández- Rodriguez, 2006^9^ | 0/50 | 0/50 | 0/50 | 0/50 | NR | NR | NR | NR | NR | NR
Soygur, 2002^17,†^ | 20 of 110 subjects randomized were excluded but number excluded from each study group was not reported | | 6 subjects withdrew due to epigastric discomfort but number withdrawing from each study group was not reported | | NR | NR | 6 subjects overall | | NR | NR
Premgamone, 2001^18^ | 5/24 (20.8) | 2/24 (8.3) | 5/24 (20.8) | 0/24 | 8/24 (33.3) | 0/24 | NR | NR | Fatigue or loss of appetite 8/24 (33.3) | 0/24
Ettinger, 1997^19^ | 15/31 (48.4) | 8/33 (24.2) | 5/31 (16.1) | 1/33 (3.0) | NR | NR | 13/31 (41.9); 8/31 (25.8%) had more than slight symptoms | 13/33 (39.4); 5/33 (15.2%) had more than slight symptoms | Diarrhea (11.5)^*^ | Diarrhea 0/33 (0)
Hofbauer, 1994^20^ | 9/25 (36.0) | 3/25 (12.0) | 4/25 (16.0) | 0/25 (0.0) | 4/25 (16.0) | 0/25 (0.0) | 4/25 (16.0) | 0/25 (0.0) | NR | NR
Barcelo, 1993^21^ | 10/28 (35.7) | 9/29 (31.0) | 2/28 (7.1) | 1/29 (3.4) | NR | NR | 5/28 (17.9) | 1/29 (3.4) | NR | NR

Abbreviations: fu = followup; NR = not reported

* number of subjects unclear/ indeterminable

† Study did not report withdrawal and adverse event data separately for subjects who were stone free at baseline from those who had residual stones at baseline.

Appendix G. Table 4 Withdrawals and adverse events for allopurinol trials

Study | Any Study Withdrawals n/N (%) | | Any or Serious Adverse Events Leading to Study Withdrawal n/N (%) | | Subjects with at leastOne Adverse Event n/N (%) | | Adverse Event: (describe) n/N (%) | | Adverse Event: (describe) n/N (%)
Study | Allopurinol | Control | Allopurinol | Control | Allopurinol | Control | Allopurinol | Control | Allopurinol | Control
Borghi, 1993^11^ | Allopurinol + Indapamide 1/25 (4.0) | Control 4/25 (16.0) Indapamide 6/25 (24.0) | Allopurinol + Indapamide 0/25 | Control 0/25 Indapamide 2/25 (8.0) | NR | NR | NR | Control NR; Indapamide Hypotension 1/25 (4.0) | NR | Control NR; Indapamide Severe hypokalemia 1/25 (4.0)
Ettinger, 1986^22^ | 7/36 (19.4) | 5/36 (13.8) | 2/36 (5.5) | 2/36 (5.5) | NR | NR | Gastrointestinal discomfort, rash, or fatigue 2^*^/36 (5.6) | Gastrointestinal discomfor, rash, or fatigue 2^*^/36 (5.6) | 1/36 (2.8) maculopapular rash; 2/36 (5.6) intercurrent illness
Miano, 1985^23^ | NR^**^ | NR^**^ | NR | NR | NR | NR | NR | NR
Robertson, 1985^24^ | NR^**^ | NR^**^ | NR | NR | NR | NR | NR | NR
Fellstrom, 1985^29^ | 2/33 (6) | NR | 2/33 (6) | NR | NR | NR | Rash 2/33 (6) | NR
Smith, 1977^25^ | Before 6 months 16/65 (24.6); Total 24/65 (36.9) | Before 6 months 24/67 (35.8); Total 38/67 (56.7) | “Drug sickness” 2/65 (3.1) | “Drug sickness” 6/67 (9.0) | NR | NR | Skin rash 1/65 (1.5) | Skin rash 1/67 (1.5) | Acute gout 3/65 (4.6) Leukopenia 1/65 (1.5) | NR

* Patients removed from study;

** Study provided only preliminary data on a portion of randomized participants and was unclear regarding whether any of participants not included in analyses had withdrawn.

Abbreviation: NR = not reported

Appendix G. Table 5 Withdrawals and adverse events for acetohydroxamic acid trials

Study | Any Study Withdrawals n/N (%) | | Any or Serious Adverse Events Leading to Study Withdrawal n/N (%) | | Subjects with at Least One Adverse Event n/N (%) | | Adverse Event: (describe) n/N (%) | | Adverse Event: (describe) n/N (%)
Study | AHA | Control | AHA | Control | AHA | Control | AHA | Control | AHA | Control
Griffith, 1991^26^ | 29/45 (64.4) Deaths 0/45 (0) | 36/49 (73.5) Deaths 1/49 (2.0) | 12/45 (26.6) | 3/49 (6.1) | 35/45 (77.7) | 24/49 (48.9) | Anemia 1/45 (2.2) Phlebitis 1/45 (2.2) | Anemia 0/45 (0) Phlebitis 1/49 (2.0) | Alopecia 4/45 (8.9) Headache 4/45 (8.9) | Alopecia 1/49 (2.0) Headache 2/49 (4.1)
Griffith, 1988^27^ | 75/121 (62.0)^*^ | 28/89 (31.5)^*^ | 20%^†^ | 5%^†^ | 75/121 (61.9) | 26/89 (29.2) | Anemia 25/99 (25) | Anemia 10/85 (11.7)
Williams, 1984^28^ | Overall 6/20 (30), of which 2/20 (10) within 3 months | NR | 2/20 (10) | NR | 9/20 (45.0) | 1/19 (5.3) | Tremulousness 5/20 (25) Myocardiopathy NR | Tremulousness NR Myocardiopathy 1/19 (5%) | Deep vein thrombosis 3/19 (15.7) Intolerable headache 1/20 (5) | NR

* numbers calculated from percentages reported;

† Actual numbers not provided by and not possible to determine from original study.

Abbreviation: NR = not reported

Appendix G. Table 6 Withdrawals and adverse events for magnesium trials

Study | Any Study Withdrawals n/N (%) | | Any or Serious Adverse Events Leading to study Withdrawal n/N (%) | | Subjects with at Least One Adverse Event n/N (%) | | Adverse Event: (describe) n/N (%) | | Adverse Event: (describe) n/N (%)
Study | Magnesium | Control | Magnesium | Control | Magnesium | Control | Magnesium | Control | Magnesium | Control
Ettinger, 1988^12^ | †9/51 17.7% due to loss of interest (suspect 3/30 in 650mg group & 6/21 in 1300mg group); 0/27 of remaining 650 mg group and 2/15 (13.3%) remaining 1300 mg group due to GI upset | †Placebo 5/31 (16.7%) Thiazide 17.7% due to loss of interest (not reported separately for each dose) and 22.6% and 18.9% due to AE for 650 and 50 mg dose groups, respectively | 1300 mg 13.3% | Placebo 3.2% Thiazide 25 mg 22.6% 50 mg 18.9% | NR | NR | Diarrhea 1300 mg 13.3% stated as “not a problem” for the 650 mg dose group | GI upset Placebo 3.2% Composite^*^ Thiazide 25 mg 22.6% 50 mg 18.9%

* lassitude, fatigue, impotence, lightheadedness, or muscular symptoms.

† Raw numbers estimated from percentages provided in publication.

Abbreviations: GI = gastrointestinal; NR = not reported