# Evidence Tables

Appendix C. Table 1 Evidence table: Diet trials for recurrent nephrolithiasis

Appendix C. Table 2 Evidence table: Thiazide trials for recurrent nephrolithiasis

Appendix C. Table 3 Evidence table: Citrate trials for recurrent nephrolithiasis

Appendix C. Table 4 Evidence table: Allopurinol trials for recurrent nephrolithiasis

Appendix C. Table 5 Evidence table: Acetohydroxamic acid (AHA) trials for recurrent nephrolithiasis

Appendix C. Table 6 Evidence table: Magnesium trials for recurrent nephrolithiasis

Appendix C. Table 7 Individual study quality for diet trials

Appendix C. Table 8 Individual study quality for pharmocological trials