# Excluded Studies

1 Yuruk E, Binbay M, Sari E, et al. A prospective, randomized trial of management for asymptomatic lower pole calculi. Journal of Urology. Apr. 2010;183(4):1424-8. not treatment to prevent recurrent stones. [pmid: 20172565].
2 Yuan ZY. Oral administration of magnesium and vitamin B6 in patients with renal calculi. Chinese Journal of urology. 1987;(2):91-3. CN-00366933. not available in English.
3 Yoshioka K, Ohashi Y, Sakai T, et al. A multicenter trial of mizoribine compared with placebo in children with frequently relapsing nephrotic syndrome. Kidney International. Jul. 2000;58(1):317-24. not adults. [pmid: 10886577].
4 Wolf H, Brocks P, Transbol I. Do thiazides prevent recurrent idiopathic renal calcium oxalate stones? Results of a randomized, controlled clinical trial. [abstract]. Kidney international. 1983;(3):426. not controlled trial.
5 Wolf H, Brocks P, Dahl C. Do thiazides prevent recurrent idiopathic renal calcium oxalate stones?. Proceedings of the European Dialysis & Transplant Association. 1983:477-80. not eligible treatment. [pmid: 6361755].
6 Van Reen R, Valyasevi A, Dhanamitta S. Studies of bladder stone disease in Thailand. XII. The effect of methionine and pyridoxine supplements on urinary sulfate. American Journal of Clinical Nutrition. Jul. 1970;23(7):940-7. not adults. [pmid: 4917073].
7 Ulmann A, Sayegh F, Clavel J, et al. Incidence of lithiasic recurrence after a diuretic therapy, alone or combined with treatment by a thiazide diuretic or phosphorus. Presse médicale (Paris, France : 1983). 1984;(20):1257-60. not available in English.
8 Tiselius HG, Ackermann D, Alken P, et al. Guidelines on urolithiasis. European Urology. Oct. 2001;40(4):362-71. not controlled trial. [pmid: 11713390].
9 Tiselius HG. Editorial comment on: Diet, fluid, or supplements for secondary prevention of nephrolithiasis: a systematic review and meta-analysis of randomized trials. European Urology. Jul. 2009;56(1):80. not controlled trial. [pmid: 19321254].
10 Thybo E, Vennits H. Oxyphenbutazone therapy in ureteric calculus. Ugeskrift for laeger. 1971;(11):493-5. not available in English. [pmid: 4928585].
11 Thomas M. Caring for Australians with Renal I. The CARI guidelines. Clinical diagnosis of kidney stones. Nephrology. Feb. 2007;12(Suppl 1):S1-3. not controlled trial. [pmid: 17316269].
12 Suzuki M, Kobayashi H, Kageyama S, et al. Excretion of bikunin and its fragments in the urine of patients with renal stones. Journal of Urology. Jul. 2001;166(1):268-74. not treatment to prevent recurrent stones. [pmid: 11435884].
13 Streem SB. Long-term incidence and risk factors for recurrent stones following percutaneous nephrostolithotomy or percutaneous nephrostolithotomy/extracorporeal shock wave lithotripsy for infection related calculi. Journal of Urology. Mar. 1995;153(3 Pt 1):584-7. not eligible treatment. [pmid: 7861487].
14 Srinivasan S, Jenita X, Kalaiselvi P, et al. Salubrious effect of vitamin E supplementation on renal stone forming risk factors in urogenital tuberculosis patients. Renal Failure. 2004;(2):135-40. not adults with previous kidney stones. [pmid: 15287196].
15 Smith MJ. Placebo versus allopurinol for recurrent urinary calculi. Proceedings of the European Dialysis & Transplant Association. 1983;20:422-6. available in abstract form only. [pmid: 6361753].
16 Smith MJ. Allopurinol and calcium-stone formers. Lancet. Feb. 10. 1973;1(7798):315. not controlled trial. [pmid: 4119188].
17 Siener R, Hesse A. Comparison of the effect of variations in dietary purine on risk of uric acid stone formation. American Journal of Clinical Nutrition. 1999;35:631s. not adults with previous kidney stones.
18 Sidabutar Lumenta NA, Suling RC. Chlorthalidone in prevention of urinary calcium stone. Journal of the Medical Association of Thailand. 1978;(Suppl 1):195-204. not controlled trial.
19 Segura JW, Preminger GM, Assimos DG, et al. Nephrolithiasis Clinical Guidelines Panel summary report on the management of staghorn calculi. The American Urological Association Nephrolithiasis Clinical Guidelines Panel. Journal of Urology. Jun. 1994;151(6):1648-51. not controlled trial. [pmid: 8189589].
20 Segura JW, Preminger GM, Assimos DG, et al. Ureteral Stones Clinical Guidelines Panel summary report on the management of ureteral calculi. The American Urological Association. Journal of Urology. Nov. 1997;158(5):1915-21. not controlled trial. [pmid: 9334635].
21 Scott R, Lewi H. Therapeutic management of upper urinary tract stone disease in 172 subjects. Urology. Apr. 1989;33(4):277-81. not controlled trial. [pmid: 2648657].
22 Schwartz BF, Bruce J, Leslie S, et al. Rethinking the role of urinary magnesium in calcium urolithiasis. Journal of Endourology. Apr. 2001;15(3):233-5. not controlled trial. [pmid: 11339386].
23 Scholz D, Schwille PO. Efficacy of thiazide in idiopathic calcium urolithiasis. Results of a one-year double-blind study (author’s transl). Arzneimittel-Forschung. 1980;(11):1928-32. not available in English. [pmid: 7006616].
24 Schell-Feith EA, Moerdijk A, van Zwieten PH, et al. Does citrate prevent nephrocalcinosis in preterm neonates?. Pediatric nephrology (Berlin, Germany). 2006;(12):1830-6. not adults.
25 Sarica K, Erturhan S, Yurtseven C, et al. Effect of potassium citrate therapy on stone recurrence and regrowth after extracorporeal shockwave lithotripsy in children. Journal of Endourology. 2006;(11):875-9. not adults. [pmid: 17144854].
26 Sarica K, Erturhan S, Altay B. Effect of verapamil on urinary stone-forming risk factors. Urological Research. 2007;(1):23-7. not patients 90 days post SWL. [pmid: 17165082].
27 Roggia A, Comeri GC, Benvenuti C, et al. Prevention of calcium lithiasis recurrence of the kidney with fibrinolytic agent. UROLOGIA. 1980;(1):95-100. not available in English.
28 Rodriguez AF, Martin MA, Ruiz MJG, et al. Effect of thiazide therapy in the prevention of urinary nephrolithiasis. Archivos espanoles de urologia. 2001;(9):1047-54. not available in English. [pmid: 11789362].
29 Riedmiller H, Androulakakis P, Beurton D, et al. EAU guidelines on paediatric urology. European Urology. Nov. 2001;40(5):589-99. not adults. [pmid: 11752871].
30 Reynolds TM. ACP Best Practice No 181: Chemical pathology clinical investigation and management of nephrolithiasis. Journal of Clinical Pathology. Feb. 2005;58(2):134-40. not controlled trial. [pmid: 15677531].
31 Reilly RF, Peixoto AJ, Desir GV. The evidence-based use of thiazide diuretics in hypertension and nephrolithiasis. Clinical Journal of The American Society of Nephrology: CJASN. Oct. 2010;5(10):1893-903. not controlled trial. [pmid: 20798254].
32 Qiang W, Ke Z. Water for preventing urinary calculi. Cochrane Database of Systematic Reviews. 2004;(3):CD004292. not controlled trial. [pmid: 15266525].
33 Preminger GM, Tiselius H-G, Assimos DG, et al. guideline for the management of ureteral calculi. Journal of Urology. 2007. Dec. 2007;178(6):2418-34. not controlled trial. [pmid: 17993340].
34 Phipps S, Tolley DA, Young JG, et al. The management of ureteric stones. Annals of the Royal College of Surgeons of England. Jul. 2010;92(5):368-72. not controlled trial. [pmid: 20626969].
35 Pearle MS, Roehrborn CG, Pak CY. Meta-analysis of randomized trials for medical prevention of calcium oxalate nephrolithiasis. Journal of Endourology. Nov. 1999;13(9):679-85. not controlled trial. [pmid: 10608521].
36 Pak CY, Sakhaee K, Fuller C. Successful management of uric acid nephrolithiasis with potassium citrate. Kidney International. Sep. 1986;30(3):422-8. not controlled trial. [pmid: 3784284].
37 Ohkawa T, Ebisuno S, Morimoto S, et al. Citrate (CG-120) therapy for urolithiasis. 1. Clinical effects. Hinyokika kiyo. Acta urologica Japonica. 1988;(5):905-17. not available in English. [pmid: 3051945].
38 Ohkawa M, Tokunaga S, Nakashima T, et al. Thiazide treatment for calcium urolithiasis in patients with idiopathic hypercalciuria. British Journal of Urology. Jun. 1992;69(6):571-6. not eligible treatment. [pmid: 1638340].
39 Nishiura JL, Campos AH, Boim MA, et al. Phyllanthus niruri normalizes elevated urinary calcium levels in calcium stone forming (CSF) patients. Urological Research. Oct. 2004;32(5):362-6. follow up less than 12 months. [pmid: 15221244].
40 Mortensen JT, Schultz A, Ostergaard AH. Thiazides in the prophylactic treatment of recurrent idiopathic kidney stones. International Urology & Nephrology. 1986;18(3):265-9. not eligible treatment. [pmid: 3533825].
41 Miyaoka R, Monga M. Use of traditional Chinese medicine in the management of urinary stone disease. International Braz J Urol. Jul–Aug. 2009;35(4):396-405. not controlled trial. [pmid: 19719854].
42 Miao TJ, et al. An evaluation of effect of magnetized water in the treatment of urinary calculus by double-blind test. Chinese Journal of urology. 1984;(3):135-6. not available in English.
43 Messing B, Thuillier F, Roche D, et al. Is hypercalciuria in total parenteral feeding reduced by additional phosphate binding?. Gastroenterologie Clinique et Biologique. 1986;(3):268. not available in English.
44 Menon VB, Baxmann AC, Froeder L, et al. Effects of calcium supplementation on body weight reduction in overweight calcium stone formers. Urological Research. Jun. 2009;37(3):133-9. not treatment to prevent recurrent stones. [pmid: 19326108].
45 Matts JP, Fitch LL, Long JM. Design of the POSCH kidney stone trial. The POSCH Group. [abstract]. Controlled clinical trials. 1989:323. available in abstract form only.
46 Mattle D, Hess B. Preventive treatment of nephrolithiasis with alkali citrate—a critical review. Urological Research. May. 2005;33(2):73-9. not controlled trial. [pmid: 15875173].
47 Massey LK, Kynast-Gales SA. Diets with either beef or plant proteins reduce risk of calcium oxalate precipitation in patients with a history of calcium kidney stones. Journal of the American Dietetic Association. Mar. 2001;101(3):326-31. follow up less than 12 months. [pmid: 11269613].
48 Martins MC, Meyers AM, Whalley NA, et al. Indapamide (Natrilix): the agent of choice in the treatment of recurrent renal calculi associated with idiopathic hypercalciuria. British Journal of Urology. Aug. 1996;78(2):176-80. follow up less than 12 months. [pmid: 8813907].
49 Makrigiannis D. A new method for the treatment of renal and ureteral calculi colic. Die Medizinische Welt. 1969:1718-9. not available in English. [pmid: 5816549].
50 Lorentzen JE, Lund F, Andersen B, et al. Effect of Radison water in treatment of patients with renal calculi. A randomized double-blind method. Ugeskrift for laeger. 1979;(9):579-81. not available in English. [pmid: 371092].
51 Ljunghall S, Fellstrom B, Johansson G. Prevention of renal stones by a high fluid intake?. European Urology. 1988;14(5):381-5. not controlled trial. [pmid: 3169081].
52 Lieske JC, Tremaine WJ, De Simone C, et al. Diet, but not oral probiotics, effectively reduces urinary oxalate excretion and calcium oxalate supersaturation. Kidney International. Dec. 2010;78(11):1178-85. follow up less than 12 months. [pmid: 20736987].
53 Laerum E, Larsen S. Is it possible to characterize recurrent urinary stone formers who benefit from thiazide prophylaxis? Application of discrimination analysis. Acta Medica Scandinavica. 1987;221(1):103-8. not relevant clinical outcome. [pmid: 3551506].
54 Laerum E. Metabolic effects of thiazide versus placebo in patients under long-term treatment for recurrent urolithiasis. Scandinavian Journal of Urology & Nephrology. 1984;18(2):143-9. not eligible treatment. [pmid: 6463598].
55 Kumar A. Influence of radish consumption on urinary calcium oxalate excretion. Nepal Medical College Journal: NMCJ. Jun. 2004;6(1):41-4. not controlled trial. [pmid: 15449653].
56 Kohri K, Kodama M, Katayama Y, et al. Allopurinol and thiazide effects on new urinary stone formed after discontinued therapy in patients with urinary stones. Urology. Oct. 1990;36(4):309-14. not eligible treatment. [pmid: 2219608].
57 Kennedy KP, Bhatt JR, Macdonagh RP. Dietary advice for patients with renal stones: are we practising evidence-based medicine?. BJU International. May. 2006;97(5):903-4. not controlled trial. [pmid: 16643468].
58 Kairaitis L. Caring for Australians with Renal I. The CARI guidelines. Kidney stones: prevention of recurrent calcium nephrolithiasis. Nephrology. Feb. 2007;12(Suppl 1):S11-20. not controlled trial. [pmid: 17316271].
59 Jiménez Verdejo A, Arrabal Martín M, Miján Ortiz JL, et al. Effect of potassium citrate in the prophylaxis of urinary lithiasis. Archivos espanoles de urologia. 2001;(9):1036-46. not available in English. [pmid: 11789361].
60 Jaipakdee S, Prasongwatana V, Premgamone A, et al. The effects of potassium and magnesium supplementations on urinary risk factors of renal stone patients. Journal of the Medical Association of Thailand. Mar. 2004;87(3):255-63. not treatment to prevent recurrent stones. [pmid: 15117041].
61 Jaeger P, Portmann L, Jacquet AF, et al. Optimal dosage of chlorthalidone in the prevention of the recurrence of nephrolithiasis is 25 mg per day. Schweizerische medizinische Wochenschrift. 1986;(10):305-8. not available in English. [pmid: 3961448].
62 Jaeger P, Portmann L, Bugnon JM, et al. Incidence of hyperoxaluria in idiopathic calcium nephrolithiasis. Schweizerische medizinische Wochenschrift. 1982;(49):1795-8. not available in English. [pmid: 7178877].
63 Hughes P. Caring for Australians with Renal I. The CARI guidelines. Kidney stones epidemiology. Nephrology. Feb. 2007;12(Suppl 1):S26-30. not controlled trial. [pmid: 17316273].
64 Hughes P. Caring for Australians with Renal I. The CARI guidelines. Kidney stones: metabolic evaluation. Nephrology. Feb. 2007;12(Suppl 1):S31-3. not controlled trial. [pmid: 17316274].
65 Hughes J, Norman RW. Diet and calcium stones. CMAJ Canadian Medical Association Journal. Jan. 15. 1992;146(2):137-43. not controlled trial. [pmid: 1310430].
66 Huen SC, Goldfarb DS. Adverse metabolic side effects of thiazides: implications for patients with calcium nephrolithiasis. Journal of Urology. Apr. 2007;177(4):1238-43. not controlled trial. [pmid: 17382697].
67 Hesse A, Strenge A, Bach D, et al. Medicinal Teas in the Prophylaxis of Urinary Calculus. Effects of Solubitrat on the Excretion of Lithogenic and Inhibitory Substances. Munchener Medizinische Wochenschrift. 1981;(13):521-4. not available in English. [pmid: 6785581].
68 Henriquez-La Roche C, Rodriguez-Iturbe B, Parra G. Increased urinary excretion of prostaglandin E2 in patients with idiopathic hypercalciuria is a primary phenomenon. Clinical Science. Jul. 1992;83(1):75-80. not relevant clinical outcome. [pmid: 1325325].
69 Heaney RP. Calcium supplementation and incident kidney stone risk: a systematic review. Journal of the American College of Nutrition. Oct. 2008;27(5):519-27. not controlled trial. [pmid: 18845701].
70 Heaney RP. Calcium intake and disease prevention. Arquivos Brasileiros de Endocrinologia e Metabologia. Aug. 2006;50(4):685-93. not controlled trial. [pmid: 17117294].
71 He HC, Zhong WD, Xie KJ, et al. Effects of potassium citrate delayed preparation in urine PH and citric acid content. Zhonghua yi xue za zhi. 2004;(21):1825-6. not available in English. [pmid: 15631783].
72 Gurocak S, Kupeli B. Consumption of historical and current phytotherapeutic agents for urolithiasis: a critical review. Journal of Urology. Aug. 2006;176(2):450-5. not controlled trial. [pmid: 16813863].
73 Goldfarb DS. Prospects for dietary therapy of recurrent nephrolithiasis. Advances in Chronic Kidney Disease. Jan. 2009;16(1):21-9. not controlled trial. [pmid: 19095202].
74 Gleeson MJ, Thompson AS, Mehta S, et al. Effect of unprocessed wheat bran on calciuria and oxaluria in patients with urolithiasis. Urology. Mar. 1990;35(3):231-4. not relevant clinical outcome. [pmid: 2156368].
75 Flagg LR. Dietary and holistic treatment of recurrent calcium oxalate kidney stones: review of literature to guide patient education. Urologic Nursing. 2007 quiz 123. Apr. 2007;27(2):113-22. not controlled trial. [pmid: 17494450].
76 Fink HA, Akornor JW, Garimella PS, et al. Diet, fluid, or supplements for secondary prevention of nephrolithiasis: a systematic review and meta-analysis of randomized trials. European Urology. Jul. 2009;56(1):72-80. not controlled trial. [pmid: 19321253].
77 Fernández-Rodríguez A, Arrabal-Martín M, García-Ruiz MJ, et al. The role of thiazides in the prophylaxis of recurrent calcium lithiasis. Actas urologicas espanolas. 2006;(3):305-9. not available in English. [pmid: 16749588].
78 Fernández Rodríguez A, Arrabal Martín M, García Ruiz MJ, et al. Effect of thiazide therapy in the prophylaxis of calcium lithiasis. Archivos espanoles de urologia. 2001;(9):1047-54. not available in English. [pmid: 11789362].
79 Fellstrom B, Danielson BG, Karlstrom B, et al. The influence of a high dietary intake of purine-rich animal protein on urinary urate excretion and supersaturation in renal stone disease. Clinical Science. Apr. 1983;64(4):399-405. follow up less than 12 months. [pmid: 6825409].
80 Fellstrom B, Backman U, Danielson BG, et al. Allopurinol treatment of renal calcium stone disease. British journal of urology. 1985;(4):375-9. not controlled trial. [pmid: 4027505].
81 Ettinger B. Recurrent nephrolithiasis: natural history and effect of phosphate therapy. A double-blind controlled study. American Journal of Medicine. Aug. 1976;61(2):200-6. not eligible treatment. [pmid: 782240].
82 Escribano J, Balaguer A, Pagone F, et al. Pharmacological interventions for preventing complications in idiopathic hypercalciuria. Cochrane Database of Systematic Reviews. 2009;(1):CD004754. not controlled trial. [pmid: 19160242].
83 Erickson SB, Vrtiska TJ, Canzanello VJ, et al. Cystone® for 1 year did not change urine chemistry or decrease stone burden in cystine stone formers. Urological Research. 2010:1-7. follow up less than 12 months.
84 Erickson S, Vrtiska T, Lieske J. Effect of Cystone® on urinary composition and stone formation over a one year period. Phytomedicine. 2011.
85 Dussol B, Saveanu A, Rotily M, et al. Effects of low-animal protein or high-fiber diets on urine composition in calcium nephrolithiasis. [abstract no: PUB452]. Journal of the American Society of Nephrology. Oct. 2004:857a. available in abstract form only.
86 Dussol B, Saveanu A, Leonetti F, et al. A 4-year randomized controlled trial of low animal protein or high-fiber diets for secondary prevention of idiopathic calcium nephrolithiasis. [abstract no: TH-F-DS876]. Journal of the American Society of Nephrology. (Abstracts). 2006:521a. available in abstract form only. [pmid: 16382018].
87 Domrongkitchaiporn S, Khositseth S, Stitchantrakul W, et al. Dosage of potassium citrate in the correction of urinary abnormalities in pediatric distal renal tubular acidosis patients. American Journal of Kidney Diseases. Feb. 2002;39(2):383-91. not adults. [pmid: 11840381].
88 Cicerello E, Merlo F, Gambaro G, et al. Effect of alkaline citrate therapy on clearance of residual renal stone fragments after extracorporeal shock wave lithotripsy in sterile calcium and infection nephrolithiasis patients. Journal of Urology. Jan. 1994;151(1):5-9. not patients 90 days post SWL. [pmid: 8254832].
89 Churchill DN. Medical treatment to prevent recurrent calcium urolithiasis. A guide to critical appraisal. Mineral &. Electrolyte Metabolism. 1987;13(4):294-304. not controlled trial. [pmid: 3627054].
90 Campoy Martínez P, Arrabal Martín M, Blasco Hernández P, et al. Orange juice in the prevention of calcium oxalate lithiasis. Actas urologicas espanolas. 1994;(7):738-43. not available in English. [pmid: 7942234].
91 Brocks P, Dahl C, Wolf H, et al. Do thiazides prevent recurrent idiopathic renal calcium stones?. Lancet. Jul. 18. 1981;2(8238):124-5. not eligible treatment. [pmid: 6113485].
92 Brocks P, Dahl C, Transbøl I, et al. Do thiazides prevent recurrent renal calculi? Preliminary results of a double-blind controlled study. Ugeskrift for laeger. 1982;(23):1669-70. not available in English. [pmid: 6753287].
93 Borghi L, Meschi T, Schianchi T, et al. Medical treatment of nephrolithiasis. Endocrinology & Metabolism Clinics of North America. Dec. 2002;31(4):1051-64. not controlled trial. [pmid: 12474645].
94 Becker G. Caring for Australians with Renal I. The CARI guidelines. Kidney stones: uric acid stones. Nephrology. Feb. 2007;12(Suppl 1):S21-5. not controlled trial. [pmid: 17316272].
95 Becker G. Caring for Australians with Renal I. The CARI guidelines. Kidney stones: cystine stones. Nephrology. Feb. 2007;12(Suppl 1):S4-10. not controlled trial. [pmid: 17316277].
96 Baumann JM, Bisaz S, Fleisch H, et al. Biochemical and clinical effects of ethane-1-hydroxy-1,1-diphosphonate in calcium nephrolithiasis. Clinical Science & Molecular Medicine. May. 1978;54(5):509-16. not treatment to prevent recurrent stones. [pmid: 108043].
97 Bach D, Hesse A, Strenge A, et al. Teecura diuretic tea in prophylaxis of relapsing urolithiasis. Zeitschrift für Allgemeinmedizin. 1981;(14):1113-8. not available in English. [pmid: 7269761].
98 Bach D, Hesse A, Strenge A, et al. Prevention of urinary calculi by means of a benzbromarone-citrate combination. Fortschritte der Medizin. 1980;(44):1752-5. not available in English. [pmid: 7461567].
99 Ackermann DK. Prospective therapeutic studies in nephrolithiasis. World Journal of Urology. 1997;15(3):172-5. not controlled trial. [pmid: 9228724].