# Search Strategy

## Ovid MEDLINE Search Strategy

1. urolith*.mp. or exp Urolithiasis/
2. (urinary calcul* or kidney calcul* or ureteral calcul* or renal calcul* or kidney stone*).mp.
3. renal colic.mp. or exp Renal Colic/
4. hypercalciuria.mp. or exp Hypercalciuria/
5. exp Hyperoxaluria, Primary/ or exp Hyperoxaluria/ or hyperoxaluria.mp.
6. hyperuricemia.mp. or exp Hyperuricemia/
7. cystinuria.mp. or exp Cystinuria/
8. (hyperuricosuria or hypercitraturia or nephrolith*).mp.
9. (calcium stone* or calcium phosphate stone* or calcium oxalate stone* or uric acid stone* or urate stone* or cystine stone* or struvite stone*).mp.
10. or/1–9
11. limit 10 to (controlled clinical trial or meta analysis or randomized controlled trial)
12. limit 10 to systematic reviews
13. 11 or 12
14. exp meta-analysis/
15. exp randomized controlled trials/ or systematic review.mp.
16. exp controlled clinical trial/
17. or/14–16
18. 10 and 17
19. 13 or 18
20. limit 19 to English language

## Cochrane Central Register of Controlled Trials (CENTRAL) Search Strategy

1. (urolith$ or urolithiasis):ti,ab,kw in Clinical Trials
2. urinary calcul* or kidney calcul* or ureteral calcul* or renal calcul* or kidney stone* in Clinical Trials
3. renal colic in Clinical Trials
4. hypercalciuria in Clinical Trials
5. hyperoxaluria in Clinical Trials
6. hyperuricemia in Clinical Trials
7. cystinuria in Clinical Trials
8. hyperuricosuria or hypercitraturia or nephrolith* in Clinical Trials
9. calcium stone* or calcium phosphate stone* or calcium oxalate stone* or uric acid stone* or urate stone* or cystine stone* or struvite stone* in Clinical Trials
10. urolith* or Urolithiasis in Clinical Trials
11. (1 OR 2 OR 3 OR 4 OR 5 OR 6 OR 7 OR 8 OR 9 OR 10)