# Acronyms and Abbreviations

AHA: Acetohydroxamic acid
ACP: American College of Physicians
AUA: American Urological Association
AHRQ: Agency for Healthcare Research and Quality
BMI: Body mass index
CENTRAL: Cochrane Central Register of Controlled Trials
CI: Confidence interval
dL: Deciliter
EHC: Effective Health Care
FDA: Food and Drug Administration
KQ: Key Questions
kg: Kilogram
mg: Milligram
PICOTS: Population, intervention, comparator, outcome, timing, setting
RCT: Randomized controlled trial
RR: Relative risk
TEP: Technical Expert Panel