# Technical Expert Panel

Paul P. Lee, M.D., J.D.

Duke Ophthalmology

Duke University School of Medicine

Durham, NC

Jeffrey Liebmann, M.D.

New York University School of Medicine Glaucoma Services

New York, NY

Flora Lum, M.D.

H. Dunbar Hoskins Center for Quality Eye Care

American Academy of Ophthalmology

San Francisco, CA

Diana Petitti, M.D., M.P.H.

Arizona State University

Phoenix, AZ