# Results

We identified 73 RCTs, 13 observational studies and 23 systematic reviews. The flow search for the literature search for the systematic reviews is described in Figure 2 and the flow search for the literature search for primary studies is described in Figure 3. Details of all studies and systematic reviews are included in Evidence Tables in Appendix C. A listing of included articles, with reason(s) for exclusion is provided in Appendix D.

Figure 2 Systematic review literature search for treatment of open-angle glaucoma

* Total may exceed number in corresponding box, as articles excluded by two reviewers at this level.

We identified 169 systematic reviews from the search in the databases. After exclusion at abstract level we included 48 or full text review. From those we excluded 25 based on quality criteria. We included for our review a total of 23 systematic reviews. Twelve reviews addressed the comparative effectiveness of medical treatment of open-angle glaucoma, 9 addressed questions of surgical treatment, and 1 compared medical versus surgical treatments for open-angle glaucoma. One additional review addressed the comparative effectiveness of glaucoma surgeries versus one another as well as surgeries versus medical treatments for open-angle glaucoma.

Figure 3 Primary study literature search for treatment of open-angle glaucoma

* Total may exceed number in corresponding box, as articles were excluded by two reviewers at this level.

** Total may exceed number in corresponding box, as some articles were covered by more than one systematic review.

*** Total may exceed number in corresponding box, as articles may apply to more than one key question

**** Other reasons: e.g. comparisons of case series, patient education reports, type of study does not correspond to the KQ, laboratory or autopsy data, letter or commentaries, drugs out of the list.

The search identified 10770 titles. 9680 were eligible after for abstract review. After applying our exclusion criteria we included 2299 articles for full text review; 1933 were excluded based on our exclusion criteria and 280 were excluded because they were included in previous systematic reviews. A total of 73 RCTs and 13 observational studies addressing adverse effects (10 medical treatment and 3 surgical treatment) were included for the final document.

A summary of the number of articles included by Key Question (KQ), type of study, and type of intervention is presented in Table 1.

Table 1 Summary of literature for treatment of open-angle glaucoma

Question and Comparison | Systematic Reviews | Randomized Controlled Trials | Observational Studies
Medical Treatments
KQ 1a | 0 | 11 | NA
KQ 3a | 9 | 0 | NA
KQ 3 – circadian | 3 | 5 | NA
KQ 4a | 1 | 19 | NA
KQ 6a | 11 | 17 | 10
Surgical Treatments
KQ 1b | 2 | 4 | NA
KQ 3b | 9 | 20 | NA
KQ 4b | 0 | 0 | NA
KQ 6b | 8 | 22 | 3
Medical-Surgical Treatments
KQ 1c | 1 | 0 | NA
KQ 3c | 2 | 2 | NA
KQ 4c | 3 | 1 | NA
KQ 6c | 2 | 2 | 0
Additional Questions
KQ 2 | 2 | 9 | NA
KQ 5 | 0 | 1 | 1

KQ = Key Question; NA = not applicable

Narrative summaries of the evidence identified for KQs 1, 3, 4, and 6 are presented within each of the following treatment comparison groups: Medical treatment, surgical treatment, and medical versus surgical treatment. KQs 2 and 5 are discussed under subheadings identified by KQ. For each question and comparison, evidence from systematic reviews is discussed first, followed by evidence from primary studies.

## Medical Treatment of Open-Angle Glaucoma

### Systematic Reviews of Medical Interventions for Open-Angle Glaucoma

We included 12 systematic reviews that address the comparative effectiveness of medical interventions for open-angle glaucoma (OAG) (Appendix C). The most common comparisons included head-to-head comparisons of prostaglandin analogs,18–23 prostaglandin analogs compared to timolol,24 25 latanoprost compared to brimonidine,21 22 timolol compared to brimonidine,26 and concomitant compared to fixed combination medications.27 28 Vass (2007) provided an overview of various topical medical treatments compared to placebo, no treatment, or another medical treatment.29 While all systematic reviews included participants with OAG, some reviews also included studies that enrolled participants with mixed or “other” glaucoma (approximately 2% of participants), and chronic-angle closure glaucoma (included in population in a minimum of one trial in a single systematic review).

### KQ 1a What is the comparative effectiveness of medical treatments for reducing visual impairment?

#### Key Points

- No studies of medical therapy were identified that directly addressed outcomes related to visual impairment.
- The available studies addressing secondary outcomes of change in visual acuity and visual field loss are of too short a duration to answer this question given that glaucoma is typically a slowly progressive disease that may take many years to cause clinically or statistically significant changes.

#### Evidence From Systematic Reviews

We did not identify any systematic reviews of medical interventions for OAG that included outcomes related to visual impairment.

#### Detailed Analysis of Primary Studies

We identified eleven studies comparing medical therapies for glaucoma that also reported something about vision-related outcomes. Unfortunately, none of these reported any outcomes related to actual impairment but rather were limited to the secondary outcomes of visual acuity and visual field mean defect. Of the 11 studies, eight reported on the visual field and six on visual acuity.

Two studies demonstrated some improvement in visual field performance. The study by Prata (2009) comparing timolol, brimonidine, and travoprost, showed an overall decrease in mean deviation (−6.56 to −5.72, p=0.045) in treated subjects.30 A study comparing betaxolol to levobunolol by Marcon (1990) demonstrated some improvement in visual field performance in 1 of 20 subjects.31

Two additional studies reported no change in visual field over the course of the studies. A cross-over study of dorzolamide-timolol, travoprost, and latanoprost showed no significant change in visual field mean deviation or pattern standard deviation over 9 months of treatment,32 and a study of timolol and carteolol showed no change in the visual field over 16 weeks.33 The 9-month study used non-standard definitions of progression (2dB loss in mean deviation or one point with a decrease in threshold of 10dB) that would not be expected to be seen over the short duration of the study.

Four studies produced results suggestive of a decline in visual field but none were able to demonstrate any statistical significance. A study of carteolol vs. timolol presented the distribution of changes in visual field mean defect, which suggests that there was a net decline in both groups. But again, no statistics were provided.34 Tuulonen (1989) compared laser trabeculoplasty to topical medications and demonstrated visual field decline in both groups (−7.4 to −8.6 with laser, −9.1 to −9.4 with medications), though neither decline was statistically significant.35

Reports of visual acuity outcomes were similarly variable. The study comparing betaxolol to levobunolol by Marcon (1990) included two subjects (10%) with improved visual acuity.31 The comparison of dorzolamide-timolol, travoprost, and latanoprost by Chiselita (2005) showed no change in visual acuity over 9 months of treatment.32 Yamamoto (1996) found no subjects lost two or more lines of vision over 16 weeks in their trial of timolol and carteolol.33 Ravalico (1994) compared levobunolol to no treatment in ocular hypertensives and reported “no variation” in visual acuity, though no criteria were provided.36

Two studies reported worsening of visual acuity at some point during the study but neither outcome was believed to be due to treatment. Berson (1985) compared levobunolol to timolol and found that 57 subjects had a decline of two or more lines of visual acuity at some point, but that these were transient.37 Similarly, Schuman (1997) found a decrease of two or more lines of acuity in 5.9 percent of their brimonidine treated group and 9.5 percent of their timolol treated group, at 12 months.38 We present a summary of the studies included in the review of KQ 1a with comparators, outcomes and results (Table 2, summary table for KQ 1a).

Table 2 Summary table for KQ 1a

Study | Patients/eyes | Comparators | Outcome | Results
Berry 1984^41^ | 20 pat/35 eyes 26 pat/43 eyes | Betaxolol 0.5% Timolol 0.5% | Visual acuity | Data not reported
Berson 1985^37^ | 48 pat 51 pat 42 pat | Levobunolol 0.5% Levobunolol 1% Timolol 0.5% | Visual acuity | Transitory changes, considered unrelated to treatment
Chiselita 2005^32^ | 38 pat/38 eyes | Latanoprost Travoprost Dorzolamide/Timolol | Visual acuity | No significant change over 9 months
Flammer 1992^34^ | 35 pat 37 pat | Carteolol Timolol 0.5% | Visual acuity and visual fields | Suggested decline in visual fields defect in both arms
Liu 2002^40^ | 27 pat 27 pat | Latanoprost 0.005% Brimonidine 0.15% | Visual acuity | Data not reported
Marco 1990^31^ | 20 pat | Betaxolol 0.5% Levobunolol | Visual acuity and visual fields | No significant improvement in visual fields
Prata 2009^30^ | 17 pat 14 pat 19 pat | Timolol 0.5% Brimonidine Travoprost | Visual acuity and visual fields | No correlation between IOP reduction and changes in visual function between the 3 medications
Ravalico 1994^36^ | 12 pat/23 eyes 14 pat/26 eyes | Levobunolol 0.5% Untreated | Visual acuity | Data not reported
Sharpe 2004^39^ | 33 pat 33 pat | Brimonidine Dorzolamide | Visual acuity | Data not reported
Schuman 1997^38^ | 186 pat 188 pat | Brimonidine Timolol 0.5% | Visual acuity | Changes, considered unrelated to treatment
Yamamoto 1996^33^ | 12 pat 9 pat 12 pat | Timolol 0.5% Carteolol 1% Carteolol 2% | Visual acuity | No significant change over 16 weeks

The grading of evidence for KQ 1a with all the domains is summarized in Table 3.

Table 3 Grading of evidence for KQ 1a

Number of Studies; Participants | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Visual Impairment/Visual Acuity
11; 918 | RCT/Medium | Inconsistent | Direct | Imprecise | Insufficient

#### Conclusions

None of the studies identified were of sufficient duration or size to identify outcomes that could plausibly be related to visual impairment due to glaucoma, which is most often a slowly progressive disease. Given the relatively slow loss of vision, even in those not being treated for glaucoma, studies attempting to assess visual impairment would need to extend to perhaps 10 or more years to be able to assess differences in visual impairment. Suggesting studies of this length is supported by the relatively low rates of progression seen in the large trials of glaucoma therapy (Ocular Hypertension Treatment Study, Collaborative Initial Glaucoma Treatment Study, Advanced Glaucoma Intervention Study) but the actual duration would need to be determined based on the initial severity of disease and anticipated risk of progression in the study population.

### KQ 3a What is the comparative effectiveness of medical treatments for lowering intraocular pressure?

Evidence from systematic reviews and primary studies addressing diurnal intraocular pressure (IOP) measurements are discussed separately.

#### Key Points

- Prostaglandins lower IOP more than dorzolamide (carbonic anhydrase inhibitor, 2.64 mmHg, 3 trials), brimonidine (alpha-adrenergic agonist, 1.64 mmHg, 4 trials), and timolol (beta-adrenergic blocker, 5% greater at 6 months, 4 trials). (Systematic Review)
- The prostaglandins appear similar in the extent to which they lower IOP, but some studies have reported a greater drop in IOP with bimatoprost (prostaglandin).
- The combination dorzolamide/timolol appears to lower IOP the same amount as prostaglandins.

#### Summary of Evidence From Systematic Reviews

##### Prostaglandin Analogs Versus Timolol

Studies comparing Timolol with travoprost24 and latanoprost,25 showed prostaglandin analogs more effective at lowering IOP. The percent IOP reduction from baseline to 1 month was 4 percent greater for participants randomized to latanoprost compared to travoprost at 1 month (95% CI, 1.2 to 6.3, three trials) and 5 percent greater at 6 months (WMD 5.0; 95% CI, 2.8 to 7.3, four trials). The mean reduction in IOP after 3 or more months was 0.81 mmHg lower for participants receiving travoprost (95% CI, −1.16 to −0.45, four trials).

##### Prostaglandin Analogs (Head-to-Head Comparisons)

Two systematic reviews included comparisons of bimatoprost and latanoprost. In both reviews the investigators concluded that bimatoprost lowered IOP more effectively than latanoprost.19 20 The difference in the proportion of participants achieving an IOP less-than or equal-to 17 mm Hg was greater with bimatoprost at 3 months, (Risk difference [RD], 12; 95% confidence interval [CI], 4 to 21, two trials), but no difference was found at 1 and 6 months.19 Cheng (2008) also noted a significant mean percent reduction in morning IOP with bimatoprost versus latanoprost (2.6% at 1 month, 2.4% at 3 months, and 5.6% at 6 months)19 and Eyawo (2009) reported significant mean IOP reduction with bimatoprost at 3 or more months of follow-up (weighted mean difference [WMD], 0.73; 95% CI, 0.10 to 1.37, eight trials).20

Both Eyawo (2009) and Li (2006) compared travoprost to latanoprost and to bimatoprost.20 24 Both reviews concluded that mean IOP reduction was similar when comparing travoprost to latanoprost. Li (2006) and Eyawo (2009) differed in their conclusions regarding bimatoprost versus travoprost, as Eyawo reported a significant difference in favor of bimatoprost at 3 or more months of followup (WMD, 0.88; 95% CI, 0.13 to 1.63, eight trials),20 while Li concluded that bimatoprost and travoprost were similarly effective (WMD 0.08; 95% CI, −0.62 to 0.79, five trials).24

#### Concomitant Versus Fixed Combination Medical Treatments

Cheng (2009) reported no difference in the mean percent reduction in IOP at 10 a.m., when they compared latanoprost to dorzolamide/timolol combination treatment.25 Cox (2009) undertook a more general analysis of concomitant versus fixed combinations including travoprost, brimonidine, dorzolamide, bimatoprost, or latanoprost combined with a beta blocker.28 Overall concomitant administration resulted in a larger mean difference in IOP from baseline to 3 months, although the difference was significant only when IOP was measured at 2 hours (WMD, 0.39; 95% CI 0.04 to 0.75, six trials) and 8 hours (WMD, 0.50; 95% CI, 0.16 to 0.85, four trials) after a dose of medication.

#### Other Comparisons

Loon (2008) concluded that timolol and brimonidine were similarly effective after comparisons of the two medications in eight trials of varying follow-up periods, and after conducting subgroup analyses of trials of less than and more than 6 months of followup (three and five trials, respectively).26

Fung (2007) and Hodge (2008) compared latanoprost and brimonidine. Fung (2007) concluded that use of latanoprost resulted in a greater mean reduction of IOP in a group of heterogeneous trials of varying duration (WMD 1.10 mmHg; 95% CI, 0.57 to 1.63, 14 trials).21 Subgroup analyses of trials of less than 6 months duration and those with 8 or more months of follow-up supported the trend of lower mean IOP among those using latanoprost, with a mean difference in IOP lowering of 1.64 mm Hg in trials of greater than or equal to 8 months (95% CI, 0.92 to 2.36, four trials). Hodge (2008) reported no difference in mean IOP at 3 months (WMD, −1.04l 95% CI, −3.01 to 0.93, three trials). 22

Hodge (2008) compared latanoprost and dorzolamide. Participants receiving latanoprost had lower IOP on average at 3 months (WMD, −2.64; 95% CI, −3.25 to −2.04, three trials).22

#### Detailed Analysis of Primary Studies

The primary studies identified as part of our search were all subsumed by the available systematic reviews.

#### Grading of Evidence

The assessment of the quality of evidence reported by the included systematic reviews were determined to be adequate so the included studies were not re-evaluated using the additional criteria used for the primary studies included elsewhere in this report.

#### Conclusions

As single agents, prostaglandins are currently the most effective at lowering IOP. Some studies have found greater IOP lowering with bimatoprost, but this has not been a consistent finding. The combination of dorzolamide and timolol appears to lower IOP about the same amount as prostaglandins.

#### Effect of Medical Treatments on Circadian Intraocular Pressure

There is some evidence from clinical trials that fluctuation of IOP throughout the day (diurnal variation) may be important in terms of predicting future progression. We therefore explicitly included studies that evaluated this aspect of glaucoma medications.

##### Key Points

- Our conclusions regarding the effect of topical therapies in lowering IOP over the 24-hour time period were limited due to the fact that one study provided almost all of the data.
- All topical medications reviewed appear to lower IOP throughout the 24-hour cycle.
- Prostaglandins appear to lower IOP more over the 24-hour cycle than beta-blockers, topical carbonic anhydrase inhibitors and alpha agonists, but the evidence for this is weak.
- While the IOP lowering effects of different prostaglandins appear to vary appreciably over the 24-hour time period, the results were inconsistent and the reported difference in the amount of IOP lowering was on the order of 1 mmHg.
- Results from systematic reviews comparing one prostaglandin to another were inconsistent.

##### Summary of Evidence From Systematic Reviews

Aptel (2008) performed a meta-analysis of mean IOP reduction for head-to-head comparisons of prostaglandin analogs based on IOP measurements taken at 8 a.m., 12 p.m., 4 p.m., and 8 p.m.18 IOP reduction was significantly greater with use of bimatoprost, when compared to latanoprost, at all time periods. Mean IOP reduction of bimatoprost was greater than travoprost at 8 a.m. and 12 p.m., but not different at the 4 p.m. and 8 p.m. time periods.18 In addition, travoprost had roughly the same effectiveness as latanoprost at lowering IOP across all time periods under investigation.

Cheng (2008) looked at the percent reduction in circadian IOP from baseline in three trials comparing bimatoprost and latanoprost and found that mean reduction was not different at follow-up (2.5% at 1 month and 2.1% at 3 months).19

Cheng (2009) compared latanoprost to dorzolamide/timolol combination treatment (including studies of both fixed and concomitant administration of dorzolamide/timolol) and found no difference in diurnal mean percent reduction in IOP at any time point (1, 2, 3, and 6 months).27

###### Detailed Analysis of Primary Studies

The medications used to lower IOP may not have equal effectiveness at different time points during the day. It is possible that some medications work better at night than others while others may work better during the daytime hours. The main way to assess this difference is to measure the IOP over the entire 24-hour period. Five RCTs met the inclusion criteria. IOP outcomes for the five RCTs were largely reported graphically and so we provide a narrative summary of the findings.

We present a summary of the studies included in the review of circadian studies with comparators, outcomes and results (Table 4).

Table 4 Summary table for circadian studies

Study | Comparators | Patients | Treatment Specifics | Mean IOP Baseline (mmHg) | Conclusions
Larsson 2001^44^ | Latanoprost 0.005% Timolol 0. 5% | 27 pts Cross over | Wash out 4w Duration 4w | 23.8 | Better effect on IOP with latanoprost than Timolol. No effect on blood pressure or heart rate
Orzalesi 2006^46^ | Latanoprost 0.005% Bimatoprost 0.03% Travoprost 0.04% | 44 pts Cross over | Wash out 4w Duration 1m | 21.9 | IOP was reduced with the 3 drugs, more so with bimatoprost. No effect on blood pressure.
Quaranta 2008^42^ | Latanoprost 0.005% Bimatoprost 0.03% | 40 pts Cross over | Wash out 6 w Duration 8w | ≤21 | No significant difference in IOP or blood pressure
Quaranta 2006^43^ | Latanoprost 0.005% Timolol 0.5% Brimonidine 0.2% Dorzolamide 2% | 27 pts Cross over | Wash out 4w Duration 6w | 24.2 | All drugs decreased IOP but latanoprost lowered it more. Some effect on blood pressure with Timolol and Brimonidine.
Yildirim 2008^45^ | Latanoprost 0.005% Bimatoprost 0.03% Travoprost 0.04% | 17 16 15 | Wash out NS Duration 8w | 22.3 22.6 23.4 | IOP was reduced with the 3 drugs with no significant difference between the 3

Quaranta (2008) studied latanoprost versus bimatoprost in 40 newly diagnosed participants with glaucoma with IOP less than or equal to 21 mmHg when measured once every two hours from 8 a.m. until 8 p.m.42 The trial randomized participants to either bimatoprost or latanoprost for 8 weeks, followed by a 24-hour IOP assessment. Participants then crossed over to the other drug for another 8 weeks, followed by a 24-hour IOP assessment. There was no difference over the 24-hour period between the two treatments. IOP dropped between 1.5 and 3.5 mmHg at different time points with an average drop of 2 mmHg from a mean of 15.5 mmHg. Blood pressure (monitored over 24 hours) did not change when using either medication.

A separate study, by the same authors involved a cohort of 27 newly diagnosed glaucoma patients with IOP greater than or equal to 23 mmHg and less than or equal to 32 mmHg (computed by taking the average of the two highest IOP measurements between 8 a.m. and 6 p.m.) The study randomized the patients to timolol 0.5 percent, brimonidine 0.2 percent, dorzolamide 0.2 percent (all given twice a day) and latanoprost (given once a day) in a crossover design in which all four medications were used by each of the patients for 6 weeks followed by 4-week washout periods.43 Latanoprost lowered IOP about 1 mmHg more than the other medications over the 24-hour time period, and no differences were seen when comparing the other medications to themselves in other arms of the study. All drugs decreased IOP at all time points over 24 hours. Both brimonidine and timolol lowered IOP less during sleeping hours than latanoprost. Brimonidine and timolol lowered systolic blood pressure and diastolic blood pressure compared to baseline over 24 hours, and brimonidine lowered it the most, especially at night.

Larsson (2001) randomized 27 participants with IOP greater than 21 mmHg (who did not have glaucoma) to 4 weeks of either timolol 0.5 percent gel (once a day in the morning) or latanaprost (once a day in the evening) with a washout of 4 weeks before crossover.44 Latanoprost lowered IOP more than timolol gel at every time point by an average of about 1.5 mmHg with a slightly greater reduction observed during sleeping hours. The study saw no differences in systolic blood pressure, diastolic blood pressure or heart rate were noted over 24 hours.

In a randomized 8-week trial, Yildrin (2008) compared latanoprost, bimatoprost and travaprost in 48 participants with IOP greater than 22 mmHg who had not previously received IOP lowering therapy.45 All three medications lowered IOP at all time points. The only observed difference between the medications was travaprost lowered IOP more than the other two at 8 a.m. and 10 a.m.

Orsalezi (2006) compared latanoprost, bimatoprost and travaprost in 44 patients with either primary OAG or ocular hypertension (OHT) and IOP greater than 21 mmHg, who had not previously received prostaglandin. The trial was a randomized cross-over study in which patients used the drugs for 1 month prior to each 24-hour measurement.46 All three medications lowered IOP by about 7 mmHg, however bimatoprost lowered IOP more at most time points by about one mmHg. None of the medications had any effect on blood pressure.

The grading of evidence for circadian studies is summarized in Table 5.

Table 5 Grading of evidence for circadian studies

Number of Studies; Participants | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Diurnal Intraocular Pressure
5; 186 | RCT/Medium | Inconsistent | Direct | Imprecise | Low

##### Conclusions

Of the available monotherapies, prostaglandins appear to lower IOP most throughout the circadian period. Combination timolol/dorzolamide appears to be equally effective. Most findings are from single studies comparing specific agents, so the evidence is relatively weak. The importance of fluctuations in IOP throughout the 24-hour period on long-term outcomes for glaucoma patients is not known. Studies looking at fluctuation in eye pressure over long periods of time have had inconsistent results with some reporting worse outcomes with greater fluctuations and others reporting no difference.

### KQ 4a What is the comparative effectiveness of medical treatments for preventing or slowing the progression of optic nerve damage and visual field loss?

#### Key Points

- A systematic review of medical treatment for glaucoma determined treatment to be protective against progressive visual field loss. This review included the results of both the Early Manifest Glaucoma Trial and the Ocular Hypertension Treatment Study.
- Other included primary studies are of insufficient size or duration to detect differences in the rates of optic nerve damage or visual field loss. Given the slowly progressive nature of glaucoma, the large trials of glaucoma therapy (summarized elsewhere) have demonstrated the need to follow hundreds of participants for 5 or more years to detect change.
- A single study addressed the comparative effectiveness of glaucoma medications with respect to their ability to prevent optic nerve damage or visual field loss and found brimonidine superior to timolol.

#### Summary of Evidence From Systematic Reviews

Vass (2007) reported that any topical medical treatment (including beta blockers and studies with unspecified topical medications) had a significant protective effect on incident visual field defect progression when compared to placebo or no treatment (odds rations [OR]. 0.62; 95% CI, 0.47 to 0.81, 10 trials). Beta blockers were also protective when compared to placebo (OR, 0.67; 95% CI, 0.45 to 1.00, eight trials), as was timolol when compared to carteolol.29 Participants randomized to timolol, however, experienced a twofold higher odds of visual field defects when compared to participants receiving levobunolol (95% CI, 1.17 to 4.14, two trials).

#### Detailed Analysis of Primary Studies

Two studies reported an improvement in visual field with topical medical treatment. Prata (2009) showed an improvement in mean deviation across their entire population of subjects taking timolol, brimonidine, or travoprost.30 This was only a 4-week study and included no control group. The study of betaxolol versus levobunolol by Marcon (1990) found one subject of 20 whose visual field improved over 12 weeks of treatment, though criteria were not specified.31 An additional seven studies found no change in visual field parameters. The subanalysis of the Ocular Hypertension Treatment Study by Herman (2006) regarding cataract formation, reported no statistically significant change in either foveal sensitivity or visual field mean deviation.47 An evaluation of dorzolamide-timolol versus travoprost versus latanoprost showed no change in mean deviation or pattern standard deviation after 9 months.32 A comparison of timolol to betaxolol by Rainer (2003) revealed an improvement in the mean deviation for the betaxolol group alone but no significant difference in final mean deviation between the two groups.48 The study of timolol, metipranolol, and carteolol by Mirza (2000) did not find any change in visual field parameters over 3 months.49 Using a custom analysis of visual field point clusters of the Octopus G1 pattern, Vainio-Jylha and Vuori (1999) found no changes in visual fields over their 24-month study of betaxolol and timolol.50 Finally, the study of timolol versus carteolol by Yamamoto (1996) found no change in visual field over 16 weeks.33

An additional nine studies were identified in which visual field measures worsened. The crossover study of latanoprost and timolol by Evans (2008) did not report on all visual field outcomes but did find that the latanoprost-then-timolol group had a statistically significant worsening of mean deviation (−1.49 to −2.41, p=0.04).51 Dirks (2006), comparing latanoprost to bimatoprost, found one subject in the latanoprost group worsened by unspecified visual field criteria.52 The European Glaucoma Prevention Study compared dorzolamide to placebo and found that in both groups, visual field worsened at a similar rate over 5 years.53 Similarly, a study of ocular hypertensives randomized to placebo or timolol found less disease progression in the treated group but the difference was not statistically significant.54 A study of brimonidine and timolol treatment found that two subjects of 48 and 46 (enrolled respectively in each group) worsened but, again, the criteria were not specified.55 Messmer (1991) randomized subjects to betaxolol or timolol and found that both groups improved during the initial 6 months and then worsened.56 Without clear statistical analysis, they report that the slope of the mean sensitivity in the betaxolol group was more positive. Another study of carteolol and timolol using the Octopus G1 pattern reports the distribution of the slope of the mean defect. This analysis seems to show disease progression in both groups but there are no analyses.34 Finally, Berry (1984) compared timolol and betaxolol and found that three of 35 eyes treated with betaxolol and two of 43 eyes treated with timolol worsened, although their conclusion was that this was due to “normal variation.”41

The Low-pressure Glaucoma Treatment Study (Krupin 2011) compared brimonidine to timolol in subjects with glaucoma at normal IOP. The investigators found the brimonidine group was significantly less likely than the timolol group to have visual field progression (9% vs. 39.2%, p=0.001).

One additional study (Martinez 2010) compared dorzolamide added to timolol with brinzolamide added to timolol and found that there was less visual field progression in the group receiving dorzolamide.57

Only one additional primary study was identified that addressed optic nerve changes. The European Glaucoma Progression Study found statistically similar risk of disease progression (by optic disc criteria) in the dorzolamide and placebo groups.53

The grading of evidence for KQ 4a with all the domains is summarized in Table 6.

Table 6 Grading of evidence for Key Question 4a

Number of Studies; Participants | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Visual Field
19;3079 | RCT/Low | Inconsistent | Direct | Imprecise | Low
Optic Nerve Changes
1;1076 | RCT/Low | N/A | Direct | Imprecise | Insufficient

#### Conclusions

A systematic review of medical treatment for glaucoma found treatment to be protective against visual field progression. Most other studies were not large enough or not of a long enough duration to detect differences in the rates of optic nerve damage or visual field loss. No other systematic reviews or individual studies addressed the comparative effectiveness of glaucoma medications with respect to their ability to prevent optic nerve damage or visual field loss.

Most of the primary studies found in our search were of inadequate duration to detect any changes in the optic nerve or visual field. Of the large studies evaluating medical therapy for glaucoma, both the Ocular Hypertension Treatment Study and the Early Manifest Glaucoma Study (which also included treatment with laser trabeculoplasty) showed a decreased rate of visual field loss and progressive optic nerve damage in those subjects treated with medications. Among such studies, only the European Glaucoma Prevention Study (EGPS) failed to find such a difference between treatment and placebo. Two important limitations of the EGPS were the relatively high loss to follow up and the fact that the response to placebo treatment was significantly higher than in prior studies. Based on the results of the Ocular Hypertension Treatment Study and the Early Manifest Glaucoma Trial, medical treatments decrease the risk of progression by 50 percent or less.

Only one of the primary studies was appropriately designed to compare rates of progression by visual field or optic nerve criteria between any two or more medications and found that brimonidine was superior to timolol in this regard.

Note that one key study in this area, the Ocular Hypertension Treatment Study (OHTS) is included in the discussion of a systematic review that is discussed in the section for KQ 4 in the medical versus surgical treatments, below.

### KQ 6a What are the harms associated with medical treatments for open-angle glaucoma?

#### Key Points

- The prostaglandin agents produce more ocular redness than does timolol (beta-adrenergic blocker). (Systematic review)
- Within the prostaglandins, latanoprost is less likely to cause redness. (Systematic review)
- Subjects on timolol (beta-blocker) were less likely to drop out of studies due to side effects than those on brimonidine (alpha-adrenergic agonist), latanoprost (prostaglandin analog), travoprost (prostaglandin analog), or betaxolol (beta-blocker). (Systematic review)

#### Summary of Evidence From Systematic Reviews

Bimatoprost was associated with a higher risk of conjunctival hyperemia when compared to other prostaglandin analogs. Aptel (2008) noted that the risk of conjunctival hyperemia was 1.7 times as high among participants receiving bimatoprost when compared to participants receiving latanoprost (95% CI, 1.44 to 2.02, five trials). 18 Cheng (2008), Eyawo (2009), and Honrubia (2009) reported similar results for the same comparison.19 20 23 Aptel (2008) and Li (2006) reported similar results after comparing bimatoprost to travoprost.18 24 However, in one trial Eyawo (2009) found the opposite result (higher risk among those using travoprost).20 Cheng (2008) further noted that there were no significant differences in other adverse effects such as eye irritation, ocular inflammation, cystoid macular edema, and iris pigmentation with use of bimatoprost versus latanoprost.19

Aptel (2008), Eyawo (2009), Honrubia (2009), and Li (2006), reported the harms related to use of latanoprost versus travoprost.18,20,23,24 In these systematic reviews, participants randomized to latanoprost were less likely to experience conjunctival hyperemia when compared to travoprost. From a meta-analysis of six randomized trials, Eyawo (2009) reported 49 percent lower odds of conjunctival hyperemia among participants exposed to latanoprost compared with those given travoprost. Li (2006) further noted that comparisons of travoprost 0.004 percent to travoprost 0.0015 percent in four trials showed that participants receiving travoprost 0.004 percent were at increased odds of conjunctival hyperemia compared to those receiving 0.0015% (OR, 1.64; 95% CI, 1.32 to 2.04).24

There were no significant differences in reports of harms such as conjunctival hyperemia, dry eye, and increased pigmentation between latanoprost, brimonidine (α2 adrenergic agonist) or dorzolamide (carbonic anhydrase inhibitor) as reported by Fung (2007) and Hodge (2008).21 22 However, there was an increased risk of fatigue reported by participants using brimonidine.

Li (2006), Loon (2008), Vass (2007), Zhang (2001) conducted separate comparison of timolol with brimonidine (α2 adrenergic agonist), prostaglandin analogs (travoprost, latanoprost), other β adrenergic antagonists, and placebo.24–26 29 While there was a twofold increase in the odds of participant drop out due to drug-related adverse events among participants randomized to timolol versus betaxolol (OR. 2.40; 95% CI, 1.04 to 5.53, five trials), the odds of dropping out were lower among participants randomized to timolol when compared to those receiving brimonidine (OR, 0.21; 95% CI, 0.14 to 0.31, three trials).29 As to the comparison of timolol with prostaglandin analogs, participants receiving either travoprost 24 or latanoprost 25 had six times the odds and twice the odds, respectively, of dropping out of the study due to conjuctival hyperemia, compared to patients receiving timolol. Both drugs also significantly increased iris pigmentation.

Conjunctival hyperemia and iris pigmentation were also significantly related to use of lantanoprost when compared to fixed and concomitant administration of timolol and dorzolamide. Cox (2008) concluded that adverse event reporting in studies of fixed versus concomitant medication formulations was inconsistent and the authors were thus unable to determine whether reports were associated with use of medications under investigation.28

#### Detailed Analysis of Primary Studies

We included 17 randomized controlled trials 32,33,37–39,41,42,49,52,53,55,58–63 and 10 observational studies 64–73 that reported harms of medical treatment (See evidence tables 11 and 12 in Appendix C).

##### Conjunctival Hyperemia

Conjunctival hyperemia is the most commonly reported adverse effect among the observational studies of medical treatment for OAG. Denis (2010) conducted an open label uncontrolled 3-month study of once-daily use of 0.005 percent latanoprost in 258 ophthalmology practices that included 600 participants with OHT or OAG. 64 Conjunctival hyperemia occurred in 10.7 percent of participants with an IOP between 20 and 23 mmHg and in 8.5 percent of participants with an IOP of 24 mmHg or greater. Eye pain was also reported among 3% of participants in each group. Chiselita (2007) conducted an open label study of travoprost among 1,133 participants (1,109 analyzed). 68 The most frequently reported adverse event was conjunctival hyperemia (6%) with severe cases requiring the withdrawal of travoprost in 10 participants. Thelen (2006) reviewed medical data for 353 OHT participants treated with lananoprost for approximately two years. 69 During this period the most frequently reported adverse event was ocular hyperemia, occurring in 20.7 percent of participants (73). Zimmerman (2003) conducted a historically controlled study of 3.534 participants (3.245 analyzed) who were switched from prior monotherapy to latanoprost. 70 Over the 6 months of follow-up the most frequently reported adverse effect was conjuntival hyperemia occurring in 2 percent of participants, and burning eyes, occurring in 1.4 percent of participants.

##### Other Harms

Barnett (2010) conducted a retrospective analysis of 1,636 Ocular Hypertension Treatment Study participants to determine the risk of retinal vein occlusion (RVO) among those randomized to medication versus those randomized to no treatment. Although there were 26 cases of RVO, the proportion of participants who developed RVO over 9 years of followup was 1.4 percent in the medication group and 2.1 percent in the control group (p = 0.14).65

Farris 2008 conducted a retrospective study of 97 participants with 188 eyes receiving various medications in addition to latanoprost who were switched to travoprost. Within 3 months, one subject experienced irritation severe enough to warrant a change back to latanoprost (1.6%).66

Sharpe (2007) reviewed the charts of 236 participants using latanoprost and 137 using bimatoprost. Within 12 months of treatment, 6 percent of participants receiving bimatoprost and 1 percent receiving latanoprost experienced periocular pigmentation (p = 0.004). 67

Arıcı (2000) compared the occurrence of ocular surface adverse effects among 24 OAG participants receiving betaxolol, 27 OAG participants receiving timolol, 26 OAG participants using betaxolol and dipivefrin hydrocholoride, and 30 control participants. OAG participants using topical medications were more likely to have fewer normal results from Schirmer’s tests and tear break up time tests and also have higher conjunctival impression cytology scores (p < 0.01) than those in the control group.71

#### Grading of Evidence

Because studies assessed a variety of different harms we did not complete a grading of evidence table for this question. There are a number of issues with assessing harms. For example, harms were not the primary outcome for the studies, meaning that the studies were not powered to detect differences. We judged the overall strength of evidence to be insufficient to make firm determination of differential harms for one therapy compared with another.

#### Conclusions

The harms of medical therapy for glaucoma are not consistently reported in a way that allows them to be easily analyzed across studies. Of the currently used medications, the prostaglandin agents are more likely to cause conjunctival hyperemia (redness) than timolol. Within the class of prostaglandins, latanoprost is less likely to cause redness than travoprost or bimatoprost and all three agents are similar with regard to ocular irritation, inflammation, cystoid macular edema, and iris pigmentation.

In a systematic review of timolol compared to other medications, subjects taking brimonidine, latanoprost, travoprost, or betaxolol were more likely to drop out of a study due to side effects than subjects taking timolol.

## Surgical Treatment of Open-Angle Glaucoma

### Systematic Reviews of Surgical Interventions for Open-Angle Glaucoma

We included 10 systematic reviews that address the comparative effectiveness of surgical interventions for the treatment of OAG (Appendix C).

Chai (2010) and Cheng (2010) discuss comparisons of viscocanalostomy versus trabeculectomy,74 75 with Cheng (2010) also compared viscocanalostomy to trabeculectomy with antimetabolites and deep sclerectomy to trabeculectomy (with or without antimetabolites).75

Wilkins (2005) and Wormald (2001) reviewed RCTs that compared primary trabeculectomy with antimetabolites versus trabeculectomy with placebo versus no treatment. 76,77 Wilkins (2005) included trials of the antimetabolite mytomycin C (MMC) and Wormald (2001) included trials of 5-Fluorouacil.

Kirwan (2009) compared trabeculectomy with beta radiation versus trabeculectomy with or without placebo.78

Rolim de Moura (2007) assessed the effectiveness of diode versus argon laser trabeculoplasty as well as SLT or trabeculectomy versus argon laser trabeculoplasty.79

Minckler (2006) compared the individual effectiveness of various aqueous shunts. The study also compared the effectiveness of these shunts with trabeculectomy and endocyclophotocoagulation.80

Finally, we identified four reviews addressing the comparative effectiveness of treatments for coexisting cataract and glaucoma.7,76,81,82 Comparisons include one-site versus two-site phacotrabeculectomy; 81 extracapsular cataract extraction or phacoemulsification and trabeculectomy with intraoperative (MMC) versus extracapsular cataract extraction or phacoemulsification and trabeculectomy with placebo or no treatment76 or with a postoperative injection of 5-Fluorouacil versus placebo or no treatment.82

### KQ 1b What is the comparative effectiveness of laser and other surgical treatments for reducing visual impairment?

#### Key Points

- No studies reported on visual impairment after laser or other surgical treatments.
- We could not determine whether individual patients sustained a clinically important decrease in visual acuity, because in all our identified studies comparing laser and other surgical treatments for glaucoma, visual acuity outcomes were reported as a mean value and not assessed as a primary outcome.
- No single treatment appeared to have a greater effect on visual acuity than any other treatment.

#### Summary of Evidence From Systematic Reviews

Liu (2010) and Minckler (2006) addressed visual acuity outcomes after surgical treatment of glaucoma.80 81 Liu (2010) found no difference in the percentage of patients with a post operative best corrected visual acuity of 20/40 or better (two trials) when one-site phacotrabeculectomy was compared to two-site phacotrabeculectomy. Minckler (2006) reported that participants receiving endocyclophotocoagulation had a 0.24 higher mean difference (worse) in logMAR visual acuity at 24 months when compared to those receiving the Ahmed implant. A comparison in one trial of single plate Molteno implant with corticosteroids versus single plate Molteno implant alone revealed that participants receiving the implant with corticosteroids were 22 percent more likely to have stable vision at followup (unchanged or within one line difference from baseline) than those receiving the implant only. None of these differences were statistically significant.

#### Detailed Analysis of Primary Studies

We did not identify any studies that reported on the primary outcome of visual impairment. We identified four studies that reported on the secondary outcome of visual acuity.

De Jong (2009) reported a change from baseline visual acuity at 12 months in an RCT comparing trabeculectomy with Ex-press minishunt, both using intraoperative mitomycin C (MMC) at a concentration of 0.2 mg/ml (the duration of exposure was not specified).83 Visual acuity was measured on an Early Treatment of Diabetic Retinopathy Study chart, but the manuscript does not specify whether patients were refracted either preoperatively or at 12 months. Two-thirds of patients had visual acuity that was unchanged, and about one-sixth had improved visual acuity and about one-sixth had decreased visual acuity. No definition of what constituted a change in acuity was provided.

Russo (2008) reported logMAR visual acuity results at 4 years in a trial in which patients received either a trabeculectomy or a non-penetrating deep sclerectomy with hyaluronic acid implant, both with MMC 0.2 mg/ml for two minutes.84 They report that the mean logMAR visual acuity in the trabeculectomy eyes changed from 0.8 (+/− 0.1) preoperatively to 0.4 (+/− 0.1) at 4 years, and that in the nonpenetrating deep sclerectomy eyes the visual acuity changed from 0.7 (+/− 0.1) preoperatively to 0.6 (+/− 0.1) at 4 years. Although this would suggest an improvement in visual acuity after both procedures, especially in the trabeculectomy group, the authors conclusion that there was more vision loss in the trabeculectomy group makes their findings uninterpretable.

Mielke (2006) performed an RCT in West Africa comparing nonpenetrating deep sclerectomy with and without intraoperative application of 0.25 mg/ml of MMC for 2 minutes.85 In the group without MMC, three of 21 eyes (14%) lost more than two lines of Snellen acuity with a mean follow-up of 18.3 months, and in the group receiving MMC, three of 18 eyes (17%) lost more than two lines of Snellen acuity with a mean followup of 14.3 months.

Shaarawy (2005) randomly performed a nonpenetrating deep sclerectomy in one eye of 13 patients and a nonpenetrating deep sclerectomy with a collagen implant in the fellow eye.86 They report aggregate visual acuity, expressed in Snellen fractions. In the eyes not receiving the collagen implant the preoperative, two-year, and four-year acuities were 0.67 (+/− 0.18), 0.56 (+/− 0.20), and 0.58 (+/− 0.20), respectively, and in the eyes receiving the collagen implant 0.66 (+/− 0.30), 0.58 (+/− 0.30), and 0.57 (+/− 0.3), respectively. The authors comment that the postoperative acuity was no different from the preoperative acuity, but offer no statistical support for their conclusion.

Note that one important study including laser trabeculoplasty, the Early Manifest Glaucoma Trial (EMGT) is included in the discussion of medical treatments of glaucoma, above.

The grading of evidence for KQ 1b with all the domains is summarized in Table 7.

Table 7 Grading of evidence for KQ 1b

Number of Studies; Participants | Study Design/Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Visual Impairment/Visual Acuity
4; 238 | RCT/Low | Inconsistent | Direct | Imprecise | Low

#### Conclusions

The literature is uninformative in addressing the question of the comparative effectiveness of laser and other surgical procedures in reducing visual impairment from glaucoma because no studies provide data on visual impairment.

### KQ 3b What is the comparative effectiveness of laser and other surgical treatments for lowering intraocular pressure?

#### Key Points

- Trabeculectomy lowers IOP more than nonpenetrating surgeries. (Systematic review)
- The use of mitomycin-C intraoperatively with trabeculectomy results in lower IOP than when it is not used. (Systematic review)
- Other alterations in surgical technique, location of surgery on the eye, and adjuvants other than mitomycin-C have not been shown to result in an added pressure decrease. (Primary studies)
- The intraocular pressure lowering effect of combined cataract surgery and trabeculectomy is not affected by the location of the conjunctival incision or the presence or absence of a peripheral iridectomy but may be more in two-site (cataract and trabeculectomy performed using different incisions) than one-site (cataract and trabeculectomy performed using the same incision) surgery. (Systematic review)
- Laser trabeculoplasty effectively lowers IOP in glaucoma patients and effectiveness does not vary with the type of laser used. (Primary studies)
- The data available for the role of aqueous drainage devices in open-angle glaucoma are inadequate to draw conclusions. (Primary studies, Systematic review)

#### Summary of Evidence From Systematic Reviews

The authors of the included systematic reviews of trabeculectomy compared to non-penetrating filtering surgeries concluded that trabeculectomy is a more effective surgical intervention for lowering IOP. Chai (2010) noted that the mean IOP of participants receiving trabeculectomy was 3.64 mmHg lower at 12 months (six trials) and 3.42 mmHg lower at 24 months (three trials) than the IOP of participants treated with viscocanalostomy.74 The outcomes were statistically significant, but the included studies enrolled participants with primary chronic angle closure glaucoma (1.7% of total included participants). Cheng (2010) confirmed this finding among participants with OAG.75 In Cheng’s study, there were fewer participants achieving normal endpoint IOP without medications or surgery (complete success) after one year in the viscocanalostomy group when compared to the trabeculectomy group (RD, −0.16; 95% CI, −0.30 to −0.02; three trials) and to the trabeculectomy with antimetabolite group (RD, −0.39; 95% CI, −0.53 to −0.24; three trials).

In a meta-analysis of five trials comparing deep sclerectomy to trabeculectomy, fewer deep sclerectomy participants achieved complete success (RD, −0.10; 95% CI, −0.19 to 0.00). 75 This finding was mirrored in an analysis of deep sclerectomy with MMC versus trabeculectomy with MMC (RD, −0.16, 95% CI, −0.32 to −0.01; two trials).

Wilkins (2005) and Wormald (2001) reported that the addition of antimetabolites to trabeculectomy significantly reduced IOP among participants enrolled in the included studies.76 82 Wilkins (2005) determined after pooling the results of two trials that participants receiving intraoperative MMC had an average IOP that was 5.41 mm Hg lower than participants receiving placebo or no treatment at 12 months. A similar finding was reported among participants receiving postoperative 5-FU (WMD, −4.67; 95% CI, −6.60 to −2.74; two trials).

The addition of beta radiation to trabeculectomy does not appear to reduce IOP more than trabeculectomy alone as Kirwan (2009) reported no difference in the mean IOP of participants treated with trabeculectomy and beta radiation compared to participants receiving trabeculectomy only, at one year after surgery (WMD, −0.97; 95% CI, −2.56 to 0.62; two trials).78

Rolim de Moura (2007) reported (in two studies) no difference in the risk of failure (defined as an IOP greater than or equal to 22) when diode and argon laser trabeculoplasty were compared at one year (relative risk [RR], 3.0; 95% CI, 0.37 to 24.17) and two years follow-up (RR, 0.50; 95% CI, 0.10 to 2.43) and when SLT was compared to argon laser trabeculoplasty at one year (RR, 1.27; 95% CI, 0.84 to 1.90). 79 When argon laser trabeculoplasty was compared with trabeculectomy across two trials at 24 months, participants randomized to argon laser trabeculoplasty were 2.03 times more likely to have failed treatment than participants randomized to trabeculectomy (95% CI, 1.38 to 2.98).

Three of the four systematic reviews addressing surgical treatments for coexisting cataract and glaucoma include pooled results for IOP, but these analyses also include results of studies with angle closure glaucoma participants in addition to OAG participants. Liu (2010) pooled the results of five trials that compared one-site to two-site phacotrabeculectomy and concluded that two-site phacotrabeculectomy significantly lowered IOP by an average of 6 percent more than one-site phacotrabeculectomy, from baseline to 12 or more months after surgery.81 Wilkins (2005) reported significant improvements in mean IOP at 12 months with the addition of MMC to extracapsular cataract extraction with trabeculectomy when compared to placebo or no treatment (WMD, −3.34; 95% CI, −4.16 to −2.51; three trials). 76 Wormald (2001) noted no significant difference in mean IOP at 12 months when postoperative 5-FU is used as an antimetabolite versus placebo or no treatment (WMD, −1.02; 95% CI, −2.40 to 0.37).82 Jampel (2003) provided a qualitative synthesis of the evidence on surgical treatment of coexisting cataract and glaucoma from literature searches conducted between 1980 and April 2000.^7^ The investigators found that use of the antimetabolite MMC improves outcomes and is more beneficial than 5-FU, that there are no differences in outcomes with limbal- and fornix-based conjunctival incisions, and that the risk of postoperative cataract increases with glaucoma surgery. Jampel (2003) concluded that the evidence did not support use of one strategy for IOP control over any other and that more research is needed particularly addressing the long-term progression of visual field loss and optic nerve damage.

Minckler (2006) reported the results of trials of aqueous shunts for all types of glaucoma.80 Overall, trabeculectomy performed better than the Ahmed implant. The mean IOP in the trabeculectomy group was 3.81 mm Hg lower than the IOP in the Ahmed implant group (two trials). Outcomes from single trials comparing endocyclophotocoagulation and Ahmed implant failed to show a difference in mean IOP at 12 months (MD 1.14; 95% CI, −1.93 to 4.21) and 24 months (MD, 0.66; 95% CI, −2.98 to 4.30). The comparisons of various shunts to each other or a single shunt compared with or without the use of antimetabolites were from single studies addressing these questions. Minckler (2006) reported no difference in mean IOP at 12 months when the Ahmed or Molteno implants were compared with or without the addition of MMC. Additionally there were no differences in high-pressure versus standard Ahmed implant, double-plate Molteno and Schocket shunts and single-plate Molteno implants with or without use of oral corticosteroids. As of the January 2006 search date for this review, there were few studies of aqueous shunts and thus the authors concluded that the evidence was insufficient for reaching any conclusions regarding the comparisons included in the review.

#### Detailed Analysis of Primary Studies

Trabeculectomy has long been considered the mainstay of incisional surgery for lowering IOP. It is often performed at the same time as cataract surgery, because many patients have concurrent cataract and glaucoma. We included 19 randomized controlled trials: Three involving trabeculectomy technique, six evaluating adjuvants at the time of trabeculectomy, four comparing trabeculectomy with variations of trabeculectomy or other glaucoma surgery, two addressing surgical techniques in combined cataract and glaucoma surgery, two addressing combining cataract surgery with glaucoma surgery other than trabeculectomy, and one studying deep sclerectomy.

One additional primary study was identified comparing “low” energy SLT to normal energy SLT.87

#### Trabeculectomy Techniques

##### Location of Surgery

Sanders (1993) in Scotland randomized 60 presumably Caucasian patients undergoing fornix-based trabeculectomy without antifibrosis agent to three different ocular sites for the surgery: nasal, superior, or temporal.88 No patient had undergone previous laser or intraocular surgery. At 18 months after surgery, the mean IOP was 14.5, 17.5 and 18.2 mm Hg for the three sites respectively. The IOPs for the nasal versus the temporal sites were statistically significantly different (p = 0.01). Although the numbers were too small for statistical analysis, eyes with a nasal trabeculectomy seemed to have more discomfort, more wound leaks, and were associated with more corneal dellen.

##### Fornix Versus Limbus Conjunctival Incision

El Sayyad (1999) randomly assigned one eye to fornix-based trabeculectomy and one eye to limbus-based trabeculectomy in 28 patients undergoing bilateral first-time trabeculectomies.89 Postoperative injections of 5-FU were used. Starting from a similar preoperative IOP of 33 mm Hg in each eye, IOPs were similar in both eyes, with a mean of 12 mm Hg at one year after surgery and 13 mm Hg at 2 years after surgery. Two late bleb leaks were noted in the limbus-based eyes and none in the fornix-based eyes.

##### Laser Suture Lysis Versus Adjustable Sutures

Kobayashi (2010) randomized 50 Japanese patients with OAG undergoing a fornix-based trabeculectomy with MMC to either scleral flap sutures requiring laser suture lysis after surgery or adjustable sutures that could be manipulated with a forceps.90 Both groups had a preoperative IOP of approximately 27 mm Hg. One year after surgery the IOP was 12.9 mm Hg in the adjustable suture group and 12.3 in the laser suture lysis group.

#### Trabeculectomy With Adjuvants

##### Mitomycin C

Reibaldi (2008) recalled patients who participated in a clinical trial in which patients with primary OAG received a limbus-based trabeculectomy with either balanced salt solution or 0.2 mg/ml of MMC applied on a sponge for 2 minutes.91 The preoperative IOP was 25 mm Hg in both groups with an average of three medications in each group. Of the 133 patients who entered the study, 114 were re-examined at a mean of 10 years in both groups, with mean IOP of 13.3 mm Hg in the MMC treated group and 14.7 in the balanced salt solution group (p=0.014). Using Kaplan-Meier curves, the authors determined that the success rate, defined as an IOP of 18 mm Hg or less was 75 percent for MMC and 55 percent for balanced salt solution (p=0.02).

##### Length of Mitomycin C Application

Kim (1998) randomized phakic patients undergoing their first trabeculectomy to receive either a 0.50–1 minute or a 3–5 minute application of 0.5 mg/ml of MMC.92 A limbus-based conjunctival flap was used. These eyes were compared to a group of similar historical controls that did not received MMC. The preoperative intraocular pressures, which ranged from 29.7 to 32.7 mm Hg were not statistically significant. The mean intraocular pressure and mean number of postoperative medications at one year, estimated from the figures, were 15 mm Hg with one postoperative medication, 12 mm Hg with 0.5 postoperative medication, and 11 mm Hg with 0.3 medications (for the no MMC, 0.5–1 minute exposure to MMC, and the 3–5-minute exposure to MMC groups, respectively).

##### 5-Fluorouracil Versus Fibrinolytic Drug

Quaranta (2000) randomized eyes undergoing their first trabeculectomy, done with a fornix-based flap, to either postoperative injections of (5-FU)or sulodexide, a fibrinolytic drug, on 10, 17, 24, 31, and 38 days after surgery.93 Preoperative IOP was comparable in both groups at about 27 mm Hg, and at one year after surgery was 15.5 mm Hg in the sulodexide eyes and 14.8 mm Hg in the 5-FU eyes. There were two bleb leaks requiring surgical repair in the 5-FU group and none in the sulodexide group.

##### Olegen Implant

Rosentreter (2010) randomized 20 eyes of 20 Caucasian patients undergoing fornix-based trabeculectomy to either MMC 0.2 mg/ml for three minutes or an Olegen (porous collagen-glycosaminoglycan matrix) implant placed on top of the scleral flap.94 Despite the small number of patients limiting the power of the study, the authors were able to conclude that the IOP at one year after surgery (11.3 mm Hg for the MMC treated group and 15.6 mm Hg for the Olegen treated group) as well as the requirement for IOP lowering medications (0.0 for the mitomycin treated group versus 0.8 for the Olegen treated group), were both statistically significant (p=0.01 for IOP and p=0.05 for medications).

##### Amniotic Graft

Eliezer (2006) randomized 32 patients, undergoing trabeculectomy using a limbus-based incision without an antifibrosis agent, to either receive or not receive an amniotic membrane graft intraoperatively.95 The amniotic membrane graft was sewn to the sclera, over the trabeculectomy flap because of its potential to decrease scarring and improve the success of the surgery. At one year, the IOP was 15.2 mm Hg in the eyes not receiving amniotic membrane and 12.8 in eyes receiving amniotic membrane, however this difference was not statistically significant (p=0.3).

##### Polytetrafluoroethylene Membrane

Cillino (2008) performed an RCT to evaluate the effect of placing a pericardial expanded polytetrafluoroethylene membrane underneath the scleral flap during trabeculectomy in eyes without previous ocular surgery.96 Sixty Caucasian patients with either OAG or pseudoexfoliation glaucoma, were randomized to one of four groups: trabeculectomy alone, trabeculectomy with MMC, trabeculectomy with membrane, or trabeculectomy with both MMC and membrane. Preoperative IOPs ranged from 28 to 35 mm Hg. At one year after surgery, mean IOP ranged from 16.4 to 17.4 mm Hg, with no difference between the four groups. Avascular blebs were noted in eyes receiving MMC but not in the other two groups.

#### Trabeculectomy Compared With Trabeculectomy Variants and Other Glaucoma Procedures

##### Minitrab

Thimmarayan (2006) randomly assigned 60 eyes of 54 subjects to either a conventional trabeculectomy (although they do not describe the surgical technique) or a “mini-trabeculectomy” in which a smaller than usual fornix-based conjunctival flap is made, and in which a scleral tunnel is created instead of a scleral flap.97 Ten percent of the eyes received postoperative 5-FU on an “as needed” basis. IOP was lowered in both groups from 28 mm Hg preoperatively to 16 mm Hg 15 months after surgery. The mini-trabeculectomy group appeared to have more hypotony, and shallower anterior chamber depths in the immediate postoperative period, but evidently the differences did not reach statistical significance.

Das (2002) randomly assigned 80 eyes of 80 subjects with OAG to either a limbus-based trabeculectomy without antifibrosis agent or a fornix-based trabeculectomy using a small incision and avoiding Tenon’s capsule.98 The preoperative IOP was 30 mm Hg in each group. At one year after surgery the mean IOP was 18.9 in the trabeculectomy group and 16.6 mm Hg in the small incision group (p=0.6), with 0.38 IOP-lowering medications in the trabeculectomy group as opposed to 0.25 IOP-lowering medications in the small incision group (p=0.025). There were no differences noted in either early or later postoperative complications between the two groups.

##### Ex-Press Shunt

De Jong (2009) performed an RCT comparing two limbus-based trabeculectomies using MMC, one with the implantation of an Ex-press minishunt underneath a trabeculectomy flap and one without in 80 eyes of 78 patients.83 The preoperative IOP was 22.8 mm Hg in the Ex-press group and 21.5 mm Hg in the trabeculectomy group, and 1 year after surgery the respective IOPs were 12.0 mm Hg and 13.9 mm Hg, respectively (p=0.02). Complications were not common and similar between the two groups.

##### Deep Sclerectomy With SK-Gel

Russo (2008) enrolled 93 Italian patients with primary OAG, who had baseline IOP of about 25.5 mmHg and had not had previous surgery, in a randomized comparison of non-penetrating deep sclerectomy with SK-Gel versus traditional trabeculectomy with MMC, and followed subjects at three and four years.84 Mean IOP was similar between the two groups at 36 and 48 months, but on average fewer medications were required in the trabeculectomy group. At 4 years, the two groups appeared to have differential outcomes with 72 percent of the trabeculectomy group having IOP greater than 21 mmHg without medicines versus 51 percent in the deep sclerectomy group (p<0.05). However, there were no statistically significant differences in achieving this IOP criterion when allowing for medication use by patients. Cataracts and flat anterior chambers were more common with trabeculectomy. In summary, IOP outcomes were similar, but more medications were required in the deep sclerectomy group.

#### Combined Cataract and Trabeculectomy Surgery Techniques

##### Peripheral Iridectomy

Kaplan-Messas (2009) performed a small clinical trial in which patients undergoing either trabeculectomy with MMC (n=11) or combined phacoemulsification and trabeculectomy with MMC (n=36), were randomized to either receive, or not receive, a peripheral iridectomy at the time of surgery.99 Given that their power to detect differences between the two groups must have been low, they found no difference in reduction of IOP with or with peripheral iridectomy. One eye in the group without an iridectomy had iris incarceration in the wound as opposed to none in the group with an iridectomy.

##### Fornix Versus Limbus Conjunctival Incision

Kozobolis (2002) performed bilateral phacoemulsification and trabeculectomy with MMC using a two-site (separate incisions for the phacoemulsification and trabeculectomy) approach in 22 patients.100 One eye was randomly assigned to a fornix-based trabeculectomy and the other to a limbus-based trabeculectomy. At one year after surgery there was no difference in the mean IOP (15 mm Hg) or the mean number of IOP lowering medications (0.3). Although the numbers were small, the authors observed faster visual recovery after surgery in the fornix-based trabeculectomies. but more bleb leaks.

#### Combined Cataract and Other (Non-Trabeculectomy) Glaucoma Surgery

##### Micro-Bypass Stent

Fea (2010) randomized patients with OAG under medical treatment needing cataract surgery to either phacoemulsification cataract surgery alone or phacoemulsification cataract surgery plus implantation of a single micro-bypass stent (iStent, Glaukos).101 The preoperative IOP was 17.9 mm Hg on an average of 2.0 medications in the iStent group and 17.3 mm Hg on an average of 1.9 medications in the control group. Sixteen months after surgery (after a one month washout of all IOP lowering medications) the IOP was lower in the group receiving the iStent (16.6 mm Hg) than in the group not receiving the iStent (19.2 mm Hg, p=0.04).

##### Comparing Trabeculectomy With Viscocanalostomy

Kobayashi (2007) randomized one eye of each of 40 Japanese patients with primary OAG and visually significant cataract to either phacoemulsification cataract surgery with limbus-based trabeculectomy or to phacoemulsification cataract surgery and viscocanalostomy.102 MMC was applied at a concentration of 0.4 mg/ml for 3 minutes. The preoperative IOP of the eyes randomized to viscocanalostomy was 24.0 mm Hg on an average of 2.8 medications, In the trabeculectomy group, IOP was 23.7 mm Hg on an average of 2.6 medications. There were no significant differences in IOP between the two groups at 1, 3, 6, and 12 months after surgery. At 12 months, the mean IOP was 14.9 mm Hg on an average of 0.2 medications in the viscocanalostomy group and 14.1 mm Hg on an average of 0.1 medications in the trabeculectomy group.

#### Other Glaucoma Operations

##### Deep Sclerectomy With and Without Mitomycin C

Mielke (2006) performed a small RCT of 39 Nigerian patients with POAG without prior surgery to assess the benefit of using MMC in deep sclerectomy.85 Deep sclerectomy (with or without MMC) resulted in an IOP of less than 18 mmHg at 18 months in less than 25 percent of both groups. The study was underpowered to determine if IOP differed between the two groups.

###### Laser Trabeculoplasty

One study compared argon laser trabeculoplasty to SLT.103 As initial laser treatment in subjects already on medical therapy, the two procedures showed similar efficacy with IOP decreasing 6.01 mmHg in the SLT group and 6.12 mmHg in the argon laser trabeculoplasty group (p = NS). When used in eyes that had failed prior angle treatment, SLT resulted in a greater reduction in IOP than argon laser trabeculoplasty (6.24 mmHg versus 4.65 mmHg, p<0.01).

Another study of titanium-sapphire laser trabeculoplasty compared to argon laser trabeculoplasty found no significant difference in the reduction of IOP between the two (8.3 versus 6.5 mmHg, p non-significant).104

Frenkel (1997) found that 35 applications over 120 degrees resulted in similar reduction of IOP when compared to 50 applications over 180 degrees (3.9 mmHg versus 4.4 mmHg, p=0.63).105

Finally, Tang (2011) compared “low” energy SLT to normal energy SLT and found no difference in the rate of success at any time point up to 12 months.

The grading of evidence for KQ 3b with all the domains is summarized in Table 8.

Table 8 Grading of evidence for KQ 3b

Number of Studies; Participants | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Intraocular Pressure
20;1194 | RCT/Medium | Consistent | Direct | Precise | Moderate

#### Conclusions

Trabeculectomy has been repeatedly demonstrated to lower IOP to a mean level in the low to mid teens. Its IOP lowering effect is potentiated by the use of MMC intraoperatively, but does not appear to be increased by alterations in surgical technique, or the addition of implants designed to improve wound healing. One small study reported slightly lower IOPs with the Ex-press mini-shunt compared to trabeculectomy. Combined cataract surgery with glaucoma surgery lowers IOP more than cataract surgery alone, but less than trabeculectomy alone.

The studies identified regarding laser trabeculoplasty consistently show a decrease in IOP with treatment but are not adequate to draw strong conclusions with regard to the type of laser used or the number of applications.

The exclusion of the Tube versus Trabeculectomy (TVT) study is important to note. While the study was well designed and well executed, the patient population enrolled in the study did not exclusively have open-angle glaucoma. Other studies of glaucoma drainage devices were also not eligible for this review as they reflect the practice of using tubes in glaucomas other than open-angle and in complex cases.

Another important exclusion is the Advanced Glaucoma Intervention Study (AGIS). The results of the AGIS could not be included as a primary study because it enrolled angle closure glaucoma subjects as well as open-angle glaucoma. Even though the number of angle closure cases was small, the data were never analyzed using the open-angle group alone so there was no way to abstract the data from the study publications. The AGIS is an important study in glaucoma, however, and also supports the conclusion that both trabeculectomy and laser can be used to lower IOP in glaucoma patients. In terms of the fundamental question asked by the study – whether initial laser trabeculoplasty or initial trabeculectomy was preferable – the 10 year results suggested that initial laser trabeculoplasty was less likely to result in visual field change in black subjects while initial trabeculectomy was preferable in white patients.106

### KQ 4b What is the comparative effectiveness of laser and other surgical treatments for preventing or slowing the progression of optic nerve damage and visual field loss?

#### Key Points

- No studies comparing laser and surgical treatments were found for which data on whether these procedures slow the progression of optic nerve damage and visual field loss were reported.

#### Summary of Evidence From Systematic Reviews

We did not identify any systematic reviews of surgical interventions for OAG that included outcomes related to optic nerve damage or visual field loss.

#### Detailed Analysis of Primary Studies

We did not identify any primary studies of surgical interventions for OAG that included outcomes related to optic nerve damage or visual field loss. However, outcomes related to optic nerve damage and visual field loss are discussed in reference to KQ 4c, comparing the effectiveness of medical and surgical interventions.

### KQ 6b What are the harms associated with laser and other surgical treatments for open-angle glaucoma?

#### Key Points

- Trabeculectomy results in more complications than nonpenetrating surgeries. (Systematic review)
- The profile of harms does not differ between one- and two-site combined cataract and glaucoma surgery. (Systematic review)

#### Summary of Evidence From Systematic Reviews

Chai (2010) and Cheng (2010) concluded that adverse effects were experienced more often by participants randomized to trabeculectomy when compared to participants randomized to other nonpenetrating filtering surgeries.74 75 Hypotony, hyphema, shallow/flat anterior chamber, and cataract were all more frequent among participants treated with trabeculectomy compared to viscocanalostomy and deep sclerectomy. Cheng (2010) additionally noted a significantly higher risk of choroidal detachment among participants receiving trabeculectomy versus both viscocanalostomy and deep sclerectomy.75

Wilkins (2005) and Wormald (2001) reported harms for the addition of antimetabolites to primary trabeculectomy. The risk of epithelial toxicity was 5.85 times as great with the addition of postoperative 5-FU in participants receiving primary trabeculectomy (95% CI, 2.04 to 16.83). 82 Wilkins (2005) noted that wound leak, hypotony, and cataract were more often reported among those receiving intraoperative MMC, but these differences were not statistically significant.76

The addition of beta radiation to trabeculectomy resulted in significantly higher risk of cataract when compared to trabeculectomy alone (RR, 2.89; 95% CI, 1.39 to 6.00).78 The risk of hypotony was higher while the risk of bleb leaks was lower, but the confidence intervals overlapped the line of no difference.

Diode laser trabeculoplasty treatment resulted in a lower, but not significant, risk of peripheral anterior synechiae (RR, 0.54; 95% CI, 0.17 to 1.76, one trial) and early IOP spikes (RR, 0.66; 95% CI, 0.21 to 2.14, three trials) when compared to argon laser trabeculoplasty.79

Reports of adverse effects across studies that addressed questions related to combined surgery for co-existing cataract and glaucoma varied by intervention under consideration. There were no differences in the risk of hyphema, choroidal detachment, and hypotony when one-site phacotrabeculectomy was compared to two-site phacotrabeculectomy.81 The odds of wound leak (1.88), hypotony (1.65), and endophthalmitis (3.44 and 1.14) were greater among participants randomized to receive MMC with trabeculectomy in addition to cataract extraction (Wilkins (2005)), as compared to the same surgery without MMC.76 Additionally the risk of wound leak was 17% lower among participants receiving postoperative 5-FU with cataract extraction and trabeculectomy while the risk of epithelial toxicity was three times greater among those receiving 5-FU (95% CI, 1.56 to 5.92), compared to the same surgery without 5-FU. As it was with primary trabeculectomy, epithelial toxicity was significantly different among participants exposed and not exposed to 5-FU.

Reports of the complications of aqueous shunts across the five trials included in the Minckler (2006) review were not amenable to meta-analysis due to the unavailability of key data from the original manuscripts.80 Minckler (2006) noted that there were limited reports of choroidal hemorrhage with the single-plate, double-plate, and pressure-ridge double-plate Molteno implants. One study reported several cases of choroidal complications, corneal complications, and strabismus with the 350-mm and 500-mm Baerveldt implants (13/55 and 19/52 respectively for choroidal hemorrhage; 17/55 and 19/52 for corneal failure; and 10/55 and 8/52 for strabismus). Other harms noted include no light perception, phthisis, tube exposure, retinal detachment, and infection.

#### Detailed Analysis of Primary Studies

We included 22 randomized controlled trials83–85,88–91,93–100,103,104,107–111 and three observational studies 112–114 that addressed questions of harms related to surgical treatment of OAG.

Nassiri (2008) reviewed the medical records of 61 participants receiving one-site phacotrabeculectomy and 52 participants receiving two-site phacotrabeculectomy.112 Over a 1-year follow-up period, the percent difference in the mean of corneal endothelial cell area was greater with two-site phacotrabeculecomy (38.04%) than one-site (32.46%) (p<0.001), where a larger increase in cell area is worse.

Jeganathan (2008) conducted a case control study of 29 cases of delayed suprachoroidal haemorrhage (DSCH) identified over a 10-year period from a total of 2,752 glaucoma surgeries. 113 Prior intraocular surgery (pars plana vitrectomy and penetrating keratoplasty) was associated with a 4.4 higher odds of DSCH. Other risk factors included postoperative hypotony defined as an IOP less than or equal to 3 mm Hg within the first week (OR 2.7; 95% CI 1.8 to 4.3). There was no association of DSCH with combined surgeries or preoperative or immediate postoperative IOP.

Shingleton (2002) conducted a retrospective study of 117 participants (126 eyes) randomized to phacotrabeculectomy with MMC with peripheral iridectomy (PI) (66 eyes) or without PI (60 eyes).115 The most frequently reported harms/complications included posterior capsule opacification among participants receiving PI (34.8%) and those not receiving PI (40%) and capsulotomy (22.7% and 11.7% among the PI and no- PI group respectively).

#### Grading of Evidence

Because studies assessed a variety of different harms, we did not complete a grading of evidence table for this question. There are a number of issues with assessing harms. For example, harms were not the primary outcome for the studies, meaning that the studies were not powered to detect differences. We judged the overall strength of evidence to be insufficient to make firm determination of differential harms for one therapy compared to another.

#### Conclusions

Trabeculectomy, when compared to the nonpenetrating procedures of deep sclerectomy or viscocanalostomy, produces more hypotony, hyphema, shallow anterior chambers, cataract, and choroidal detachment.

There is no clear difference in harms produced by one-site versus two-site combined cataract extraction and trabeculectomy.

The harms associated with glaucoma drainage devices have not been adequately compared to the harms of other procedures in the treatment of OAG.

## Medical Versus Surgical Treatment of Open-Angle Glaucoma

This section summarizes systematic reviews, and any additional primary studies not included in those systematic reviews, of medical versus surgical treatment of OAG. It also includes various combinations of medical and surgical treatment versus other treatment (medical, surgical, or no treatment).

### Systematic Reviews of Medical Versus Surgical Interventions for Open-Angle Glaucoma

We included two systematic reviews that summarize comparisons of surgical and medical treatments of OAG. One additional systematic review includes comparisons of medical and/or surgical treatments with a concurrent no treatment group among participants with ocular hypertension, OAG, or normal-tension glaucoma.

Burr (2004) summarized the evidence from three RCTs addressing the effect of initial medical treatment versus initial trabeculectomy for preventing the progression of visual field loss and optic nerve damage.116 Two of the studies assessed patients with “severe” glaucoma, one assessed “mild” glaucoma and the final one did not state the baseline glaucoma status. Medicines and surgical techniques have evolved since this review—two of the studies were initiated before 1990 when prostaglandins were not available. Furthermore, visual field testing has also evolved substantially.

Maier (2005) reviewed five clinical trials of participants with ocular hypertension randomized to either medical and/or surgical (laser or incisional) treatment to lower IOP or to no treatment.117 Rolim de Moura (2007) summarized the evidence from 19 randomized controlled trials comparing laser trabeculoplasty alone to medical treatment, another surgical treatment (trabeculectomy), and a different type of laser trabeculoplasty.79 Rolim de Moura (2007) also included comparisons of laser trabeculoplasty plus medical treatment to no treatment and comparisons of alternative trabeculoplasty techniques (six studies - not discussed in this report).

### KQ 1c What is the comparative effectiveness of medical versus surgical treatment for reducing visual impairment?

#### Key Points

- Although trabeculectomy may reduce the risk of vision loss compared to medical treatment after adjusting for demographic and comorbid factors, the body of evidence is limited and inconclusive. (Systematic review)

#### Summary of Evidence From Systematic Reviews

Burr (2004) reported that in two trials with reports of visual acuity outcomes, there were no significant differences in visual acuity (mean or loss of two or more Snellen lines) when trabeculectomy was compared to medical treatment.116 The investigators of a third trial reported that participants receiving trabeculectomy experienced a 53 percent lower risk of losing two or more Snellen lines of visual acuity (0.3 logMAR) after adjustments for demographic factors and comorbidities including cataract requiring surgery (95% CI, 0.31 to 0.74).

#### Detailed Analysis of Primary Studies

We did not identify any primary studies of medical versus surgical interventions for OAG that included outcomes related to visual impairment or visual acuity.

#### Grading of Evidence

Not applicable as we did not identify evidence from primary studies addressing this question.

#### Conclusions

There is limited evidence in the literature regarding visual acuity outcomes when comparing medical to surgical treatments for glaucoma.

### KQ 3c What is the comparative effectiveness of medical versus surgical treatment for lowering intraocular pressure?

#### Key Points

- Incisional surgery lowers IOP more than lasers or medications. (Systematic review)
- Initial treatment with lasers tends to reduce the need for medications to achieve the same IOP. (Systematic review)

#### Summary of Evidence From Systematic Reviews

Burr (2004) reported that the IOP of participants randomized in two trials to trabeculectomy was 6.14 mmHg lower than participants receiving medical treatment at one year (95% CI, 4.25 to 8.02).116 In the third included trial, the mean difference at one year was on average 3.6 mmHg lower with trabeculectomy (95% CI, 2.78 to 4.42).

In one trial, there was a 1.6 mmHg difference in IOP between 2 to 4 years of followup (95% CI, −0.69 to 3.89), and a 3.4 mm Hg difference in favor of trabeculectomy at 5 years (95% CI, 1.04 to 5.76, one trial). In another trial that followed participants for 5 years, the mean difference in IOP in the group receiving trabeculectomy was 1.9 mm Hg (95% CI, 0.85 to 2.95). This finding was not statistically significant.

Rolim de Moura (2007) reported that the relative risk of experiencing an IOP greater than or equal to 22 mmHg (failure) at one year among participants receiving argon laser trabeculoplasty versus continued medical treatment was 0.08 in one trial (95% CI, 0.02 to 0.31) and 0.41 in a second trial (95% CI, 0.22 to 0.77).79 At 24 months, the relative risk of failure was 0.80 with argon laser trabeculoplasty compared to medical treatment alone (95% CI, 0.71 to 0.91, two trials).

#### Detailed Analysis of Primary Studies

Only a small number of articles compared IOP outcomes between medical and surgical therapy and the treatments compared were dissimilar. We therefore did not perform meta-analysis.

Tuuolonin (1989) enrolled 191 consecutive Finnish treatment-naive phakic patients with primary OAG or pseudoexfoliation glaucoma (PXG) in an RCT comparing laser trabeculoplasty to medical therapy.35 Outcomes from 39 participants were available at 1 year. Nearly half of the patients receiving laser were subsequently treated with medications. The reduction of IOP was slightly greater in the laser trabeculoplasty group.

Lai (2004) randomized one eye of each patient (n=29) to either SLT or medical therapy (baseline IOP was about 26 mmHg, medications used were not stated).118 While more medications were required in the eyes that did not have SLT, the IOP was lowered about 8.5 mmHg in both groups (however, nearly one-fifth required surgery within 5 years). Eyes treated with SLT required fewer medications over 5 years of follow-up (total 24 subjects).

Migdal (1986) was included in existing systematic reviews but we include a brief description here.119 In this study, Migdal (1986) randomized 168 primary OAG patients with IOP greater than or equal to 24 mmHg (mean around 35 mmHg) to medicines (pilocarpine, sympathomimetic, and/or timolol), laser (360 degrees in two sessions) or trabeculectomy without antimetabolite. Mean IOP was similar in the medicine and laser groups (around 21 mmHg with some having failed and advanced to other therapy) and around 14 mmHg in the surgery group at one year. Failures of each therapy were excluded from mean IOP reported values in all follow-up reports,120 but almost none of those assigned to surgery developed IOP greater than 22 mmHg whereas about 20% in the medicine group and 30% in the laser group had elevated IOP within 5 years (which meant that IOP could not be kept below 23 mmHg with pilocarpine alone).

The grading of evidence for KQ 4b with all the domains is summarized in Table 9.

Table 9 Grading of evidence for KQ 4b

Number of Studies; Participants | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Intraocular Pressure
2; 220 | RCT/Medium | Consistent | Direct | Imprecise | Low

#### Conclusions

IOP is lowered more by trabeculectomy than by laser or medical treatment. Treating with lasers lowers IOP and when compared to treating with medications reduces the number of medications needed to keep IOP at the same level.

### KQ 4c What is the comparative effectiveness of medical versus surgical treatment for preventing or slowing the progression of optic nerve damage and visual field loss?

#### Key Points

- Trabeculectomy may prevent more visual field loss than medicines when used as initial therapy in advanced glaucoma. (Systematic review)
- The Collaborative Initial Glaucoma Treatment Study (CIGTS) included surgical techniques and medications that are current and found no difference in change in visual field (but did not report on change in the optic nerve).
- Treatment of ocular hypertension with medicines preserves visual fields better than no treatment. (Systematic review)

#### Summary of Evidence From Systematic Reviews

Maier (2005) summarized the evidence from five RCTs, which randomized participants with ocular hypertension to either medical and/or surgical treatment to lower IOP, or to no treatment.117 Participants receiving topical medications were 44 percent less likely to experience progression of visual field loss and optic disc damage when compared to participants receiving no treatment (HR 0.56; 95% CI, 0.39 to 0.81). Among participants with primary OAG (two trials), medically and/or surgically treated participants were 35 percent less likely to experience progression of field loss and optic disc damage when compared to participants receiving no treatment. This finding was mirrored in a subgroup analysis (two trials) of participants with normal tension glaucoma (HR 0.70; 95% CI, 0.48 to 1.02).

Burr (2004) reviewed the evidence from three RCTs addressing the effect of initial medical treatment versus initial trabeculectomy for preventing the progression of visual field loss and optic nerve damage.116 In one trial, at a mean of 4.6 years of followup, 26 percent of participants undergoing trabeculectomy compared with 47 percent medically treated participants experienced progression of visual field severity of one stage or more (OR, 2.56; 95% CI, 1.12 to 5.83).

In the second trial that examined participants with IOP less than 22 mm Hg at 5 or more years of follow-up, visual field progression was more likely in medically treated participants than those receiving trabeculectomy. Using the mean of the first three visual field scores compared to the mean of the last three scores, medically treated participants scored on average four points higher than those in the trabeculectomy group (MD, 3.92; 95% CI, 2.02 to 5.82). In this same trial, the investigators found no difference in progression of visual field loss measured by Humphrey automated perimetry in the trabeculectomy group (71%) versus the medical treatment group (63%) (OR, 0.69; 95% CI, 0.29 to 1.67).

In the third trial, there was no difference in the mean change in visual field score at one year in the unadjusted analysis (MD, −0.5; 95% CI, −1.10 to 0.10) and 5 years (MD, 0.30; 95% CI, −0.45 to 1.05), but the investigators reported a significant difference after adjusting for demographic factors (age, gender, race) and baseline visual field score. The medical treatment group’s change in visual field score was lower than the trabeculectomy group (MD, −0.36; 95% CI, −0.67 to −0.05) suggesting less progression among those receiving medical treatment. Further adjustments for the incidence of cataract requiring surgery resulted in mean scores that were not different among the groups of interest (MD, −0.28; 95% CI, −0.59 to 0.03).

Two trials included in the Rolim de Moura (2007) review compared ALT to medications in newly diagnosed glaucoma patients and reported on visual field outcomes.79 The risk of visual field loss among participants randomized to laser trabeculoplasty was 23 percent lower when compared to participants receiving medical treatment at one year (RR, 0.77; 95% CI, 0.46 to 1.28) and 30 percent lower at two years (RR, 0.70; 95% CI, 0.42 to 1.16).

#### Detailed Analysis of Primary Studies

A limited number of trials with optic nerve and visual field outcomes met our inclusion criteria. Given the methodological heterogeneity of these studies, we present a narrative summary of the results.

Two studies, included in existing systematic reviews, warrant mention. Jay (1989) enrolled 116 newly diagnosed patients with primary OAG who had untreated IOP greater than 25 mmHg on two occasions in an RCT comparing medical therapy (up to three medications followed by trabeculectomy) to trabeculectomy from 1980–1985.^110^ Additional therapy was provided at the discretion of the treating clinician. Visual fields were followed using a Tubingen perimeter and categorized by severity with a one grade worsening of the visual field considered “progression.” Those undergoing surgery had more stable fields than those started with medical therapy. Based on results from survival analysis, surgery appeared to preserve visual field more in those with mild field loss than those with more severe field loss at baseline. This study showed a benefit of surgery first on the visual field, but the baseline IOP was very high (in the upper 30s) for the group as a whole and the results may not apply to those with lower baseline IOP.

In a study included in the existing systematic reviews, Migdal (1986) assessed visual field outcomes using Friedman automated visual field tests in 168 POAG patients randomized to surgery, medicines (pilocarpine, sympathomimetics, and/or timolol) or laser SLT and found that visual field score did not change significantly over 5 years in the surgery group, but did worsen in both the other arms.120

Our systematic review identified one eligible RCT. Tuuolonin (1989) enrolled 191 consecutive Finnish treatment-naive phakic patients with primary OAG or PXG in an RCT comparing laser trabeculoplastySLT to medical therapy and reported on 39 of these at one year.35 No significant changes in visual field or optic nerve were noted in the two groups, but duration of followup was short and the number of patients completing one year was small.

The grading of evidence for KQ 4c with all the domains is summarized in Table 10.

Table 10 Grading of evidence for KQ 4c

Number of Studies; Participants | Domains Pertaining to Strength of Evidence | Consistency | Directness | Precision | Strength of Evidence
Visual Field
1;191 | RCT/High | Not Applicable | Indirect | Imprecise | Insufficient
Optic Nerve Changes
1;191 | RCT/High | Not applicable | Direct | Precise | Insufficient

#### Conclusions

Based on systematic reviews and additional primary studies, both medical and surgical treatments decrease the risk of incident or worsening of visual field loss, but initial surgery may be more effective in this regard.

### KQ 6c What harms are reported in studies of medical versus surgical treatments for open-angle glaucoma?

#### Key Points

- Trabeculectomy is associated with cataract worsening and an increased need for cataract surgery over time when compared to medical treatments for glaucoma. (Systematic review)
- Intraocular surgery rarely results in severe vision loss due to infection and or bleeding. These risks are not associated with medical or laser treatments.
- Laser trabeculoplasty can produce peripheral anterior synechiae, whereas medical treatment does not. (Systematic review)

#### Summary of Evidence From Systematic Reviews

Burr (2004) reported a significantly higher risk of cataract (OR, 2.69; 95% CI, 1.64 to 4.42) and cataract surgery at up to three years post intervention (HR, 2.72; 95% CI, 1.51 to 4.89) in the trabeculectomy group compared to the medication group.116 Surgical complications included serous choroidal detachment (11%), hyphema (11%), encapsulated blebs (12%), and shallow or flat anterior chamber (14%) (one trial, 517 eyes, but reports also encompass fellow eyes not enrolled in the trial).

Rolim de Moura (2007) reported an elevated risk of systemic (RR 4.88) and ocular (RR 1.5) adverse effects among participants receiving laser trabeculoplasty with beta blockers versus no treatment, but each of these outcomes were reports from single trials and were not statistically significant.79 There was, however, an 11-fold increase in the risk of peripheral anterior synechiae among participants randomized to argon laser trabeculoplasty when compared to participants receiving medical treatment (95% CI, 5.63 to 22.09, two trials).

#### Detailed Analysis of Primary Studies

We included two randomized controlled trials that reported harms related to medical versus surgical treatment of OAG.35 110 We did not identify any observational studies.

Harms were not covered in a systematic fashion in the primary studies and therefore the results could not be synthesized. The harms reported in the primary studies are summarized in Appendix C.

#### Grading of Evidence

Grading was not completed as harms were addressed in a variety of ways (i.e., different outcomes) in the two RCTs identified for this question.

#### Conclusions

The evidence is conclusive that intraocular glaucoma surgery increases the risk of cataract and cataract surgery when compared to laser trabeculoplasty and medical treatment. Laser trabeculoplasty does not carry the risk of ocular discomfort associated with intraocular glaucoma surgery or medications. Medical therapy can produce systemic harms that are not produced by trabeculoplasty or intraocular glaucoma surgery. Ocular side effects are greater in the first 2 years after trabeculectomy than with medical therapy, but are similar after 2 years. Intraocular glaucoma surgery carries the rare but serious risk of intraocular infection, which does not occur with laser or medical treatment.

### KQ 2 Do medical treatments, lasers and other surgical treatments improve patient-reported outcomes?

#### Key Points

- There is no direct evidence regarding the impact of glaucoma treatment on patient reported outcomes
- Medical and surgical treatments reduce the patient’s fear of blindness compared to after diagnosis
- Several studies suggest that the type of glaucoma treatment does not have an influence on QOL.
- There is some evidence that among medical treatments, patients prefer those that are less frequently applied.
- Since there are unlikely to be any future trials with a placebo arm, it will not be possible to determine definitively if treatments improve patient-reported outcomes relative to no treatment. It will still be possible to compare the effectiveness of different treatments on patient-reported outcomes, however.

#### Summary of Evidence From Systematic Reviews

Two systematic reviews addressed the relationship between medical versus surgical treatment of OAG and patient-reported outcomes, and the included studies are summarized in the analysis of primary studies section that follows.79,116

#### Detailed Analysis of Primary Studies

We identified nine trials that met our eligibility criteria and assessed patient-reported outcomes. Three trials reported QOL outcomes and one of these also reported fear of blindness as a QOL outcome.121–123 Two trials reported patient preference.124,125 One trial reported patient satisfaction and convenience.126 Three additional trials used a QOL instrument that was not publicly available and were not analyzed for that reason.127–129 We thus include six trials in our narrative summary.

Four trials compared medical treatments, including one that compared a solution to a gel. One trial compared trabeculectomy to medical treatment and another trial compared laser plus medical treatment to no treatment. The six trials varied in diagnosis, age, race and severity of glaucoma and risk of bias. We did not perform a meta-analysis due to appreciable variability in interventions, outcomes, and follow-up intervals. The studies are described in detail in Evidence Table 21 (Appendix C) and those included in the analysis are summarized in Summary Table below.

We present a summary of the studies included in the review of KQ 2 with interventions, outcomes and results (Table 11).

Table 11 Summary of evidence for KQ 2

Study | Design, Sample Size | Interventions | Outcomes | Overall Risk of Bias | Results
CIGTS 2001^122,130^ | RCT 607 patients, | Primarily trabeculectomy (with or without 5-fluorouracil) vs. Primarily medications, starting with topical beta-blocker | - QOL; - Fear of blindness; - Symptom (frequency and bothersomeness) | Low | - QOL: No differences.; - Symptoms: Overall decrease in both groups. Surgical patients reporting 22% more symptom bothersomeness related to visual function; - Fear of blindness decreased in both groups
EMGT 2005^123^ | RCT 255 patients | No treatment vs. Betaxolol and ALT, | - QOL | Low | No difference
Javitt 2000^121^ | RCT 219 patients | Brimonidine vs. Timolol | - QOL | Medium | No difference
Solish 2004^126^ | RCT 492 patients | Timolol/Dorzolamide fixed combination vs. Timolol and Brimonidine | - Convenience; - Satisfaction | Medium | Both treatments were convenient for >80% of patients and satisfied > 82% of the patients.
Konstas 2003^125^ | Randomized cross-over trial 54 patients | Latanoprost vs. Timolol/Dorzolamide fixed combination | - Preference | Medium | 80 % preferred lanatanoprost vs. 20% timolol/dorzolamide
Schenker 1999^124^ | Randomized cross-over trial 202 patients | Timolol Gel vs. Timolol Solution | - Preference | Medium | - 71% preferred timolol gel vs. 29% timolol solution; - compliance was higher with timolol gel

#### Outcomes

##### Quality of Life

Comparison between different treatment groups was made in three trials (Collaborative Initial Glaucoma Treatment Study - CIGTS 2001, EMGT 2005, Javitt 2000). The CIGTS Study, comparing medical treatment to surgical trabeculectomy, reported no significant time-specific differences between treatment groups in either the Visual Activities Questionnaire Total or Peripheral Vision subscale scores; however, with the Acuity subscale, time-specific treatment group differences were observed at 2-, 6-, and 30-month followup periods, with more dysfunction reported by the surgically treated group.130 In addition, surgical patients reported approximately 22% more symptom bothersomeness on the Symptom Impact Glaucoma Total score. There were no treatment group differences noted in model-based results for the disease-specific measure of patient perceptions.130 In the EMGT, a Swedish version of the National Eye Institute Visual Function Questionnaire-25 was administered to subjects in the two arms of the study, those treated with laser trabeculoplasty and betaxolol 0.5%, and those who were not treated. Treatment was not associated with a change in the QOL as assessed by the National Eye Institute Visual Function Questionnaire-25.^123^ Lastly, Javitt (2000) compared brimonidine 0.2% and timolol 0.5% treated individuals over 4 months and QOL was assessed with the SF-36. 121 The changes of the SF-36 scores only varied during the study from 1 to 3 units on a scale of 0–100, which was not statistically significant.

One study (CIGTS, 2001) assessed fear of blindness as a QOL outcome and found a decrease in both groups (pharmacological and surgical) throughout the course of the study.122 At baseline, 34% of all patients reported moderate amount or a lot of worry about blindness. After 5 years this number decreased to 11%. The authors could not detect any association between the initial treatment assignment and fear of blindness.

##### Satisfaction and Convenience

Solish (2004) assessed patient satisfaction and convenience after 1 and 3 months of treatment with either the fixed combination (both drugs in one bottle) of timolol 0.5 percent and dorzolamide 2 percent, or the unfixed combination (separate bottles) of timolol 0.5 percent and brimonidine 0.2 percent.126 They found no statistically significant differences between the two drugs alone and in fixed combination. Eight-seven percent of patients treated with the fixed combination of dorzolamide/timolol reported the treatment to be convenient versus 80 percent treated with the concomitant administration of the two drugs (p=0.056). Eighty-seven percent of patients treated with the fixed combination of dorzolamide/timolol were satisfied with the treatment versus 85 percent treated with the concomitant administration of the two drugs (p=0.643). The study was funded by the manufacturer of the fixed combination product.

##### Preference

In one trial (Konstas, 2003), the subjects preferred latanoprost over the fixed combination of timolol maleate/dorzolamide (80% vs 20%, p<0.0001), mostly because of convenience (latanoprost was administered only once a day).125 In the other trial (Schenker (1999)) the patients preferred timolol gel given once a day over timolol solution (71% vs 29%) given twice a day after 6 weeks on each treatment (p<0.001), because of the reduced frequency of administration.124

The grading of evidence for KQ 2 with all the domains is summarized in Table 12.

Table 12 Grading of evidence for KQ 2

Number of Studies; Subjects | Risk of Bias: Design/Quality | Consistency | Directness | Precision | Strength of Evidence
Quality of Life
3; 1081 | RCT/ low | Consistent | Direct | Imprecise | Insufficient
Satisfaction and Convenience
1; 492 | RCT/ medium | Not applicable | Direct | Imprecise | Insufficient
Preference
2; 256 | Randomized cross-over/ medium | Consistent | Direct | Imprecise | Insufficient
Fear of Blindness
1; 607 | RCT/ low | Not applicable | Direct | Imprecise | Insufficient

#### Conclusions

Open-angle glaucoma generally is asymptomatic until late in its clinical course, and treatment is generally considered to slow or stop the course of disease rather than improve symptoms. For this reason, it is understood that the initiation of treatment is not expected to improve patient-reported outcomes. Hence, the goal is to select an effective treatment with the least treatment-related adverse outcomes. Therefore, it is not surprising that few studies compare patient-reported outcomes before and after the initiation of treatment. In the EMGT, subjects treated with eye drops and laser treatment reported the same QOL as those subjects who were observed without treatment. In the CIGTS, patients undergoing trabeculectomy surgery reported more eye-related symptoms in the first 2 years after surgery when compared to the group randomized to medical treatment.

The reduction in fear of blindness with initiation of treatment in the CIGTS must be kept in context. These were newly diagnosed patients who had no fear of blindness before diagnosis, and so naturally would have had concerns about blindness after learning of their diagnosis. This fear of blindness diminished over time, possibly as they realized that there was not rapidly losing vision, and was not clearly a treatment effect.

### KQ 5 Does lowering intraocular pressure or preventing or slowing the progression of optic nerve damage and visual field loss reduce visual impairment and change vision-related quality of life?

#### Key Points

- We found no studies that adequately addressed the relationship between the intermediate outcomes of intraocular pressure reduction, prevention of optic nerve damage, or prevention of visual field loss and the outcomes of visual impairment and vision-related quality of life.

#### Summary of Evidence From Systematic Reviews

We did not identify any systematic reviews or well designed primary studies that address the relationship between the intermediate outcomes of IOP reduction, prevention of optic nerve damage, or prevention of visual field loss and the outcomes of visual impairment and vision-related QOL.

#### Detailed Analysis From Primary Studies

Two studies were identified in which some link was made between the intermediate outcomes of IOP reduction, prevention of optic nerve damage, and prevention of visual field loss and the final outcomes of decreased visual impairment and vision-related QOL.30 131 The study by Prata (2009) was motivated by the hypothesis that decreasing IOP alone can result in an improvement in visual function.30 All 54 subjects received pressure-lowering medication such that there was an overall reduction in IOP from 24.8 mmHg to 16.9 mmHg (p<0.001). After four weeks of treatment, the authors reported an increase in both visual field mean deviation from −6.56 to −5.72 (p=0.02) and a visual analog scale132 from 6.96 to 7.52 (p=0.045). These results, while suggestive that lowering IOP alone may be beneficial for visual function and patient-reported quality of vision, are severely limited by the fact that there was no control group that did not receive pressure-lowering medications.

The second study, by Montemayor (2001), is a cross-sectional evaluation of the relationship between quality of life, visual function, and numbers of glaucoma medications.131 While there were no significant correlations between objective measures of visual function (visual acuity, visual field mean deviation) and quality of life, they did find correlation between the Visual Function Assessment133 and quality of life as measured by the EQ-5D health status tool.134 These results only indirectly address KQ 5 by measuring the correlation between visual field damage and QOL, which does not imply a cause and effect relationship, and the study also does not consider reduction in visual field loss.

While these studies met our inclusion criteria, neither of them was adequately designed to provide reliable information on which to draw conclusions regarding KQ 5.

The grading of evidence for KQ 5 with all the domains is summarized in Table 13.

Table 13 Grading of evidence for KQ 5

Number of Studies; Participants | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Visual Impairment
2; 278 | RCT and Observational (cross-sectional) studies/ Medium | Inconsistent | Indirect | Imprecise | Insufficient

#### Link Between Visual Field Loss and Visual Impairment

Although there are no studies linking any glaucoma treatment to differential effects on either visual impairment or patient reported outcomes, there have been a number of cross-sectional studies relating the degree of visual field loss due to glaucoma to both of these outcomes. While none of these studies was eligible for inclusion in this systematic review, some of this evidence is discussed below in order to make it clear that treatment may affect the final outcomes in the analytic framework by slowing the loss of visual field.

In its most severe form OAG can cause total and irreversible bilateral blindness. Therefore there is no question that OAG can produce marked decreases in both patient reported outcomes and objectively observed functional limitations. Cross-sectional studies comparing patients with OAG with visual field loss to controls have demonstrated that both patient-reported and objectively observed function is diminished in glaucoma.

Walking and balance are important functions, particularly in the older age group most likely to have visual field loss from glaucoma. In a glaucoma focus group, difficulty walking was a common complaint. Forty-nine percent of patients described difficulties with steps, 42 percent described difficulty going shopping, and 36 percent described difficulty crossing the road.135 Similarly, questionnaires given to glaucoma patients demonstrated that two of the strongest correlates with binocular visual field loss were difficulty with stairs and bumping into objects, 136 Observation of walking by patients with glaucoma provides objective evidence of problems to corroborate the patient reported outcomes. Patients with glaucoma walk more slowly than similarly aged controls, and walking speed is strongly correlated with mean deviation in the worse-eye visual field.137 A population-based comparison of walking in individuals with and without glaucoma demonstrated that patients with bilateral, but not unilateral, glaucoma walked slower, and bumped into objects more frequently.138 In the Salisbury Eye Evaluation Study, patients with bilateral, but not unilateral glaucoma had more trouble performing balance tasks such as semi-tandem and tandem stands, in which the heel of one foot is placed next to or in front of the big toe of the second foot.138

Falling is one serious outcome that may result from difficulties with walking and balance. Glaucoma patients in the Singapore Malay Eye Study had four-fold higher odds of falling than non-glaucoma individuals after adjusting for visual acuity.139 Among Medicare recipients, glaucoma patients coded as visually impaired were more likely to have had a fall or accident (OR 1.6) and to have had a femur fracture (OR 1.6) when compared with glaucoma patients not coded to have visual loss.140

Driving is a critical activity of daily living. Patients with glaucoma perceive more difficulty driving than control individuals without glaucoma,141 and perceived difficulty increases with worsening visual field damage in the better eye.142 Participants in the Salisbury Eye Evaluation Study with bilateral, but not unilateral, glaucoma had worse self-reported scores with regard to driving at night, suggesting that disability may occur primarily in patients with bilateral disease.143

Difficulty with tasks involving near vision is more common in glaucoma patients than in persons without glaucoma. Altangerel directly tested the performance of glaucoma patients on an index of activities and identified searching for objects, reading, and manual tasks (placing a stick into holes of different sizes) as most related to the extent of visual field loss.144

Therefore, with respect to varied important tasks of everyday living, individuals with visual field loss from glaucoma have worse self-reported visual abilities and measurably worse task performance than their counterparts without glaucoma.

#### Conclusions

Evidence from cross-sectional studies not included in this review, because these studies do not address the KQs in our analytic framework, supports the conclusion that more severe visual field loss results in more visual impairment and worse patient reported outcomes. This link is the basis for current treatments, which are intended to slow visual field progression by lowering intraocular pressure. However, we found no studies showing a direct link between treatment and visual impairment or patient-reported outcomes, however. We also found no link between those final outcomes and the intermediate outcomes addressed by KQ 3 and 4. Future studies might advance the field by evaluating this indirect link.