# References

1 Quigley HA, Broman AT. The number of people with glaucoma worldwide in 2010 and 2020. Br J Ophthalmol. 2006;90(3):262-7. [pmid: 16488940].
2 Quigley HA, Flower RW, Addicks EM, et al. The mechanism of optic nerve damage in experimental acute intraocular pressure elevation. Invest Ophthalmol Vis Sci. 1980;19(5):505-17. [pmid: 6154668].
3 Sommer A, Tielsch JM, Katz J, et al. Relationship between intraocular pressure and primary open angle glaucoma among white and black Americans. The Baltimore Eye Survey. Arch Ophthalmol. 1991;109(8):1090-5. [pmid: 1867550].
4 Kass MA, Heuer DK, Higginbotham EJ, et al. The Ocular Hypertension Treatment Study: a randomized trial determines that topical ocular hypotensive medication delays or prevents the onset of primary open-angle glaucoma. Arch Ophthalmol. 2002;120(6):701-13. discussion 829–30. [pmid: 12049574].
5 Heijl A, Leske MC, Bengtsson B, et al. Reduction of intraocular pressure and glaucoma progression: results from the Early Manifest Glaucoma Trial. Arch Ophthalmol. 2002;120(10):1268-79. [pmid: 12365904].
6 Li T. Bridging the gap between evidence generation and clinical decision making. [PhD dissertation]. United States -- Maryland. The Johns Hopkins University. 2010.
7 Jampel HD, Lubomski LH, Friedman DS, et al. Treatment of coexisting cataract and glaucoma, Evidence Report/Technology Assessment No. 38. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-97-0006.) AHRQ Publication No. 03-E041. Rockville, MD. Agency for Healthcare Research and Quality. June. 2003. www.ncbi.nlm.nih.gov/books/NBK33731/.
8 Centers for Disease Control and Prevention. International Classification of Diseases, Ninth Revision (ICD-9). Centers for Disease Control and Prevention. 2009.
9 Heijl A, Bengtsson B, Hyman L, et al. Early Manifest Glaucoma Trial Group. Natural history of open-angle glaucoma. Ophthalmology. 2009;116(12):2271-6. [pmid: 19854514].
10 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. [updated March 2011]. The Cochrane Collaboration. 2011.
11 Wells GA, Shea B, O’Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Ottawa Hospital Research Institute.
12 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(47454):1490. [pmid: 15205295].
13 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health-care Program. J Clinical Epidemiology. 2010;63(5):513-23.
14 Whitlock EP, Lin JS, Chou R, et al. Using existing systematic reviews in complex systematic reviews. Ann Intern Med. 2008;148:776-82. [pmid: 18490690].
15 Shaarawy TM, Sherwood MB, Grehn F, editors. Guidelines on Design and Reporting of Glaucoma Surgical Trials. Amsterdam, The Netherlands. Kugler Publications. 2009.
16 Ederer F, Gaasterland DA, Dally LG, et al. The Advanced Glaucoma Intervention Study (AGIS): 13. Comparison of treatment outcomes within race: 10-year results. Ophthalmology. 2004;111(4):651-64. [pmid: 15051195].
17 Lichter PR, Musch DC, Gillespie BW, et al. Interim clinical outcomes in the Collaborative Initial Glaucoma Treatment Study comparing initial treatment randomized to medications or surgery. Ophthalmology. 2001;108(11):1943-53. [pmid: 11713061].
18 Aptel F, Cucherat M, Denis P. Efficacy and tolerability of prostaglandin analogs: a meta-analysis of randomized controlled clinical trials. J Glaucoma. 2008;17(8):667-73. [pmid: 19092464].
19 Cheng JW, Wei RL. Meta-analysis of 13 randomized controlled trials comparing bimatoprost with latanoprost in patients with elevated intraocular pressure. Clin Ther. 2008;30(4):622-32. [pmid: 18498911].
20 Eyawo O, Nachega J, Lefebvre P, et al. Efficacy and safety of prostaglandin analogues in patients with predominantly primary open-angle glaucoma or ocular hypertension: a meta-analysis. Clin Ophthalmol. 2009;3:447-56. [pmid: 19684868].
21 Fung AT, Reid SE, Jones MP, et al. Meta-analysis of randomised controlled trials comparing latanoprost with brimonidine in the treatment of open-angle glaucoma, ocular hypertension or normal-tension glaucoma. Br. J. Ophthalmol. 2007;91(1):62-8. [pmid: 16956912].
22 Hodge WG, Lachaine J, Steffensen I, et al. The efficacy and harm of prostaglandin analogues for IOP reduction in glaucoma patients compared to dorzolamide and brimonidine: a systematic review. Br J Ophthalmol. 2008;92(1):7-12. [pmid: 18156371].
23 Honrubia F, Garcia-Sanchez J, Polo V, et al. Conjunctival hyperaemia with the use of latanoprost versus other prostaglandin analogues in patients with ocular hypertension or glaucoma: a meta-analysis of randomised clinical trials. Br J Ophthalmol. 2009;93(3):316-21. [pmid: 19019922].
24 Li N, Chen X-M, Zhou Y, et al. Travoprost compared with other prostaglandin analogues or timolol in patients with open-angle glaucoma or ocular hypertension: Meta-analysis of randomized controlled trials. Clinical and Experimental Ophthalmology: Clin. Exp. Ophthalmol. 2006;34(8):755-64.
25 Zhang WY, Po AL, Dua HS, Azuara-Blanco A. Meta-analysis of randomised controlled trials comparing latanoprost with timolol in the treatment of patients with open angle glaucoma or ocular hypertension. Br J Ophthalmol. 2001;85(8):983-90. [pmid: 11466259].
26 Loon SC, Liew G, Fung A, et al. Meta-analysis of randomized controlled trials comparing timolol with brimonidine in the treatment of glaucoma. Clin Experiment Ophthalmol. 2008;36(3):281-9. [pmid: 18412600].
27 Cheng JW, Xi GL, Wei RL, et al. Efficacy and tolerability of nonpenetrating glaucoma surgery augmented with mitomycin C in treatment of open-angle glaucoma: a meta-analysis. Can J Ophthalmol. 2009;44(1):76-82. [pmid: 19169318].
28 Cox JA, Mollan SP, Bankart J, et al. Efficacy of antiglaucoma fixed combination therapy versus unfixed components in reducing intraocular pressure: a systematic review. Br J Ophthalmol. 2008;92(6):729-34. [pmid: 18460539].
29 Vass C, Hirn C, Sycha T, et al. Medical interventions for primary open angle glaucoma and ocular hypertension. Cochrane Database Syst Rev. 2007;(4).
30 Prata TS, Piassi MV, Melo LA Jr. Changes in visual function after intraocular pressure reduction using antiglaucoma medications. Eye (Lond). 2009;23(5):1081-5. [pmid: 18670465].
31 Marcon IM. A double-masked comparison of betaxolol and levobunolol for the treatment of primary open-angle glaucoma. Arquivos Brasileiros De Oftalmologia. 1990;53(1):27-32.
32 Chiselita D, Antohi I, Medvichi R, et al. Comparative analysis of the efficacy and safety of latanoprost, travoprost and the fixed combination timolol-dorzolamide; a prospective, randomized, masked, cross-over design study. Oftalmologia. 2005;49(3):39-45. [pmid: 16408674].
33 Yamamoto T, Kitazawa Y, Noma A, et al. The effects of the beta-adrenergic-blocking agents, timolol and carteolol, on plasma lipids and lipoproteins in Japanese glaucoma patients. J Glaucoma. 1996;5(4):252-7. [pmid: 8795770].
34 Flammer J, Kitazawa Y, Bonomi L, et al. Influence of carteolol and timolol on IOP an visual fields in glaucoma: a multi-center, double-masked, prospective study. Eur J Ophthalmol. 1992;2(4):169-74. [pmid: 1490088].
35 Tuulonen A, Koponen J, Alanko HI, et al. Laser trabeculoplasty versus medication treatment as primary therapy for glaucoma. Acta Ophthalmol (Copenh). 1989;67(3):275-80. [pmid: 2669435].
36 Ravalico G, Salvetat L, Toffoli G, et al. Ocular hypertension: A follow-up study in treated and untreated patients. NEW TRENDS OPHTHALMOL. 1994;9(2):97-101.
37 Berson FG, Cohen HB, Foerster RJ, et al. Levobunolol compared with timolol for the long-term control of elevated intraocular pressure. Arch Ophthalmol. 1985;103(3):379-82. [pmid: 3883972].
38 Schuman JS, Horwitz B, Choplin NT, et al. A 1-year study of brimonidine twice daily in glaucoma and ocular hypertension: A controlled, randomized, multicenter clinical trial. Arch Opthalmol. 1997;115(7):847-52.
39 Sharpe ED, Day DG, Beischel CJ, et al. Brimonidine purite 0.15% versus dorzolamide 2% each given twice daily to reduce intraocular pressure in subjects with open angle glaucoma or ocular hypertension. Br J Ophthalmol. 2004;88(7):953-6. [pmid: 15205246].
40 Liu CJ, Ko YC, Cheng CY, et al. Changes in intraocular pressure and ocular perfusion pressure after latanoprost 0.005% or brimonidine tartrate 0.2% in normal-tension glaucoma patients. Ophthalmology. 2002;109(12):2241-7. [pmid: 12466165].
41 Berry DP Jr, Van Buskirk EM, Shields MB. Betaxolol and timolol. A comparison of efficacy and side effects. Arch Ophthalmol. 1984;102(1):42-5. [pmid: 6367723].
42 Quaranta L, Pizzolante T, Riva I, et al. Twenty-four-hour intraocular pressure and blood pressure levels with bimatoprost versus latanoprost in patients with normal-tension glaucoma. Br J Ophthalmol. 2008;92(9):1227-31. [pmid: 18586898].
43 Quaranta L, Gandolfo F, Turano R, et al. Effects of topical hypotensive drugs on circadian IOP, blood pressure, and calculated diastolic ocular perfusion pressure in patients with glaucoma. Invest Ophthalmol Vis Sci. 2006;47(7):2917-23. [pmid: 16799034].
44 Larsson LI. Intraocular pressure over 24 hours after repeated administration of latanoprost 0.005% or timolol gel-forming solution 0.5% in patients with ocular hypertension. Ophthalmology. 2001;108(8):1439-44. [pmid: 11470697].
45 Yildirim N, Sahin A, Gultekin S. The effect of latanoprost, bimatoprost, and travoprost on circadian variation of intraocular pressure in patients with open-angle glaucoma. J Glaucoma. 2008;17(1):36-9. [pmid: 18303382].
46 Orzalesi N, Rossetti L, Bottoli A, et al. Comparison of the effects of latanoprost, travoprost, and bimatoprost on circadian intraocular pressure in patients with glaucoma or ocular hypertension. Ophthalmology. 2006;113(2):239-46. [pmid: 16458092].
47 Herman DC, Gordon MO, Beiser JA, et al. Topical ocular hypotensive medication and lens opacification: evidence from the ocular hypertension treatment study. Am J Ophthalmol. 2006;142(5):800-10. [pmid: 17056362].
48 Rainer G, Dorner GT, Garhofer G, et al. Changing antiglaucoma therapy from timolol to betaxolol: effect on ocular blood flow. Ophthalmologica. 2003;217(4):288-93. [pmid: 12792136].
49 Mirza GE, Karakucuk S, Temel E. Comparison of the effects of 0.5% timolol maleate, 2% carteolol hydrochloride, and 0.3% metipranolol on intraocular pressure and perimetry findings and evaluation of their ocular and systemic effects. J Glaucoma. 2000;9(1):45-50. [pmid: 10708231].
50 Vainio-Jylha E, Vuori ML. The favorable effect of topical betaxolol and timolol on glaucomatous visual fields: a 2-year follow-up study. Graefes Arch Clin Exp Ophthalmol. 1999;237(2):100-4. [pmid: 9987624].
51 Evans DW, Bartlett JD, Houde B, et al. Latanoprost-induced stabilization of central visual function in patients with primary open-angle glaucoma. J Ocul Pharmacol Ther. 2008;24(2):224-9. [pmid: 18355134].
52 Dirks MS, Noecker RJ, Earl M, et al. A 3-month clinical trial comparing the IOP-lowering efficacy of bimatoprost and latanoprost in patients with normal-tension glaucoma. Adv Ther. 2006;23(3):385-94. [pmid: 16912020].
53 Miglior S, Zeyen T, Pfeiffer N, et al. Results of the European Glaucoma Prevention Study. Ophthalmology. 2005;112(3):366-75. [pmid: 15745761].
54 Heijl A, Bengtsson B. Long-term effects of timolol therapy in ocular hypertension: a double-masked, randomised trial. Graefes Arch Clin Exp Ophthalmol. 2000;238(11):877-83. [pmid: 11148810].
55 Melamed S, David R. Ongoing clinical assessment of the safety profile and efficacy of brimonidine compared with timolol: year-three results. Brimonidine Study Group II. Clin Ther. 2000;22(1):103-11. [pmid: 10688394].
56 Messmer C, Flammer J, Stumpfig D. Influence of betaxolol and timolol on the visual fields of patients with glaucoma. Am J Ophthalmol. 1991;112(6):678-81. [pmid: 1957903].
57 Martínez A, Sanchez-Salorio M. Predictors for visual field progression and the effects of treatment with dorzolamide 2% or brinzolamide 1% each added to timolol 0.5% in primary open-angle glaucoma. Acta Ophthalmologica. 2010;88(5):541-52. [pmid: 19799592].
58 Alm A, Schoenfelder J, McDermott J. A 5-year, multicenter, open-label, safety study of adjunctive latanoprost therapy for glaucoma. Arch Ophthalmol. 2004;122(7):957-65. [pmid: 15249358].
59 Waldock A, Snape J, Graham CM. Effects of glaucoma medications on the cardiorespiratory and intraocular pressure status of newly diagnosed glaucoma patients. Br J Ophthalmol. 2000;84(7):710-3. [pmid: 10873979].
60 Shin D. Adjunctive therapy with brinzolamide 1% ophthalmic suspension (Azopt) in patients with open-angle glaucoma or ocular hypertension maintained on timolol therapy. Surv Ophthalmol. 2000;44(Suppl 2):S163-8. [pmid: 10665519].
61 Diggory P, Cassels-Brown A, Vail A, et al. Randomised, controlled trial of spirometric changes in elderly people receiving timolol or betaxolol as initial treatment for glaucoma. Br J Ophthalmol. 1998;82(2):146-9. [pmid: 9613379].
62 Netland PA, Weiss HS, Stewart WC, et al. Cardiovascular effects of topical carteolol hydrochloride and timolol maleate in patients with ocular hypertension and primary open-angle glaucoma. Night Study Group. Am J Ophthalmol. 1997;123(4):465-77. [pmid: 9124243].
63 Scoville B, Mueller B, White BG, et al. A double-masked comparison of carteolol and timolol in ocular hypertension. Am J Ophthalmol. 1988;105(2):150-4. [pmid: 3277436].
64 Denis P, Baudouin C, Bron A, et al. First-line latanoprost therapy in ocular hypertension or open-angle glaucoma patients: a 3-month efficacy analysis stratified by initial intraocular pressure. BMC Ophthalmol. 2010;10:4. [pmid: 20181282].
65 Barnett EM, Fantin A, Wilson BS, et al. The incidence of retinal vein occlusion in the ocular hypertension treatment study. Ophthalmology. 2010;117(3):484-8. [pmid: 20031222].
66 Farris EP. Efficacy and tolerability of a large scale change in regimen from latanoprost to travoprost in glaucoma patients at the Manhattan Veterans Administration Hospital. Clin Ophthalmol. 2008;2(2):303-12. [pmid: 19668721].
67 Sharpe ED, Reynolds AC, Skuta GL, et al. The clinical impact and incidence of periocular pigmentation associated with either latanoprost or bimatoprost therapy. Curr Eye Res. 2007;32(12):1037-43. [pmid: 18085467].
68 Chiselita D. Evaluation of the role of travoprost 0.004% ophthalmic solution in the management of open angle glaucoma and ocular hypertensive patients. Oftalmologia. 2007;51(2):81-6. [pmid: 17937041].
69 Thelen U, Christ T, Schnober D, et al. Midterm response with latanoprost therapy in german ocular hypertension patients. Curr Eye Res. 2007;32(1):51-6. [pmid: 17364735].
70 Zimmerman TJ, Stewart WC. Intraocular pressure, safety, and quality of life in glaucoma patients switching to latanoprost from monotherapy treatments. J Ocul Pharmacol Ther. 2003;19(5):405-15. [pmid: 14583133].
71 Arici MK, Arici DS, Topalkara A, et al. Adverse effects of topical antiglaucoma drugs on the ocular surface. Clin Experiment Ophthalmol. 2000;28(2):113-7. [pmid: 10933774].
72 Renieri G, Fuhrer K, Scheithe K, et al. Efficacy and tolerability of preservative-free eye drops containing a fixed combination of dorzolamide and timolol in glaucoma patients. J Ocul Pharmacol Ther. 2010;26(6):597-603. [pmid: 20977366].
73 Kobayashi H, Kobayashi K. A correlation between latanoprost-induced conjunctival hyperemia and intraocular pressure-lowering effect. J Glaucoma. 2011;20(1):3-6. [pmid: 20520573].
74 Chai C, Loon SC. Meta-analysis of viscocanalostomy versus trabeculectomy in uncontrolled glaucoma. J Glaucoma. 2010;19(8):519-27. [pmid: 20179632].
75 Cheng JW, Xi GL, Wei RL, et al. Efficacy and tolerability of nonpenetrating filtering surgery in the treatment of open-angle glaucoma: a meta-analysis. Ophthalmologica. 2010;224(3):138-46. [pmid: 19738394].
76 Wilkins M, Indar A, Wormald R. Intra-operative mitomycin C for glaucoma surgery. Cochrane Database Syst Rev. 2005;(4):CD002897. [pmid: 16235305].
77 Zacharia PT, Deppermann SR, Schuman JS. Ocular hypotony after trabeculectomy with mitomycin C. Am J Ophthalmol. 1993;116(3):314-26. [pmid: 8357056].
78 Kirwan JF, Rennie C, Evans JR. Beta radiation for glaucoma surgery. Cochrane Database Syst Rev. 2009;(2):CD003433. [pmid: 19370589].
79 Rolim de Moura CR, Paranhos A Jr, Wormald R. Laser trabeculoplasty for open angle glaucoma, Cochrane Database of Systematic Reviews: Reviews. John Wiley & Sons, Ltd. Chichester, UK. [doi: 10.1002/14651858.CD003919.Pub2]. 2007;2007(4). 4.
80 Minckler DS, Vedula SS, Li TJ, et al. Aqueous shunts for glaucoma. Cochrane Database Syst Rev. 2006;(2):CD004918. [pmid: 16625616].
81 Liu HN, Chen XL, Li X, et al. Efficacy and tolerability of one-site versus two-site phaco-trabeculectomy: a meta-analysis of randomized controlled clinical trials. Chin Med J (Engl). 2010;123(15):2111-5. [pmid: 20819551].
82 Wormald R, Wilkins MR, Bunce C. Post-operative 5-Fluorouracil for glaucoma surgery. Cochrane Database Syst Rev. 2001;(3):CD001132. [pmid: 11686977].
83 de Jong LA. The Ex-PRESS glaucoma shunt versus trabeculectomy in open-angle glaucoma: a prospective randomized study. Adv Ther. 2009;26(3):336-45. [pmid: 19337705].
84 Russo V, Scott IU, Stella A, et al. Nonpenetrating deep sclerectomy with reticulated hyaluronic acid implant versus punch trabeculectomy: a prospective clinical trial. Eur J Ophthalmol. 2008;18(5):751-7. [pmid: 18850554].
85 Mielke C, Dawda VK, Anand N. Deep sclerectomy and low dose mitomycin C: a randomised prospective trial in west Africa. Br J Ophthalmol. 2006;90(3):310-3. [pmid: 16488952].
86 Shaarawy T, Mermoud A. Deep sclerectomy in one eye vs deep sclerectomy with collagen implant in the contralateral eye of the same patient: long-term follow-up. Eye (Lond). 2005;19(3):298-302. [pmid: 15258610].
87 Tang M, Fu Y, Fu MS, et al. The efficacy of low-energy selective laser trabeculoplasty. Ophthalmic Surg Lasers Imaging. 2011;42(1):59-63. [pmid: 21117578].
88 Sanders R, MacEwen CJ, Haining WM. Trabeculectomy: effect of varying surgical site. Eye (Lond). 1993;7(Pt 3):440-3. [pmid: 8224303].
89 el Sayyad F, el-Rashood A, Helal M, et al. Fornix-based versus limbal-based conjunctival flaps in initial trabeculectomy with postoperative 5-fluorouracil: four-year follow-up findings. J Glaucoma. 1999;8(2):124-8. [pmid: 10209729].
90 Kobayashi H, Kobayashi K. A Comparison of the Intraocular Pressure Lowering Effect of Adjustable Suture Versus Laser Suture Lysis for Trabeculectomy. J Glaucoma. 2010.
91 Reibaldi A, Uva MG, Longo A. Nine-year follow-up of trabeculectomy with or without low-dosage mitomycin-c in primary open-angle glaucoma. Br J Ophthalmol. 2008;92(12):1666-70. [pmid: 18782799].
92 Kim YY, Sexton RM, Shin DH, et al. Outcomes of primary phakic trabeculectomies without versus with 0.5- to 1-minute versus 3- to 5-minute mitomycin C. Am J Ophthalmol. 1998;126(6):755-62. [pmid: 9859998].
93 Quaranta L, Bettelli S, Gandolfo E. Efficacy of sulodexide as adjunct in trabeculectomy. A two-year randomized clinical study. Acta Ophthalmol Scand Suppl. 2000;(232):63-5. [pmid: 11235544].
94 Rosentreter A, Schild AM, Jordan JF, et al. A prospective randomised trial of trabeculectomy using mitomycin C vs an ologen implant in open angle glaucoma. Eye (Lond). 2010;24(9):1449-57. [pmid: 20733558].
95 Eliezer RN, Kasahara N, Caixeta-Umbelino C, et al. Use of amniotic membrane in trabeculectomy for the treatment of glaucoma: a pilot study. Arq Bras Oftalmol. 2006;69(3):309-12. [pmid: 16936950].
96 Cillino S, Zeppa L, Di Pace F, et al. E-PTFE (Gore-Tex(registered trademark)) implant with or without low-dosage mitomycin-C as an adjuvant in penetrating glaucoma surgery: 2 year randomized clinical trial. Acta Ophthalmol. 2008;86(3):314-21. [pmid: 17995980].
97 Thimmarayan SK, Rao VA, Gupta A. Mini-trabeculectomy in comparison to conventional trabeculectomy in primary open angle glaucoma. Eur J Ophthalmol. 2006;16(5):674-9. [pmid: 17061217].
98 Das JC, Sharma P, Chaudhuri Z, et al. A comparative study of small incision trabeculectomy avoiding tenon’s capsule with conventional trabeculectomy. Ophthalmic Surg Lasers. 2002;33(1):30-6. [pmid: 11820660].
99 Kaplan-Messas A, Cohen Y, Blumenthal E, et al. Trabeculectomy and phaco-trabeculectomy with and without peripheral iridectomy. Eur J Ophthalmol. 2009;19(2):231-4. [pmid: 19253239].
100 Kozobolis VP, Siganos CS, Christodoulakis EV, et al. Two-site phacotrabeculectomy with intraoperative mitomycin-C: fornix- versus limbus-based conjunctival opening in fellow eyes. J Cataract Refract Surg. 2002;28(10):1758-62. [pmid: 12388024].
101 Fea AM. Phacoemulsification versus phacoemulsification with micro-bypass stent implantation in primary open-angle glaucoma: randomized double-masked clinical trial. J Cataract Refract Surg. 2010;36(3):407-12. [pmid: 20202537].
102 Kobayashi H, Kobayashi K. Randomized comparison of the intraocular pressure-lowering effect of phacoviscocanalostomy and phacotrabeculectomy. Ophthalmology. 2007;114(5):909-14. [pmid: 17397924].
103 Russo V, Barone A, Cosma A, et al. Selective laser trabeculoplasty versus argon laser trabeculoplasty in patients with uncontrolled open-angle glaucoma. Eur J Ophthalmol. 2009;19(3):429-34. [pmid: 19396790].
104 Goldenfeld M, Melamed S, Simon G, et al. Titanium:sapphire laser trabeculoplasty versus argon laser trabeculoplasty in patients with open-angle glaucoma. Ophthalmic Surg Lasers Imaging. 2009;40(3):264-9. [pmid: 19485290].
105 Frenkel RE, Shin DH, Epstein DL, et al. Laser trabeculoplasty: how little is enough?. Ophthalmic Surg Lasers. 1997;28(11):900-4. [pmid: 9387175].
106 Ederer F, Gaasterland DA, Dally LG, et al. The Advanced Glaucoma Intervention Study (AGIS): 13. Comparison of treatment outcomes within race: 10-year results. Ophthalmology. 2004;111(4):651-64. [pmid: 15051195].
107 Shin DH, Iskander NG, Ahee JA, et al. Long-term filtration and visual field outcomes after primary glaucoma triple procedure with and without mitomycin-C. Ophthalmology. 2002;109(9):1607-11. [pmid: 12208706].
108 Singh K, Byrd S, Egbert PR, et al. Risk of hypotony after primary trabeculectomy with antifibrotic agents in a black west African population. J Glaucoma. 1998;7(2):82-5. [pmid: 9559492].
109 Tressler CS, Cyrlin MN, Rosenshein JS, et al. Subconjunctival versus intrascleral mitomycin-C in trabeculectomy. Ophthalmic Surg Lasers. 1996;27(8):661-6. [pmid: 8858631].
110 Jay JL, Allan D. The benefit of early trabeculectomy versus conventional management in primary open angle glaucoma relative to severity of disease. Eye (Lond). 1989;3(Pt 5):528-35. [pmid: 2698360].
111 Shuster JN, Krupin T, Kolker AE, et al. Limbus- v fornix-based conjunctival flap in trabeculectomy. A long-term randomized study. Arch Ophthalmol. 1984;102(3):361-2. [pmid: 6703982].
112 Nassiri N, Nassiri N, Rahnavardi M, et al. A comparison of corneal endothelial cell changes after 1-site and 2-site phacotrabeculectomy. Cornea. 2008;27(8):889-94. [pmid: 18724149].
113 Jeganathan VS, Ghosh S, Ruddle JB, et al. Risk factors for delayed suprachoroidal haemorrhage following glaucoma surgery. Br J Ophthalmol. 2008;92(10):1393-6. [pmid: 18684750].
114 Shingleton BJ, Chaudhry IM, O’Donoghue MW. Phacotrabeculectomy: peripheral iridectomy or no peripheral iridectomy?. J Cataract Refract Surg. 2002;28(6):998-1002. [pmid: 12036643].
115 Schwiesow KA, Diamond GR. Hyphema and elevated intraocular pressure in a neonate. J Pediatr Ophthalmol Strabismus. 2004;41(3):183-4. [pmid: 15206606].
116 Burr J, Azuara-Blanco A, Avenell A. Medical versus surgical interventions for open angle glaucoma. 2004:CD004399.
117 Maier PC, Funk J, Schwarzer G, et al. Treatment of ocular hypertension and open angle glaucoma: meta-analysis of randomised controlled trials. BMJ. 2005;331(7509):134. [pmid: 15994659].
118 Lai JS, Chua JK, Tham CC, et al. Five-year follow up of selective laser trabeculoplasty in Chinese eyes. Clin Experiment Ophthalmol. 2004;32(4):368-72. [pmid: 15281969].
119 Migdal C, Hitchings R. Control of chronic simple glaucoma with primary medical, surgical and laser treatment. Trans Ophthalmol Soc U K. 1986;105(Pt 6):653-6. [pmid: 3310341].
120 Migdal C, Gregory W, Hitchings R. Long-term functional outcome after early surgery compared with laser and medicine in open-angle glaucoma. Ophthalmology. 1994;101(10):1651-6. discussion 1657. [pmid: 7936562].
121 Javitt JC, Schiffman RM. Clinical success and quality of life with brimonidine 0.2% or timolol 0.5% used twice daily in glaucoma or ocular t hypertension: a randomized clinical trial. Brimonidine Outcomes Study Group I. J Glaucoma. 2000;9(3):224-34. [pmid: 10877373].
122 Janz NK, Wren PA, Guire KE, et al. Fear of blindness in the Collaborative Initial Glaucoma Treatment Study: patterns and correlates over time. Ophthalmology. 2007;114(12):2213-20. [pmid: 17490746].
123 Hyman LG, Komaroff E, Heijl A, et al. Treatment and vision-related quality of life in the early manifest glaucoma trial. Ophthalmology. 2005;112(9):1505-13. [pmid: 16019074].
124 Schenker H, Maloney S, Liss C, et al. Patient preference, efficacy, and compliance with timolol maleate ophthalmic gel-forming solution versus timolol maleate ophthalmic solution in patients with ocular hypertension or open-angle glaucoma. Clin Ther. 1999;21(1):138-47. [pmid: 10090431].
125 Konstas AG, Kozobolis VP, Tersis I, et al. The efficacy and safety of the timolol/dorzolamide fixed combination vs latanoprost in exfoliation glaucoma. Eye (Lond). 2003;17(1):41-6. [pmid: 12579169].
126 Solish AM, DeLucca PT, Cassel DA, et al. Dorzolamide/Timolol fixed combination versus concomitant administration of brimonidine and timolol in patients with elevated intraocular pressure: a 3-month comparison of efficacy, tolerability, and patient-reported measures. J Glaucoma. 2004;13(2):149-57. [pmid: 15097262].
127 Javitt J, Goldberg I. Comparison of the clinical success rates and quality of life effects of brimonidine tartrate 0.2% and betaxolol 0.25% suspension in patients with open-angle glaucoma and ocular hypertension. Brimonidine Outcomes Study Group II. J Glaucoma. 2000;9(5):398-408. [pmid: 11039742].
128 Cantor LB, Hoop J, Katz LJ, et al. Comparison of the clinical success and quality-of-life impact of brimonidine 0.2% and betaxolol 0.25 % suspension in patients with elevated intraocular pressure. Clin Ther. 2001;23(7):1032-9. [pmid: 11519768].
129 Simmons ST, Earl ML. Three-month comparison of brimonidine and latanoprost as adjunctive therapy in glaucoma and ocular hypertension patients uncontrolled on beta-blockers: tolerance and peak intraocular pressure lowering. Ophthalmology. 2002;109(2):307-14. discussion 314–5. [pmid: 11825814].
130 Janz NK, Wren PA, Lichter PR, et al. The Collaborative Initial Glaucoma Treatment Study: interim quality of life findings after initial medical or surgical treatment of glaucoma. Ophthalmology. 2001;108(11):1954-65. [pmid: 11713062].
131 Montemayor F, Sibley LM, Courtright P, et al. Contribution of multiple glaucoma medications to visual function and quality of life in patients with glaucoma. Can J Ophthalmol. 2001;36(7):385-90. [pmid: 11794387].
132 Pointer JS. Evaluating the visual experience: visual acuity and the visual analogue scale. Ophthalmic Physiol Opt. 2003;6:547-52. [pmid: 14622359].
133 Courtright P, Poon CI, Richards JS, et al. Visual function among corneal disease patients waiting for penetrating keratoplasty in British Columbia. Ophthalmic Epidemiol. 1998;5(1):13-20. [pmid: 9575534].
134 Brooks R. EuroQol: the current state of play. Health Policy. 1996;37(1):53-72. [pmid: 10158943].
135 Nelson P, Aspinall P, O’Brien C. Patients’ perception of visual impairment in glaucoma: a pilot study. Br J Ophthalmol. 1999;83(5):546-52. [pmid: 10216052].
136 Viswanathan AC, McNaught AI, Poinoosawmy D, et al. Severity and stability of glaucoma: patient perception compared with objective measurement. Arch Ophthalmol. 1999;117(4):450-4. [pmid: 10206571].
137 Turano KA, Rubin GS, Quigley HA. Mobility performance in glaucoma. Invest Ophthalmol Vis Sci. 1999;40(12):2803-9. [pmid: 10549639].
138 Friedman DS, Freeman E, Munoz B, et al. Glaucoma and mobility performance: the Salisbury Eye Evaluation Project. Ophthalmology. 2007;114(12):2232-7. [pmid: 17980433].
139 Lamoureux EL, Chong E, Wang JJ, et al. Visual impairment, causes of vision loss, and falls: the singapore malay eye study. Invest Ophthalmol Vis Sci. 2008;49(2):528-33. [pmid: 18234995].
140 Bramley T, Peeples P, Walt JG, et al. Impact of vision loss on costs and outcomes in medicare beneficiaries with glaucoma. Arch Ophthalmol. 2008;126(6):849-56. [pmid: 18541852].
141 Gutierrez P, Wilson MR, Johnson C, et al. Influence of glaucomatous visual field loss on health-related quality of life. Arch Ophthalmol. 1997;115(6):777-84. [pmid: 9194730].
142 Parrish RK 2nd, Gedde SJ, Scott IU, et al. Visual function and quality of life among patients with glaucoma. Arch Ophthalmol. 1997;115(11):1447-55. [pmid: 9366678].
143 Freeman EE, Munoz B, West SK, et al. Glaucoma and quality of life: the Salisbury Eye Evaluation. Ophthalmology. 2008;115(2):233-8. [pmid: 17655930].
144 Altangerel U, Spaeth GL, Steinmann WC. Assessment of function related to vision (AFREV). Ophthalmic Epidemiol. 2006;13(1):67-80. [pmid: 16510349].
145 Glaucoma: Diagnosis and management of chronic open angle glaucoma and ocular hypertension. National Collaborating Centre for Acute Care. 2009.