# Peer Reviewers

Richard E. Gliklich, M.D.

Mount Sinai School of Medicine

New York, NY

Jeffrey Liebmann, M.D.

New York University School of Medicine Glaucoma Services

New York, NY

Flora Lum, M.D.

H. Dunbar Hoskins Center for Quality Eye Care

American Academy of Ophthalmology

San Francisco, CA