# Methods

## Topic Development

The Agency for Healthcare Quality and Research (AHRQ) requested that the Johns Hopkins University Evidence-based Practice Center (JHU EPC) assist with the formulation and refinement of the Comparative Effectiveness Review topic “Effectiveness of screening and treatment for glaucoma.”

In consultation with AHRQ, the JHU EPC identified a small group of stakeholders to serve as members of a Key Informant Group. The Key Informant Group helped shape the Key Questions (KQs) relevant to the topic by providing input regarding the populations and clinical subgroups, interventions, and outcomes of interest to clinicians, policy makers, payers, and consumers.

The JHU EPC investigators incorporated the feedback of the Key Informants into a draft of the KQs, analytic framework, and inclusion criteria which was posted to the AHRQ Web site for public comment from April 22 to May 20, 2010. KQs and Inclusion criteria were finalized after consideration of the public comments received.

A Technical Expert Panel was selected to provide broad expertise and perspectives specific to the topic under development. The Technical Expert Panel reviewed a protocol outlining a proposed methodological approach for the completion of the comparative effectiveness review, provided information to the JHU EPC to aid in the refinement of the inclusion criteria and literature search strategies and recommended approaches to specific issues as requested by the JHU EPC. The final protocol entitled Comparative Effectiveness of Treatment for Open-Angle Glaucoma was posted to the AHRQ Web site on November 16, 2010.

## Analytic Framework

The analytic framework (Figure 1) is a modified version of a larger framework depicting the impact of both screening and treatment for open-angle glaucoma (OAG). The figure focuses on the treatment portion of the framework and depicts the KQs within the context of the inclusion criteria. In general, the figure illustrates how treatment of open- angle glaucoma may reduce visual impairment (KQ 1) and/or improve patient-reported outcomes (KQ 2). It shows how treatment of open- angle glaucoma may reduce intraocular pressure (KQ 3) and/or prevent or slow the progression of optic nerve damage and visual field loss (KQ4). The framework also depicts a potential relationship between the intermediate outcomes of visual field loss and optic nerve damage and the final health outcomes of visual disability and quality of life (KQ 5). Finally, the potential harms of treatment (KQ 6) are included in the framework.

Figure 1 Analytic framework for treatment of open-angle glaucoma

KQ = Key Question; T = Key questions for the Comparative Effectiveness of Treatment for Glaucoma; S = Key questions for the Comparative Effectiveness of Screening for Glaucoma

This figure focuses on the treatment portion of the framework and depicts the Key Questions within the context of the inclusion criteria. In general, the figure depicts potential pathways by which treatment of open-angle glaucoma may reduce visual impairment (KQ1) and/or improve patient-reported outcomes (KQ2). It shows how treatment of open-angle glaucoma may reduce intraocular pressure (KQ3) and/or prevent or slow the progression of optic nerve damage and visual field loss (KQ4). The framework also depicts a potential relationship between the intermediate outcomes of visual field loss and optic nerve damage and the final health outcomes of visual disability and quality of life (KQ5). Finally, the potential harms that may result from treatment (KQ6) are included in the framework. This figure also shows the screening aspects of the framework. In general, the figure illustrates how screening-based programs (which may incorporate treatment when indicated) may reduce visual impairment (KQ1) and/or improve patient reported outcomes (KQ2), reduce intraocular pressure (KQ4) and possibly slow the progression of optic nerve damage and/or visual field loss (KQ5). The figure also illustrates the potential predictive value of candidate screening tests to detect open-angle glaucoma and open angle glaucoma suspects (KQ3). The potential harms of screening (KQ6) are also illustrated in the framework.

## Study Selection

### Types of Studies

We included randomized controlled trials (RCTs) and “quasi-randomized” controlled trials of medical, laser, and incisional surgical treatments for OAG for inclusion as primary studies for KQs 1, 2, 3, and 4. We included observational study designs, cohort and case control studies, in addition to randomized and “quasi-randomized” controlled trials for KQs 5 and 6.

We also included systematic reviews that address the KQs as described in Data Synthesis.

### Types of Participants

We included studies of participants with primary or secondary chronic OAG or OAG suspects aged 40 years and older (specific exclusions are listed below). These types of glaucoma may also be described in the literature as the following conditions:

- Ocular hypertension
- Low tension or normal tension glaucoma
- Pseudoexfoliative glaucoma/pseudoexfoliation syndrome
- Pigmentary glaucoma
- Steroid-responsive glaucoma

We specifically excluded the following conditions: juvenile/congenital glaucoma, traumatic glaucoma, neovascular glaucoma, refractory glaucoma, and inflammatory glaucoma as well as all types of angle closure.

We considered studies that enrolled participants diagnosed with included and excluded glaucoma types (as described above) if the investigators conducted analyses of included subgroups and if we were able to abstract data for the included glaucoma types only.

We included studies in which at least 95 percent of the participants are aged 40 and older or those in which the mean age is greater than 50 years. If the age was not specified, the study was excluded.

There were no limitations based on stage or severity of disease, disease etiology, comorbid ocular or other medical conditions, geographic location, or demographic characteristics, (e.g., gender, race/ethnicity).

### Types of Interventions

We included studies of medical (eye drops and systemic treatment), laser, and incisional surgery treatments for OAG.

#### Medical Treatments

We considered studies of the following agents for this review:

- Prostaglandin analogs
  ○ Bimatoprost
  ○ Latanoprost
  ○ Travoprost
- Beta adrenergic antagonists
  ○ Timolol
  ○ Levobunolol
  ○ Betaxolol
  ○ Carteolol
- Topical and oral carbonic anhydrase inhibitors
  ○ Acetazolamide
  ○ Brinzolamide
  ○ Dorzolamide
- Alpha2 adrenergic agonists
  ○ Brimonidine
- Combination medical treatments
  ○ Dorzolamide plus timolol
  ○ Brimonidone plus timolol

We included preparations of the above-mentioned agents by trade, or generic/chemical name. The complete list is in Appendix E.

We included studies of the impact of medical intervention on diurnal intraocular pressure if outcomes were assessed over a 24-hour period and participants were admitted to a hospital, sleep laboratory, or other facility overnight.

We excluded from this review studies of the following medical interventions that are no longer commonly used to treat glaucoma:

- Pilocarpine
- Apraclonidine
- Epinephrine
- Unoprostone
- Dipivaphrin
- Ocusert
- Iopidine
- Metipranolol
- Systemic β-blockers

We also excluded treatments that were not approved by the Food and Drug Administration (i.e., experimental treatments).

#### Laser and Incisional Surgical Treatments

We considered for this review studies of the following laser and incisional surgical treatments as well as use of devices that are designed to increase aqueous outflow.

##### Office-Based Laser Treatments

- Argon and selective laser trabeculoplasty (SLT)

##### Surgical Procedures

- Trabeculectomy
- Aqueous drainage devices
  ○ Baerveldt implant
  ○ Ahmed implant
  ○ Krupin implant
  ○ Molteno implant
- Cyclophotocoagulation – trans-scleral and endoscopic
- Deep sclerectomy
- Viscocanalostomy

##### Specialized Surgical Devices

- iScience microcatheter (canaloplasty)
- Trabectome (modified trabeculotomy)
- ExPRESS shunt (modified trabeculectomy)
- Glaukos iStent (trabecular bypass)
- SOLX™ gold shunt (trabecular bypass)

##### Definitions of Surgical Treatments

Laser trabeculoplasty: Laser energy (argon, YAG, diode) is applied to the trabecular meshwork in an effort to reduce the resistance to outflow for aqueous humor. The procedure is performed as part of an office visit and requires topical anesthesia and a mirrored contact lens.
Trabeculectomy: The most commonly performed incisional surgery for lowering intraocular pressure in glaucoma patients. Under local anesthesia, a passageway is created at the limbus (junction between the cornea and sclera) that allows the aqueous humor to flow from the anterior chamber to the space between the sclera and the conjunctiva, thereby lowering the intraocular pressure. The hallmark of a trabeculectomy is the fluid-filled bleb (blister) present on the surface of the eye underneath the upper eyelid.
Trabeculotomy: An incisional surgery procedure generally used to lower intraocular pressure in glaucoma affecting infants and children. A metal probe or a suture is passed into Schlemm’s canal, a structure into which aqueous humor passes as it exits the eye. The probe is used to disrupt tissue that is typically impeding outflow of aqueous from the eye, thereby increasing outflow and decreasing the intraocular pressure. Some surgeons also use trabeculotomy in the treatment of glaucoma in adults.
Aqueous drainage devices: Any of a number of plastic implants used in the surgical management of glaucoma, with the aim of lowering the intraocular pressure. All devices consist of a tube that is inserted into the eye, and a plate connected to the tube that is sewn to the sclera and covered by conjunctiva. Aqueous humor moves through the tube and out of the eye to drain on top of the plate into the space between the plate and the conjunctiva.
Cyclophotocoagulation: A procedure in which laser energy is used to damage the ciliary processes, reducing the amount of aqueous humor that they produce, and thereby lowering the intraocular pressure. The procedure can be performed through the sclera (external cyclophotocoagulation) or from the inside of the eye (endocyclophotocoagulation).
Deep sclerectomy: In this procedure the surgeon makes an opening in the conjunctiva to expose the sclera. The surgeon dissects a partial thickness flap of about 5 mm in width to about one third depth in the sclera at the limbus. A second flap is dissected below this flap in order to leave a very thin layer of tissue and to expose Schlemm’s canal. This underlying flap of scleral tissue is removed and the surgeon grasps the roof of Schlemm’s canal and removes a strip that is about 3 mm in length. Aqueous humor is able to permeate the remaining tissue without a full thickness hole being necessary. The external flap is then sutured down in its original position and the conjunctiva is sewn back in place.
Viscocanalostomy: The surgical procedure is the same as for deep sclerectomy (see above). In addition, viscoelastic is injected into Schlemm’s canal in a circumferential fashion in an effort to dilate Schlemm’s canal. The external flap is then sutured down in its original position and the conjunctiva is sewn back in place.
Canaloplasty: First a combined deep sclerectomy and visocanalostomy procedure is performed (see above). Following this a microcathater with an illuminated tip is passed through Schlemm’s canal for 360 degrees. A 10-0 Prolene suture is tied to the catheter and threaded around Schlemm’s canal for 360 degrees. The two ends of this suture are tied under tension in an effort to expand Schlemm’s canal. The external flap is then sutured down in its original position and the conjunctiva is put back in place.
Trabectome: The surgeon makes a 1.7 mm incision through the peripheral cornea and injects viscoelastic into the anterior chamber. The Trabectome device is then introduced into the anterior chamber and under visualization using direct gonioscopy with an operating microscope the Trabectome is used to ablate about one quadrant of trabecular tissue. The Trabectome uses low energy electrical pulses to vaporize the trabecular tissue and aspiration is used to remove it. The viscoelastic is removed and the corneal wound is sutured closed.
iStent: The Glaukos Trabecular Micro-Bypass Stent (iStent) is placed into Schlemm’s canal. It is made of nonferromagnetic titanium. One end sits in the anterior chamber and the posterior end sits in Schlemm’s canal allowing fluid to bypass the trabecular meshwork. The device is inserted under direct visualization (using direct gonioscopy) through a 3 mm temporal clear corneal incision. After placing viscoelastic in the anterior chamber, the applicator is passed through the incision and the device is anchored into Schlemm’s canal in the nasal angle. Viscoelastic is removed with irrigation and aspiration.
Gold shunt: The SOLX™ Gold Shunt is a 24-karat gold rectangle (3.2 × 5.2 mm) that connects the anterior chamber to the suprachoroidal space. There are two plates with grooves in them to allow flow from the higher-pressure anterior chamber to the lower pressure suprachoroidal space. The conjunctiva is disinserted at the limbus and a full thickness scleral incision is created 2 mm posterior to the limbus. A crescent blade is used at 90% scleral depth to direct the anterior portion of the shunt to the anterior chamber and to cut posteriorly 2 to 3 mm to direct the posterior segment into the suprachoroidal space. The scleral incision is closed with 10-0 nylon sutures, and the conjunctiva is closed.

#### Surgical Treatment of Coexisting Cataract and Glaucoma

We included studies of combined cataract and glaucoma surgical procedures published after April 2000. Studies published prior to this period are summarized in the AHRQ report titled Surgical Treatment of Coexisting Cataract and Glaucoma.7 We excluded from this review studies of the following surgical interventions or surgery-related conditions or complications:

- Cataract surgery alone among participants with glaucoma
- Treatment of surgical complications
- Intraocular pressure variations after surgery and treatment of IOP after surgery
- Intraocular pressure fluctuation after surgery
- Variations in anesthesia
- Assessment or treatment of filtering blebs alone (bleb survival, revision of blebs, comparisons of blebs, bleb failure)

### Comparators

KQs 1, 2, 3, 4, and 6 explored comparisons of medical, laser, and incisional surgical treatments for OAG to each other (e.g., medical versus laser, medical versus medical) or to no treatment. For KQs 1, 2, 3, 4, and 6, we also included studies in which the intervention is a laser or incisional surgical treatment for glaucoma but the comparator is a combined or staged procedure for cataract and glaucoma (glaucoma surgical treatments combined or staged with phacoemulsification or extra capsular cataract extraction).

### Outcomes

#### Key Question 1

##### Primary Outcome

The proportion of participants with moderate, severe, and profound visual impairment as defined in the International Classification of Diseases, Clinical Modification, 9th Revision (ICD-9). 8 The ICD-9 criteria define moderate visual impairment as best corrected visual acuity of between 20/70 and 20/160, severe visual impairment as acuity between 20/200 and 20/400 or a visual field of 20 degrees or less, and profound visual impairment as an acuity of 20/500 to 20/1000 or no more than 10 degrees of visual field. We also considered other measurements of visual impairment as defined by included studies.

##### Secondary Outcome

We included visual acuity outcomes among the treatment groups of interest (Early Treatment of Diabetic Retinopathy Study or Snellen) as reported in included studies (e.g., mean visual acuity or proportion of participants in pre-specified visual acuity categories).

#### Key Question 2

We considered participants’ mean total or relevant item/subscale scores as measured by any validated questionnaire, e.g., National Eye Institute Visual Function Questionnaire (NEI-VFQ), for the following patient-reported outcomes among the treatment groups of interest:

##### Primary Outcome

Vision-related quality of life (vision-related functional loss as well as the impact of functional loss on activities of daily living)

##### Secondary Outcomes

- Treatment convenience
- Patient satisfaction
- Patient preference values or utility values
- Adherence to medical treatment

#### Key Question 3

##### Primary Outcome

We included the proportion of participants with intraocular pressure measurements at pre-specified levels as outlined below among the treatment groups of interest. Since the analysis of intraocular pressure varies appreciably by trial, we considered other intraocular pressure outcomes as reported in included studies.

- Intraocular pressure ≤ 18 mmHg
- ≥ 20% decrease in intraocular pressure from baseline levels

#### Key Question 4

##### Primary Outcomes

- The proportion of participants with progressive optic nerve damage as defined by included studies and as observed via fundus photography or other imaging of the posterior pole.
- The proportion of participants with progression of visual field loss as defined by the Early Manifest Glaucoma Trial and as measured via automated threshold perimetry.5 We also considered other assessments of visual field loss as defined by included studies.

#### Key Question 5

Key Question 5 explores the association of (1) lowering intraocular pressure or (2) preventing or slowing the progression of (a) optic nerve damage and (b) visual field loss (intermediate outcomes of treatment) and final health outcomes (reduced visual impairment and improved vision-related quality of life) among the populations of interest. The outcomes were as described above in Outcomes for Key Questions 1, 2, 3, and 4.

#### Key Question 6

We compared the proportion of participants experiencing the following adverse events among the treatment groups of interest:

Potentially serious:

- Cataract formation (visually significant cataract requiring surgery or report of cataract surgery)
- Low intraocular pressure (hypotony)
- Decreased visual acuity
- Infection (e.g., blebitis, endophthalmitis)
- Inflammation
- Strabismus
- Peripheral anterior synechiae
- Retinal tear and detachment
- Systemic allergic reaction
- Loss of an eye
- Need for additional surgery
- Hyphema
- Transient decrease in central vision
- Systemic side effects
- Choroidal (detachment, effusion, hemorrhage)
- Cardiac arrhythmia
- Death

Less likely to be serious:

- Eye irritation
- Eye watering
- Eye redness
- Patient discomfort
- Ocular surface disease
- Other patient complaint
- Skin discoloration
- Conjunctival injection
- Iris color change
- Punctal stenosis
- Conjunctival foreshortening

We also included other harms as reported in included studies.

### Timing of Outcomes

#### Medical Treatments

We assessed medical treatment outcomes at a minimum of one month post intervention. We included outcomes reported at 6 months (2–9 months) and one year (10–18 months) as reported in included studies. The exception was circadian medical treatment studies in which the investigators report outcomes assessed over a twenty-four hour period.

#### Surgical Treatments

We assessed outcomes at a minimum of one year (10–18 months) and at annual intervals thereafter as reported in included studies.

### Setting

Eye care provider clinical settings only (ophthalmologists and optometrists)

### Search Strategy

We searched the following databases for primary studies: MEDLINE, Embase, LILACS (Latin American and Caribbean Literature on Health Sciences) and CENTRAL (the Cochrane Central Register of Controlled Trials). We developed a search strategy for MEDLINE, accessed via PubMed, based on an analysis of the medical subject heading (MeSH) terms and text words of key articles identified a priori and adapted this search strategy for searches of Embase (using EMTREE terms) and CENTRAL (Appendix A). We searched the literature without imposed language, sample size or date restrictions, but excluded non-English language studies at the time of full text review. We searched relevant systematic reviews to identify any additional eligible articles. The databases were last searched on October 6, 2011.

We also conducted a search in MEDLINE and CENTRAL for systematic reviews that address the KQs of interest. For MEDLINE, the search included the topic strategy, as noted above, combined with the term “AND systematic[sb]” and was limited to systematic reviews published from 2009 to 2011. The search for systematic reviews was conducted on March 2, 2011. We screened an existing database of eye and vision systematic reviews to identify relevant OAG systematic reviews published prior to 2009.^6^

### Abstract Screening

We screened potentially relevant citations (primary studies and systematic reviews) using the Web-based systematic review software, DistillerSR (http://systematic-review.net/). Citations identified by the search strategies were uploaded to DistillerSR and managed in the following manner: Two reviewers independently assessed titles and abstracts resulting from the literature searches according to the inclusion criteria. We classified the titles and abstracts as “include,” “exclude” or “unsure.” Disagreements about eligibility were resolved through discussion among reviewers. A copy of the abstract review form is included in Appendix B.

### Full-Text Screening

Citations tagged as “unsure” by both reviewers, “unsure” by one reviewer and “include” by the other, or “include” by both reviewers, were promoted to full-text screening. Two reviewers independently applied the same inclusion criteria as used during abstract screening. Non-English language articles were also removed from further consideration at this stage. We resolved any disagreements regarding inclusion through discussion or, as needed, during a team meeting.

### Data Abstraction

Data abstraction forms were designed and pilot tested. One reviewer extracted descriptions of the study, including details about the population, intervention(s) and outcomes of interest, using the systematic review software, DistillerSR. A second reviewer verified the data. We resolved disagreements through discussion.

### Risk-of-Bias Assessment

We used the Cochrane Collaboration’s tool for assessing the risk of bias of randomized and quasi RCTs.10 Two reviewers assessed the included studies for sources of systematic bias according to the guidelines in Chapter 8 of the Cochrane Handbook for Systematic Reviews of Interventions using the following criteria: sequence generation and allocation concealment (selection bias), masking of participants, study investigators, and outcome assessors (detection bias), incomplete outcome data (attrition bias), selective outcome reporting (reporting bias), and other sources of bias. Masking of investigators and participants might not have be possible with some of the interventions being examined, but was noted when mentioned. We reported judgments for each criterion as “Low risk of bias,” “High risk of bias” or “Unclear risk of bias (information is insufficient to assess).” The two reviewers resolved disagreements through discussion.

Two reviewers assessed the methodological rigor of observational studies using a modified version of the Newcastle Ottawa Scale.11 The Newcastle Ottawa Scale includes domains to assess the quality of study group selection (representativeness, selection, case definitions), comparability of cohorts/cases, and controls. On the basis of the design or analysis, and ascertainment of exposure(s) or outcome(s) adequacy of follow-up, non-response rate and financial or other conflicts of interest. Each item query required a yes, no, or unable to determine/not reported response. In addition, reviewers provided an overall assessment of the quality of each study as “good” “fair” or “poor” using the reporting bias, selection bias, and confounding domains as a basis for the assessment.

We used a tool adapted by Li (2010) from the Critical Appraisal Skills Program, Assessment of Multiple Systematic Reviews; and the Preferred Reporting Items for Systematic Reviews and Meta-analyses statement, to assess the methodological quality of systematic reviews.6 We used the following criteria, adapted from Li, to determine which systematic reviews were of sufficient quality to be considered for inclusion in this review: comprehensive search for primary studies (searches of more than one bibliographic database); risk of bias assessment; and appropriate analysis methods (no pooled arm analysis).

## Rating Body of Evidence

We assessed the quantity, quality and consistency of the body of available primary study evidence addressing KQs 1 through 6. We used an evidence grading scheme recommended by the GRADE Working Group, adapted by AHRQ in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews (http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=328) and recently published in the Journal of Clinical Epidemiology.12 13

Although we included systematic reviews that addressed our KQs and consider systematic reviews as the highest level of evidence for addressing questions of therapy, we were unable to adapt the grading scheme to include systematic reviews as the evidence grading scheme is designed to assess the body of evidence derived from individual studies and is less amenable assessment of the evidence from one or more systematic reviews incorporated into a more complex review.

We assessed the quality and consistency of the best available primary study evidence, including assessment of the risk of bias in relevant studies, as well as aspects of consistency, directness, and precision as described in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews and by Owens (2010).12 13 For each outcome of interest, two reviewers graded the major outcomes for each of the KQs and, if needed, discussed their recommendations and reached consensus.

## Data Synthesis

When we identified existing high-quality systematic reviews that addressed the KQs, we cited these reviews as evidence and did not abstract and synthesize data from primary studies. We abstracted and synthesized data from primary studies that addressed interventions, comparisons, and outcomes that were not identified in systematic reviews, and those studies that had been published or identified after the date of last search conducted for the systematic review. We adapted the recommendations of Whitlock (2008) for incorporating systematic reviews in complex reviews and provided a narrative summary of the review methods (i.e., inclusion/exclusion criteria, search strategy, statistical methodology) and findings (i.e., number of studies included, quantitative and qualitative results). Similarly, in the instance of multiple reviews, we evaluated the consistency across reviews addressing the same key question.14

The plan for the analysis of primary studies, including the assessments of heterogeneity, reporting bias, measures of treatment effect, data synthesis, and subgroup analysis was included in the protocol for this review.