# Introduction

The Agency for Healthcare Research and Quality Effective Health Care Program requested a comparative effectiveness review of various treatment options for glaucoma. The topic was selected through the Effective Health Care Program nomination process and from a review of the scientific medical literature.

## Background

Glaucoma is a leading cause of visual impairment and blindness both in the United States and worldwide. It is estimated to affect 60.5 million people worldwide.1 Glaucoma is defined as an acquired disease of the optic nerve (neuropathy), characterized by a particular appearance of the optic nerve and by visual field defects that are usually midperipheral and in the nasal visual field. Depending upon whether the optic nerve damage is associated with an open or closed appearance to the drainage channels for aqueous humor in the front of the eye, the glaucoma is referred to as open angle (the subject of this report) or closed-angle.

Mild glaucoma damage to the optic nerve may be asymptomatic, but as the damage worsens, the patient begins to have difficulty with peripheral vision, contrast sensitivity, glare, and adjusting from light to dark and dark to light – symptoms that eventually affect day to day function and quality of life. In its most severe form, glaucoma results in total, irreversible blindness.

Although deficient blood supply to the optic nerve, inadequate structural support for the neurons that make up the optic nerve, and insufficient supplies of neurotrophins needed to maintain the health of the optic nerve have been hypothesized as risk factors for glaucoma, experimental models and other evidence from human participants have shown that elevated intraocular pressure (IOP) results in damage to the optic nerve in a pattern characteristic of glaucoma.2 Furthermore, studies have demonstrated correlations between the level of IOP and the risk of having glaucoma as well as the worsening of glaucoma once present. Other studies have demonstrated that lowering IOP reduces both the incidence of glaucoma in individuals who do not have glaucoma damage but are at high risk for its development, and the rate of progression of glaucoma in individuals with established glaucoma.3–5 Therefore, the treatments for glaucoma today all focus on the reduction of IOP, which secondarily prevents the worsening of visual field loss and may therefore prevent visual impairment and blindness.

## Treatments for Open-Angle Glaucoma

Medical, laser, and incisional surgical treatments are all used to treat glaucoma. The most commonly used medical treatment includes several classes of eye drops, such as prostaglandin analogs, beta-adrenergic antagonists, carbonic anhydrase inhibitors, and alpha-adrenergic agonists, as well as systemic carbonic anhydrase inhibitors. Laser trabeculoplasty is an office procedure that lowers IOP by increasing the outflow of aqueous humor from the eye. Incisional surgery to lower IOP includes procedures that have been performed for decades, such as trabeculectomy and aqueous drainage device surgery, as well as a host of newer procedures, such as non-penetrating deep sclerectomy, canaloplasty, endoscopic cyclophotocoagulation, and alternative methods of trabecular bypass.

## Rationale for a Comparative Effectiveness Review

Although there is high-level evidence from randomized controlled trials (RCTs) of medical and laser therapy versus observation in patients with early glaucoma, initial medical therapy compared to initial surgical therapy in patients with established glaucoma, and laser therapy versus surgical therapy in participants not controlled with medical therapy, are addressed only by single RCTs that also do not, in most cases, include novel medical and surgical treatments.5,16,17

Given developments in the treatment of glaucoma, including the realization of the importance of adherence to medical therapy, and the introduction of new surgical modalities, it is appropriate to update the evidence on the safety and effectiveness of glaucoma treatments.

## Purpose of Evidence Report

The objective of this comparative effectiveness review is to summarize the evidence regarding the safety and effectiveness of medical, laser, and other surgical treatments for open-angle glaucoma (OAG) in adults.

## Key Questions

Key Question 1. Do medical, laser, and other surgical treatments for OAG reduce visual impairment?

- Key Question 1a: What is the comparative effectiveness of medical treatments for reducing visual impairment?
- Key Question 1b: What is the comparative effectiveness of laser and other surgical treatments for reducing visual impairment?
- Key Question 1c: What is the comparative effectiveness of medical versus surgical treatment for reducing visual impairment?

Key Question 2. Does treatment of OAG improve patient-reported outcomes?

Key Question 3. Do medical, laser, and other surgical treatments for OAG lower intraocular pressure?

- Key Question 3a: What is the comparative effectiveness of medical treatments for lowering intraocular pressure?
- Key Question 3b: What is the comparative effectiveness of laser and other surgical treatments for lowering intraocular pressure?
- Key Question 3c: What is the comparative effectiveness of medical versus surgical treatment for lowering intraocular pressure?

Key Question 4. Do medical, laser, and other surgical treatments for OAG prevent or slow the progression of optic nerve damage and visual field loss?

- Key Question 4a: What is the comparative effectiveness of medical treatments for preventing or slowing the progression of optic nerve damage and visual field loss?
- Key Question 4b: What is the comparative effectiveness of laser and other surgical treatments for preventing or slowing the progression of optic nerve damage and visual field loss?
- Key Question 4c: What is the comparative effectiveness of medical versus surgical treatment for preventing or slowing the progression of optic nerve damage and visual field loss?

Key Question 5. Does lowering intraocular pressure or preventing or slowing the progression of optic nerve damage and visual field loss reduce visual impairment and change vision-related quality of life?

Key Question 6. What are the harms associated with medical, laser, and other surgical treatments for OAG?

- Key Question 6a: What are the harms associated with medical treatments for OAG?
- Key Question 6b: What are the harms associated with laser and other surgical treatments for OAG?
- Key Question 6c: What harms are reported in studies of medical versus surgical treatments for OAG?