# Discussion

In the analytic framework we developed to structure this work, the ultimate outcome of treating open-angle glaucoma (OAG) is the prevention of visual impairment and the maintenance or improvement of patient-reported outcomes like quality of life. Key Questions (KQs) 1 and 2 directly evaluate these outcomes. Recognizing that studying these final outcomes of glaucoma treatment directly requires large studies of long duration, we also included in the analytic framework the intermediate outcomes of intraocular pressure (IOP), rate of visual field loss, and rate of optic nerve damage as each of these outcomes is very likely linked to the final outcome of visual impairment. KQs 3 and 4 address the link between treatment and these intermediate outcomes. In an effort to gather all evidence linking treatment to changes in visual impairment and quality of life, Key Question 5 was included to assess the link between the intermediate outcomes reported by most glaucoma trials (IOP, visual field, optic nerve) and the ultimate outcomes of visual impairment and self-reported declines in quality of life.

Because glaucoma can be treated both medically and surgically, our evaluation was further structured to compare medications to other medications, medications to surgeries, and surgeries to other surgeries. This was done because it made the most sense from a clinical perspective. The key questions were therefore each evaluated within each of these three categories.

We identified no studies that evaluated either medical or surgical glaucoma treatments with regard to their impact on visual impairment (KQ 1). Our methods were designed to use standard definitions of visual impairment based on visual acuity and visual field loss, but even alternative definitions of visual impairment did appear in any appropriate studies. Glaucoma is a slowly progressive disease and recent publications indicate that the average untreated glaucoma patient would require more than 20 years to lose most of his/her visual field.9 Most clinical trials cannot enroll a large enough number of subjects and follow them long enough to detect a difference in the proportion progressing to severe vision loss. A small number of studies provided data on visual acuity or visual field outcomes that might have been used to evaluate this question, but either the data reported were not adequate to determine rates of visual disability or the studies were of too short a duration to ascertain relative differences in glaucoma progression.

We also found the evidence linking treatment with relative changes in patient-reported outcomes (KQ 2) to be insufficient. There is some evidence that patients prefer less frequent dosing of medications and there is evidence that treatment of any kind reduces the fear of blindness compared to after diagnosis, but we found nothing linking treatment to more important outcomes like vision-related quality of life.

As mentioned above, we attempted to find an indirect link from treatment to the final outcomes via KQ 5. Again, no studies were found that adequately evaluated the link between any of the intermediate outcomes and the final outcomes in the analytic framework.

Taking KQs 1, 2, and 5 together, we therefore did not find evidence for direct or indirect links between treatment of glaucoma and the prevention of visual impairment or changes in patient-reported outcomes. As noted above, since glaucoma is a slowly progressive disease (even if untreated), it is not surprising that no studies of these links were identified. The required duration of such studies would present significant challenges, primarily in terms of the followup of the subjects for a long enough period of time to ascertain relative differences in the outcomes.

In contrast to the lack of evidence for KQs 1, 2, and 5, the past decade has seen significant progress in terms of information related to the intermediate outcomes of IOP (KQ 3) and changes in visual field and optic nerve (KQ 4). With regard to IOP, there is moderate evidence that a number of treatments can significantly lower IOP relative to no treatment.

Medical therapy for glaucoma has been available for over a century and there is moderate evidence that all of the currently used medications lower IOP. Among medications, the prostaglandin agents are consistently superior to the other classes in terms of their pressure lowering ability. Specifically, latanoprost has been shown to be superior to timolol, brimonidine, and dorzolamide. This result is consistent with the NICE guidelines from 2009 regarding glaucoma medications.145 It is also now clear from large clinical trials (Collaborative Normal-Tension Glaucoma Study, Early Manifest Glaucoma Trial, and Ocular Hypertension Treatment Study) that treatment with medications decreases the risk of visual field loss or optic nerve damage. The reduction in the risk of visual field loss or optic nerve damage was close to 50% in these major trials. The topical medications included in this review have been shown to be superior to placebo with regard to visual field loss and/or optic nerve damage, but there is not adequate evidence to suggest the superiority of one medication over another in terms of these same outcomes.

Laser trabeculoplasty has also been shown to decrease IOP in OAG. Although multiple types of laser are currently in use, there is no evidence to support the use of one technology over another. Specifically, our results, similar to the conclusions provided in the National Institute for Health and Clinical Excellence glaucoma guidelines,145 support the equivalence of argon laser trabeculoplasty and SLT. Furthermore, laser trabeculoplasty and topical medications have similar ability to prevent visual field loss due to glaucoma.

As with medications and laser, incisional surgeries lower IOP. In terms of relative effect, trabeculectomy lowers pressure more than non-penetrating procedures like viscocanalostomy and deep sclerectomy. There is also moderate evidence that trabeculectomy with the antimetabolite mitomycin-C lowers pressure more than the same procedure without mitomycin-C. Interestingly, there is no evidence to support a reduction in IOP when mitomycin-C is used with the non-penetrating procedures. Although many variations on the basic trabeculectomy have been evaluated, including differences in technique and in adjuvants, there is insufficient evidence that any of them provides additional reduction in IOP.

Based on the evidence we analyzed, it is likely that trabeculectomy is superior to medications in terms of preventing visual field loss. Taken together, the current best evidence supports the contention that medication and laser trabeculoplasty have similar efficacy but that trabeculectomy is superior to both with respect to the intermediate outcomes addressed by KQs 3 and 4.

There is, of course, a downside to any treatment in the form of side effects and complications. In general, the harms produced by medications are not vision threatening and most commonly include signs and symptoms like conjunctival hyperemia and ocular irritation. There is evidence that the prostaglandin agents are more likely to cause conjunctival hyperemia than are the other classes of medication, and that latanoprost is the least likely to cause this of the three prostaglandins that have been most widely used and studied (latanoprost, bimatoprost and travoprost). On the other hand, timolol is more likely to result in systemic side effects like shortness of breath or bradycardia, though these are rarely severe.

As expected, the complications of surgery are more significant compared to those of medications, and they include cataract formation, choroidal effusions, hyphema, and flattening of the anterior chamber. If these complications are severe, they can result in vision loss. Among surgical treatments, these complications are more common in trabeculectomy than in non-penetrating surgeries and are likely more common in trabeculectomies done with mitomycin-C than in those performed without it.

The fact that the treatment that is most likely to lower IOP and prevent visual field and optic nerve progression (trabeculectomy) is also the one with the most significant side effects is a challenge to clinical decision making. When deciding from among medications, laser, and incisional surgery, a clinician would ideally perform some sort of patient-specific risk-benefit analysis to determine which intervention is most appropriate, given the risk of progression. Even if this were something clinicians were good at, the fact is that there are no good studies that clearly quantify the relative risks and benefits of various treatments to inform such an analysis.

In conclusion, we did not find direct or indirect links between glaucoma treatment and visual impairment or patient-reported outcomes. This should be an area of focus in future glaucoma trials, but trials would need to be of adequate size and duration to detect differences between groups. We did find, however, that a number of current medical and surgical treatments clearly lower IOP and can prevent visual field loss and optic nerve damage. While we found direct comparisons between some treatments, the remaining gaps noted above also represent an area in which future research could be directed.