# Included Devices and Medications

Glaucoma Medications: FDA Approval Status

Pharmacologic category | Generic Name | US Brand Name | FDA Status | Approval Date | Marketing Status
Non-selective beta-adrenergic receptor blocker | Timolol | Betimol® | Approved - NDA 020439 | 3/31/1995 | Prescription
| | Istalol® | Approved - NDA 021516 | 06/04/2004 | Prescription
| | Timoptic® | Approved - NDA 018086 | 8/17/1978 | Prescription
| | Timoptic-XE® | Approved - NDA 020330 | 11/4/1993 | Prescription
| | Timoptic OcuDose® | Approved - NDA 019463 | 11/5/1986 | Prescription
| | Timolol GFS | Approved
| Levobunolol | Betagan® | Approved - NDA 019219 | 12/19/1985 | Prescription
| Metipranolol | OptiPranolol | Approved - NDA 019907 | 12/29/1989 | Prescription
Beta 1 selective beta blocker | Betaxolol | Betoptic | Approved - NDA 019270 | 8/30/1985 | Prescription
Alpha2 Agonist | Apraclonidine | Iopidine® | Approved - NDA 019779 | 12/31/1987 | Prescription
| Brimonidine | Alphagan® | Approved - NDA 020490 | 3/13/1997 | Discontinued
| | Alphagan P® | Approved - NDA 021262 | 3/16/2001 | Prescription
Carbonic Anhydrase Inhibitor | Brinzolamide | Azopt® | Approved - NDA 020816 | 4/1/1998 | Prescription
| Acetazolamide | Diamox® | Approved - NDA 012945 | | Prescription
| | Sequels®
| Dorzolamide | Trusopt® | Approved - NDA 020408 | 12/9/1994 | Prescription
Cholinergic | Carbachol | Isopto® Carbachol | Approved | | Discontinued
| | Miostat® | Approved - NDA 016968 | 9/28/1972 | Prescription
Prostaglandin Analogs | Travoprost | Travatan® | Approved - NDA 021257 | 3/16/2001 | Prescription
| | Travatan® Z | Approved - NDA 021994 | 9/21/2006 | Prescription
| Bimatoprost | Lumigan® | Approved - NDA 021275 | 3/16/2001 | Prescription
| | Latisse TM | Approved - NDA 022369 | 12/24/2008 | Prescription
| Latanoprost | Xalatan® | Approved - NDA 020597 | 6/5/1996 | Prescription
Combined | Dorzolamide and timolol | Cosopt® | Approved - NDA 020869 | 4/7/1998 | Prescription
| | Preservative-free Cosopt®
| Brimonidine and timolol | Combigan® | Approved - NDA 021398 | 10/30/2007 | Prescription
| Brinzolamide and Timolol | Azarga® | Not Approved
| Travoprost and Timolol | DuoTrav® | Not Approved
| Bimatoprost and Timolol | Ganfort® | Not Approved

Glaucoma Medications: Generic and Trade Names

Pharmacologic category | Generic Name | US Brand Name | Canadian Brand Name | Mexican Brand name | European Brand Names
non-selective beta-adrenergic receptor blocker | Timolol | Betimol® | Apo-Timol® | Globitan | Timabak
| | Istalol® | Gen-Timolol | Horex
| | Timoptic® | Nu-Timolol | Imot Ofteno
| | Timoptic-XE® | Phoxal-timolol | Nyolol
| | Timoptic OcuDose® | PMS-Timolol | Shemol
| | Timolol GFS | Tim-AK | Timoptol
| | | Timoptic® | Timozzard
| | | Timoptic-XE®
| | | Alti-Timolol
| | | Apo-Timop®
| | | Mylan-Timolol
| | | Sandoz-Timolol
| Levobunolol | Betagan® | Apo-Levobunolol® | Betagan | Vistagan
| | | Betagan® | | Vistagan-Liquifilm
| | | Novo-Levobunolol
| | | Optho-Bunolol®
| | | PMS-Levobunolol
| | | Sandoz-Levobunolol
| Metipranolol | OptiPranolol | OptiPranolol | | Turoptin
| | | | | Normoglaucon
| | | | | Minims metipranolol
| | | | | Betacarpin augentropfen
| | | | | Betamann
| | | | | Betaophtiole
Beta 1 selective beta blocker | Betaxolol | Betoptic | Betoptic S | Betoptic S | Oxodal
| | | Sandoz-Betaxolol
Alpha2 Agonist | Apraclonidine | Iopidine® | Iopidine®
| Brimonidine | Alphagan® | Alphagan® | Agglad Ofteno
| | | Apo-Brimonidine P® | Alphagan
| | | Apo-Brimonidine® | Nor-Tenz
| | | PMS-Brimonidine Tartrate
| | | ratio-Brimonidine
| | | Sandoz-Brimonidine
Carbonic Anhydrase Inhibitor | Brinzolamide | Azopt® | Azopt® | Azopt
| Acetazolamide | Diamox® | Apo-Acetazolamide® | Acetadiazol
| | Sequels® | Diamox®
| Dorzolamide | Trusopt® | Trusopt® | Trusopt
Cholinergic | Carbachol | Isopto® Carbachol | Isopto® Carbachol
| | Miostat® | Miostat®
Prostaglandin Analogs | Travoprost | Travatan® | Travatan® | Travatan
| | Travatan® Z | Travatan® Z
| Bimatoprost | Lumigan® | Lumigan® | Lumigan
| | Latisse TM | Lumigan® RC
| Latanoprost | Xalatan® | Xalatan® | Xalatan
Combined | Dorzolamide and timolol | Cosopt® | Cosopt® | Cosopt
| | Preservative-free Cosopt®
| Brimonidine and timolol | Combigan® | Combigan®

Glaucoma Treatment Devices

Laser, ophthalmic Product code: HQF
Company | Product | FDA Status” | Approval Date
20/20 TECHNOLOGIES, INC | HYPERION LTK SYSTEM (PMA Number P990078) | PMA | 5/8/2002
ADVANCED SURGICAL PRODUCTS INC. | PRISMA DISPOSABLE ENDO-OCULAR PROBE | SE | 4/13/1988
AESCULAP-MEDITEC NORTH AMERICA | MEDITEC LINK | SE | 6/17/1998
ALCON LABORATORIES | NEXT GENERATION LASER | SE | 11/5/2007
ALCON RESEARCH, LTD | OPHTHALAS 532 SOLID STATE PHOTOCOAG | Registered | n/a
ALCON RESEARCH, LTD | NEXT GENERATION LASER; PUREPOINT LASER SYSTEM | Registered | n/a
ALCON RESEARCH, LTD | ALCON LIO | Registered | n/a
AMERICAN LASER CORP. | BQ/BM INTEGRATED LASER DELIVERY SYSTEM | SE | 5/17/1999
AMERICAN MEDICAL OPTICS | ARGON LASER PHOTOCOAGULATOR SYS | SE | 11/6/1984
AMERICAN MEDICAL OPTICS | AMERI. MEDICAL OPTICS ARGON LASER PHOTO | SE | 8/15/1984
AMERICAN MEDICAL OPTICS | AMER. MEDICAL OPTICS ARGON/KRYPTON LASE | SE | 8/15/1984
AMERICAN MEDICAL OPTICS | AMER. MED. OPTICS ARGON LASER PHOTO | SE | 6/19/1984
AMERICAN MEDICAL OPTICS | AMER. MED. OPTICS ARGON/KRYPTON LASER | SE | 6/7/1984
BAUSCH & LOMB INC. | MILLENNIUM MICROSURGICAL SYSTEM AND PERISTALTIC PHACO PACK | SE | 2/10/2004
BIOPHYSIC MEDICAL INC. | INDIRECT OPHTHALMOSCOPE ACCESSORY DELIVERY SYSTEM | SE | 3/24/1989
BIOPHYSIC MEDICAL INC. | OPHTHALAS DYE OPHTHALMIC LASER | SE | 10/29/1987
BIOPHYSIC MEDICAL INC. | FOUR MODIFICATIONS TO OPHTHALAS ARGON/DYE LASER | SE | 8/30/1988
BRITT CORP. INC. | LASER PHOTOCOAGULATOR 1520-A & K | SE | 1/30/1984
BRITT CORP. INC. | BRITT KRYPTON LASERS 150K & 152K | SE | 1/22/1982
CANDELA LASER CORP. | CANDELA DIODE TRABECULOPLASTY LASER DTL | SE | 3/4/1991
CANDELA LASER CORP. | CANDELA UPC LASER PHOTOCOAGULATOR | SE | 8/2/1989
CARL ZEISS INC. | VISULINK 900 ARGON | SE | 8/14/1995
CARL ZEISS INC. | ZEISS VISULAS ARGON LASER | SE | 1/6/1988
CARL ZEISS MEDITEC AG | VISUMAX LASER KERATOME | SE | 7/8/2010
CARL ZEISS MEDITEC AG | VISULAS YAG II LASER | Registered | n/a
CARL ZEISS MEDITEC AG | VISUMAX LASER KERATOME | Registered | n/a
CARSON LASERWORKS | JR -- OPHTHALMIC ARGON LASER | SE | 11/12/1993
CAVITRON CORP. | LASER PHOTOCOAGULATION | SE | 12/28/1978
CERAMOPTEC INC. | CERALAS DIODE LASER SYSTEM (CERALAS D2) | SE | 2/21/1997
CERAMOPTEC INC. | MEGABEAM ENDOCULAR PROBE | SE | 4/1/1994
CHIRON VISION CORP. | LASAG MICRORUPTOR 2 ND:YAG OPHTH. LASER SYSTEM | SE | 1/10/1989
COBURN OPTICAL IND. INC. | MEDITEC (RODENSTOCK) LASER PHOTOCOAGUL | SE | 10/11/1979
COHERENT MEDICAL DIVISION | MODEL 900K PHOTOCOAGULATOR | SE | 7/28/1980
COHERENT MEDICAL GROUP | COHERENT MARIE ARGON PHOTOCOAGULATOR | SE | 6/15/1989
COHERENT MEDICAL GROUP | SYSTEM 920 PHOTOCOAGULATOR TO INCLUDE SCHIRMERSCOP | SE | 1/3/1985
COHERENT MEDICAL GROUP | LDS - LASER DELIVERY SYSTEM | SE | 10/7/1986
COHERENT MEDICAL GROUP | SYSTEM 920 ARGON/DYE PHOTOCOAGULATOR | SE | 6/5/1985
COOPER LASERSONICS INC. | MONITOR CO2 LASER SURGICAL SYSTEM | SE | 4/25/1984
COOPER LASERSONICS INC. | MODEL 8000 ND:YAG LASER SYS TREATMENT OF BENIGN LE | SE | 1/3/1985
COOPER LASERSONICS INC. | MODEL 4000 MD-YAG LASER FOR MALIGNANT | SE | 6/26/1984
COOPERVISION INC. | RESUBMITTED DIODE LASER COAGULATOR | SE | 8/2/1988
COOPERVISION INC. | MODEL 9500 ARGON KRYPTON & DYE SURGICAL LASER SYS | SE | 2/4/1986
COOPERVISION INC. | MODEL 1000 OPHTHALMIC LASER SYSTEM | SE | 9/24/1986
D.O.R.C. INTL. B.V. | OPHTHALMIC LASER PROBE | Registered | n/a
D.O.R.C. INTL. B.V. | LASERSTAR 532 | Registered | n/a
D.O.R.C. INTL. B.V. | OPHTHALMIC ILLUMINATED LASER PROBES | Registered | n/a
DIRECTED ENERGY INC. | MODEL 10-C W/FL-10A/U OPTICAL ATTACHMENT/OPTHALMIC | SE | 5/22/1987
DOUGLAS JAMES DONALDSON COMPLIANCE SERVICES | CRYSTAL FOCUS EMERALD-CW LASER PHOTOCOAGULATOR | SE | 10/19/1990
DOUGLAS JAMES DONALDSON COMPLIANCE SERVICES | CRYSTAL FOCUS EMERALD LASER/SLT OPHF 0.6 ENDO HAND | SE | 3/5/1991
ELLEX MEDICAL PTY. LTD. | LASEREX MODEL LP4532 | SE | 10/6/2004
ELLEX MEDICAL PTY. LTD. | LASEREX LP1532 PHOTOCOAGULATOR | SE | 10/3/1997
ELLEX MEDICAL PTY. LTD. | INTEGRE MODEL LP581 | SE | 3/11/2008
ELLEX MEDICAL PTY. LTD. | INTEGRE PRO MODEL L2RY | SE | 7/2/2008
ELLEX MEDICAL PTY. LTD. | INTEGRE FAMILY; SOLITAIRE LP4532 | Registered | n/a
ELLEX MEDICAL PTY. LTD. | INTEGRE DUO LP1RG; INTEGRE LP5532 | Registered | n/a
ELLEX MEDICAL PTY. LTD. | INTEGRE PRO FAMILY | Registered | n/a
ELLEX MEDICAL PTY. LTD. | INTEGRE LP1561 | Registered | n/a
ENDO OPTIKS, INC. | LASER, OPHTHALMIC (NOT SPECIFIED) | Registered | n/a
F. & F. KOENIGKRAMER | RELIANCE OPHTHALMIC SLIT LAMP R-083 | SE | 2/4/1984
G. RODENSTOCK INSTRUMENTE GMBH | RODENSTOCK LASER SLITLAMP | SE | 11/4/1997
G. RODENSTOCK INSTRUMENTE GMBH | ORION 3001 LASER PHOTOCOAGULATOR | SE | 11/13/1986
GLENDALE PROTECTIVE TECHNOLOGIES INC. | LASERMED* GOGGLES AND SPECTACLES | SE | 9/21/1989
HCG INC. | HCG INC. MEDICAL LASER ENDOCOAGULATOR MODEL P.C. | SE | 7/25/1985
HERAEUS LASERSONICS INC. | ND:YAG LASER SYSTEMS (VARIOUS MODELS) | SE | 5/24/1991
HGM INC. | FLEISCHMAN-SWARTZ ENDO-OCULAR PROBE | SE | 5/9/1984
HGM INC. | HGM ILLUMINATING IMAGING ENDOCULAR PROBE | SE | 3/1/1994
HGM INC. | MEDICAL LASER ENDOCOAGULATOR 5K | SE | 4/2/1984
HGM INC. | FLEISCHMAN-SWARTZ ENDO-OCULAR PROBE (STERILE) | SE | 3/21/1986
HGM INC. | HGM INC. MEDICAL LASER ENDOCOAGULATOR MODEL 8-K | SE | 4/23/1985
HGM INC. | HGM ASPIRATING ENDOOCULAR(TM) PROBE | SE | 8/17/1993
HGM MEDICAL LASER SYSTEMS INC. | COMPAC(TM) DIODE LASERS | SE | 4/25/1991
INFINITECH INC. | INFINITECH MULTI-SPOT SLIT LAMP LASER ADAPTER | SE | 8/1/1997
IRIDERM DIV. | DIOPEXY PROBE | SE | 7/19/1996
IRIDERM DIV. | OCULIGHT GL | SE | 8/28/1996
IRIDEX CORP. | IRIS MEDICAL IQ 810 PHOTOCOAGULATOR | SE | 9/20/2004
IRIDEX CORP. | OCULIGHT SL/SLX | SE | 5/3/2002
IRIDEX CORP. | IRIDEX WIRELESS FOOTSWITCH | SE | 11/14/2006
IRIDEX CORP. | IRIS MEDICAL OCULIGHT GL/GLX LASER SYSTEMS | SE | 8/27/2003
IRIDEX CORP. | LASER, OPHTHALMIC (NOT SPECIFIED) | Registered | n/a
IRIDEX CORP. | LASER, OPHTHALMIC (NOT SPECIFIED) | Registered | n/a
IRIDEX CORP. | LASER, OPHTHALMIC (NOT SPECIFIED) | Registered | n/a
KEELER INSTRUMENTS INC. | MICROLASE 8 0 0 (OPHTHALMIC LASER) | SE | 3/15/1989
KEELER INSTRUMENTS INC. | MICROLASE BY LASER TRABECULOPLASTY | SE | 10/31/1989
KEELER INSTRUMENTS INC. | KEELER MULTILASE 3000 | SE | 11/22/1994
LASAG AG | LASAG MICRORUPTER 2 ND:YAG LASER TRABECULOPLASTY | SE | 3/27/1990
LASER INDUSTRIES LTD. | OPHTHALMIC ARGON LASER #700A | SE | 1/30/1984
LASERMED CORP. | OCULASE 514 OPHTHALMIC ARGON LASER | SE | 2/4/1984
LASERTEK OY | LASER COAGULATOR MODEL 41AK | SE | 2/8/1979
LASERTEK OY | COAGULATOR MODEL 40 AARGON | SE | 2/8/1979
LASERTEK OY | MODEL 150K LASER COAGULATOR | SE | 1/30/1984
LIGHT-MED (USA) INC. | LPULSA SYL-9000 OPHTHALMIC YAG LASER | SE | 3/30/1999
LIGHTMED CORP. | LIGHTLAS 810 INFRARED LASER PHOTOCOAGULATOR | SE | 8/8/2002
LIGHTMED CORP. | LIGHTLAS SELECTOR | SE | 8/13/2009
LIGHTMED CORP. | LIGHTLAS 577 MEDICAL OPTICAL PUMPED SEMICONDUCTOR LASER | SE | 9/28/2009
LIGHTMED CORP. | LIGHTLAS MODEL 532 | SE | 9/18/2009
LIGHTMED CORP. | LIGHTLAS 561 OPTHALMIC PHOTOCOAGULATOR | SE | 9/20/2007
LIGHTMED CORP. | LIGHTLAS 532 PHOTOCOAGULATOR | SE | 8/22/2001
LIGHTMED CORP. | AURA PT; OPHTHALMIC YAG LASER; SYL-9000 | Registered | n/a
LIGHTMED CORP. | LIGHTLAS 561 | Registered | n/a
LIGHTMED CORP. | LIGHTLAS 532 | Registered | n/a
LIGHTMED CORP. | LIGHTLAS 810 | Registered | n/a
LIGHTMED CORP. | LIGHTLAS SELECTOR DEUX | Registered | n/a
LIGHTMED CORP. | LIGHTLAS 577 | Registered | n/a
LIGHTMED CORP. | LIGHTLAS 532 | Registered | n/a
LUMENIS INC. | FAMILY OF SELECTA OPHTHALMIC LASER SYSTEMS (SELECTA 1064 SELECTA SLT SELECTA DUO) DELIVERY DEVICE AND ACCESSORIES | SE | 9/30/2005
LUMENIS INC. | MODEL 900S INTRAOCULAR PROBE | SE | 11/16/1981
LUMENIS INC. | AURA PT-II | Registered | n/a
LUMENIS INC. | LASER, OPHTHALMIC (NOT SPECIFIED) | Registered | n/a
LUMENIS INC. | LASER, OPHTHALMIC (NOT SPECIFIED) | Registered | n/a
LUMENIS INC. | SELECTA 1064; SELECTA DUO; SELECTA SLT; SELECTA TRIO | Registered | n/a
LUMENIS INC. | NOVUS 2000 | Registered | n/a
LUXTEC CORP. | LUXSCOPE | SE | 11/21/1997
MARTIN S. KNOPF ASSOC. INC. | URAM OPHTHALMIC LASER ENDOSCOPE | SE | 5/28/1991
MEDITEC INC. | MDS 83 OPHTHALMIC DYE LASER SYSTEM | SE | 8/1/1985
MEDITEC OF AMERICA | LASER LENS-VARIOUS MODELS | SE | 4/5/1984
MERIDIAN AG | MERILAS 532A | SE | 12/14/2007
MERIDIAN AG | MERILAS 532ALPHA | Registered | n/a
MIRA INC. | OPHTHALMIC LASER PHOTOCOAGULATOR | SE | 11/12/1985
MIRA INC. | ENDOPHOTOCOAGULATION PROBE | SE | 10/10/1986
MIRA INC. | OPHALMIC LASER PHOTOCOAGULATOR | SE | 11/12/1985
MIRA INC. | MIRALITE | SE | 10/31/1986
NIDEK CO., LTD. HAMACHO PLANT | LASER DIODE PHOTOCOAGULATOR DC-3300 | Registered | n/a
NIDEK CO., LTD. HAMACHO PLANT | MC-300; MC-500; MULTICOLOR LASER PHOTOCOAGULATOR | Registered | n/a
NIDEK INC. | MODEL DC-1200 DIODE LASER PHOTOCOAGULATOR | SE | 10/16/1989
NIDEK INC. | NIDEK ADC-8000 LASER SYSTEM | SE | 10/15/1987
NIDEK INC. | ARGON/KRYPTON ION LASER PHOTOCOAGULA | SE | 3/16/1984
NIDEK INC. | NIDEK MODEL AC-2300 | SE | 11/22/1993
NIDEK INC. | NIDEK MODEL GYC-1500 AND GYC-2000 | SE | 9/14/1995
NIDEK INC. | NIDEK MODEL AKC-8000 | SE | 8/7/1989
NIDEK INC. | DC-3300 LASER DIODE PHOTOCOAGULATOR | SE | 2/11/2002
NIDEK INC. | NIDEK OPEATING MICROSCOPE DELIVERY SYSTEM (OMDS) | SE | 9/15/1988
OCULAR INSTRUMENTS INC. | RITCH TRABECULOPLASTY LASER LENS | SE | 7/11/1986
OCULAR INSTRUMENTS INC. | MULTIPLE RITCH TRABECULOPLASTY | Registered | n/a
OD -OS GMBH | NAVILAS LASER SYSTEM | SE | 10/27/2009
OD -OS GMBH | NAVILAS LASER SYSTEM | Registered | n/a
OMNIGUIDE COMMUNICATIONS INC. | OMNIGUIDE BEAMPATH CO2 MARK I LASER BEAM DELIVERY | SE | 5/9/2005
OMNIGUIDE, INC. | OMNIGUIDE BEAM PATH CO2 MARK | Registered | n/a
OPHTHALMED LLC | 20G SMA LASER FIBER MODEL LF100 | SE | 9/21/2005
OPHTHALMED LLC | A1x010x (20g, 23g, 25g ILLUM PROBE); A4xx010 (20g LASER/ASP PROBE); A5xx100 (20g LASER/ILLUM PROBE); A6xx110 (20g LASER/ILLUM/ASP PROBE); OPHTHALMED LASER-ILLUMINATION | Registered | n/a
OPTIMEDICA CORPORATION | PASCAL STREAMLINE PHOTOCOAGULATOR | SE | 5/4/2010
OPTIMEDICA CORPORATION | PASCAL STREAMLINE PHOTOCOAGULATOR | SE | 9/25/2009
OPTIMEDICA CORPORATION | PASCAL STREAMLINE PHOTOCOAGULATOR | Registered | n/a
OPTIMEDICA CORPORATION | PASCAL STREAMLINE | Registered | n/a
OPTO ELETRONICA S.A. | OPTO ADVANT YAG LASER | Registered | n/a
PEREGRINE SURGICAL LTD. | PEREGRINE SOFT TIP ASPIRATING LASER PROBE MODEL PD720.60 | SE | 6/21/2006
PEREGRINE SURGICAL LTD. | PEREGRINE ILLUMINATING LASER PROBE MODEL PD600.10 | SE | 6/27/2003
PEREGRINE SURGICAL LTD. | LASER, OPHTHALMIC (NOT SPECIFIED) | Registered | n/a
PEREGRINE SURGICAL LTD. | LASER, OPHTHALMIC (NOT SPECIFIED) | Registered | n/a
PEREGRINE SURGICAL LTD. | ASPIRATING LASER PROBE | Registered | n/a
PFIZER LASER SYSTEMS | CENTAURI | SE | 2/11/1991
QUANTEL MEDICAL | Q-SWITCHED ND:YAG OPHTALMIC LASER (WITH SLIT LAMP) MODEL OPTIMIS II | SE | 3/24/2005
QUANTEL MEDICAL | FREQUENCY DOUBLED ND: YAG PHOTOCOAGULATOR MODEL VITRA | SE | 2/7/2005
QUANTEL MEDICAL | SUPRA OPHTHALMIC LASER PHOTOCOAGULATOR | SE | 4/24/2007
QUANTEL MEDICAL | SUPRA TWIN OPHTHALMIC LASER PHOTOCOAGULATOR | SE | 3/25/2009
QUANTEL MEDICAL | SUPRA 577.Y LASER | SE | 6/16/2009
QUANTEL MEDICAL | IRIDIS OPHTHALMIC PHOTOCOAGULATOR | SE | 12/17/2002
QUANTEL MEDICAL | IRIDIS; OPTIMIS-II, VIRIDIS; SUPRA; VIRIDIS TWIN; VITRA | Registered | n/a
QUANTEL MEDICAL | LASER, OPHTHALMIC (NOT SPECIFIED) | Registered | n/a
SOLX INC. | SOLX 790 TITANIUM SAPPHIRE LASER | SE | 9/12/2008
SOLX INC. | SOLX 790 TITANIUM SAPPHIRE LASER | Registered | n/a
STALLION MEDICAL, INC. | OPHTHALMIC PHOTOCOAGULATOR LASER | Registered | n/a
STEFANOVSKY & ASSOC. | LASER PROTECTIVE EYESHIELD | SE | 12/30/1983
STERILMED, INC. | LASER, OPHTHALMIC (NOT SPECIFIED) | Registered | n/a
SUMMIT TECHNOLOGY INC. | LASER AND EMPHASIS SCLEROSTOMY TIP | SE | 7/22/1993
SUNRISE TECHNOLOGIES, INC. | SUNRISE TECHNOLOGIES HYPERION(TM) HOLMIUM LASER SYSTEM FOR LASER THERMAL KERATOPLASTY (LTK) (PMA Number P990078) | PMA | 3/16/2001
SUNRISE TECHNOLOGIES, INC. | HYPERION LTK SYSTEM (PMA Number P990078) | PMA | 12/11/2000
SURGICAL LASER TECHNOLOGIES INC. | SLT CONTACT LASER SYSTEM OCULOPLASTICS | SE | 6/6/1988
SURGICAL LASER TECHNOLOGIES INC. | SLT CL60 CONTACT LASER SYSTEM CUTTING & COAGULA. | SE | 9/30/1988
SYNEMED INC. | DERMATOLOGY HANDPIECE-OPHTH LASER | SE | 12/3/1983
TARACAN PTY. LTD. | LASEREX ERA ARTICULATED ARM KIT MODEL LQP4106-AA | SE | 7/6/2000
TOP CON | TOPCON EC-200 ENDO-PHOTOCOAGULATOR LASER | SE | 12/18/1990
VISITEC CO. | HESSBURG GLIDE UNTRAOCULAR LENSGUIDES | SE | 9/24/1985