# Excluded Articles

A new beta blocking agent in the treatment of chronic open-angle glaucoma: timolol maleate Foreign language
Sclera-covered filter operation. Fortschr Ophthalmol. Suppl. 87 ; 84:S106-47. It is not a RCT and has less than 100 patients
Trabeculotomy. Fortschr Ophthalmol. Suppl. 87 ; 84:S148-76. It is a case series
Aalto-Korte K. Contact allergy to dorzolamide eyedrops. Contact Dermatitis. 98; 39(4):206. It is a case series
Abelson MB, Netland PA, Chapin MJ. Switching patients with glaucoma or ocular hypertension from dual therapy to monotherapy: evaluation of brimonidine as a model (Structured abstract). Advances in Therapy. 2001;18(6):282-297. [pmid: 11841198]. Data not abstractable
Abelson MB, Netland PA, Chapin MJ. Switching patients with glaucoma or ocular hypertension from dual therapy to monotherapy: evaluation of brimonidine as a model. Unique comparators
Abraham SV, Teller JJ. Influence of various miotics on cataract formation. Br J Ophthalmol. 69 ;53(12):833-8. Does not address any key questions (see below for questions), It is not a RCT and has less than 100 patients
Abramov VG, Vakurin EA. Results of trabeculectomy in primary open-angle glaucoma. Foreign language
Abramov VG, Vakurin EA, Chirkin VE. Filtering variants of trabeculectomy in open-angle glaucoma. Foreign language
Abramov VG, Vakurin EA, Il’in VP, Shiriaeva NV. Late results of trabeculectomy in open-angle glaucoma. Foreign language
Abu El-Asrar AM, Al-Mezaine HS. Advances in the treatment of diabetic retinopathy. Systematic review
Accorinti M, Ciapparoni V, Pirraglia MP, Pivetti-Pezzi P. Treatment of severe ocular hypotony in AIDS patients with cytomegalovirus retinitis and cidofovir-associated uveitis. Medical KQ 3 only
Adachi M, Shirato S, Kaburagi T, Suzuki Y. Ten-year results of argon laser trabeculoplasty. Foreign language
Adamsons IA, Polis A, Ostrov CS, Boyle JE. Two-year safety study of dorzolamide as monotherapy and with timolol and pilocarpine. Dorzolamide Safety Study Group. J Glaucoma. 98 ;7(6):395-401. Other (specify):pilocarpine
Adamsons I. Irreversible corneal decompensation in patients treated with topical dorzolamide. Am J Ophthalmol. 99 ;128(6):774-6. No original data (e.g., systematic review, narrative review, editorial, letter)
Adamsons I, Anderrson KW, Strohmaier KM, Clineschmidt CM. Three month results of a clinical trial comparing 0.5% timolol/2.0% MK-507 combination to concomitant use of 0.5% timolol and 2.0% MK-507. Meeting abstract
Adamsons I, Boyle J, Ghosh K. A Randomized Trial Comparing the Dorzolamide/Timolol Combination to Monotherapy with Timolol or Dorzolamide. Meeting abstract
Adamsons I, Clineschmidt C, Polis A, Taylor J, Shedden A, Laibovitz R. The efficacy and safety of dorzolamide as adjunctive therapy to timolol maleate gellan solution in patients with elevated intraocular pressure. Additivity Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
Adamsons I, Clineschmidt C, et al. The efficacy and safety of dorzolamide as adjunctive therapy to timolol maleate gellan solution in patients with elevated intraocular pressure. Medical KQ 3 or KQ 3 and KQ 6 only
Adefule-Ositelu AO, Adegbehingbe BO, Adefule AK, Adegbehingbe OO, Samaila E, Oladigbolu K. Efficacy of Garcinia kola 0.5% Aqueous Eye Drops in Patients with Primary Open-Angle Glaucoma or Ocular Hypertension. Middle East Afr J Ophthalmol. 2010;17(1):88-93. [pmid: 20543944]. Other (specify):not FDA approved, Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Adil SE, El Sayyad FF, Helal MH, El-Maghraby MA, El-Hamzawey H. Trabeculectomy in black population: results from saudi arabia. Meeting abstract
Agarwai HC, Sood NN, Dayal Y. Timolol in open angle glaucoma. Indian J Ophthalmol. 81 ;29(1):9-11. It is not a RCT and has less than 100 patients
Agarwal HC, Anuradha VK, Titiyal JS, Gupta V. Effect of intraoperative intracameral 2% hydroxypropyl methylcellulose viscoelastic during trabeculectomy. Ophthalmic Surg Lasers Imaging. 2005;36(4):280-5. [pmid: 16156143]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Agarwal HC, Elankumaran P, Gupta V, Titiyal JS. Comparison of subscleral partial thickness sclerectomy plus trabeculotomy with trabeculectomy for primary open angle glaucoma. Asian J Ophthalmol. 2005;7(3):96-100. It is not a RCT and has less than 100 patients
Agarwal HC, Poovali S, Sihota R, Dada T. Comparative evaluation of diode laser trabeculoplasty vs frequency doubled Nd : YAG laser trabeculoplasty in primary open angle glaucoma. Eye (Lond). 2006;20(12):1352-6. [pmid: 16215542]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Agarwal HC, Saigal D, Sihota R. Assessing the role of subconjunctival versus intrascleral application of mitomycin C in high-risk trabeculectomies. Indian J Ophthalmol. 2001;49(2):91-5. [pmid: 15884512]. OAG can’t be analyzed separately
Agarwal R, Agarwal P. Future target molecules in antiglaucoma therapy: tgf-Beta may have a role to play. Systematic review
Agbeja-Baiyeroju AM, Omoruyi M, Owoaje ET. Effectiveness of trabeculectomy on glaucoma patients in Ibadan. Afr J Med Med Sci. 2001;30(1–2):39-42. [pmid: 14510148]. Data not abstractable
Aggarwal SP, Hendeles S. Risk of sudden visual loss following trabeculectomy in advanced primary open-angle glaucoma. Br J Ophthalmol. 86 ;70(2):97-9. [pmid: 11801512]. It is not a RCT and has less than 100 patients
Aguinaga Ontoso I, Guillen Grima F, Aguinaga Ontoso E, Fernandez LR. Does medical treatment of mild intraocular hypertension prevent glaucoma? (Structured abstract). European Journal of Epidemiology. 97 ;13(1):19-23. No original data (e.g., systematic review, narrative review, editorial, letter)
Ah-Fat FG, Canning CR. A comparison of the efficacy of Holmium laser sclerostomy ab externo versus trabeculectomy in the treatment of glaucoma. EYE. 94 ;8(4):402-405. OAG can’t be analyzed separately
Ahmad Lone I, Rizvi A, Sajjad Ahmad S, Ahmad Unto R. Comparison of latanoprost and dorzolamide in patients with open angle glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Ahmad S. Cardiopulmonary effects of timolol eyedrops. Lancet. 79 ; 2(8150):1028. It is a case series
Ai H, Yang X-G, Wang R-S, Tian B-Y, Xue X-H, Guo B. Comparative analysis of the clinical outcomes of non-penetrating trabecular surgery and trabeculectomy in treatment of primary open angle glaucoma. Foreign language
Airaksinen PJ. The long-term hypotensive effect of timolol maleate compared with the effect of pilocarpine in simple and capsular glaucoma. Acta Ophthalmol (Copenh). 79 ;57(3):425-34. Does not address any key questions
Airaksinen PJ, Valkonen R, Stenborg T, Takki K, Klemetti A, Kontkanen M, Oskala P. A double-masked study of timolol and pilocarpine combined. Am J Ophthalmol. 87 ;104(6):587-90. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Airaksinen PJ, Valle O, Takki KK, Klemetti A. Timolol treatment of chronic open-angle glaucoma and ocular hypertension. A 2.5-year multicenter study. Graefes Arch Clin Exp Ophthalmol. 82 ;219(2):68-71. Other (specify):Inadequate control
Ajit RR, Fenerty CH, Henson DB. Patterns and rate of adherence to glaucoma therapy using an electronic dosing aid. Eye. 2010;24(8):1338-1343. [pmid: 20339390]. OAG can’t be analyzed separately
Akafo SK, Thompson JR, Rosenthal AR. A cross-over trial comparing once daily levobunolol with once and twice daily timolol. Medical KQ 3 or KQ 3 and KQ 6 only
Akarsu C, Onol M, Hasanreisoglu B. Postoperative 5-fluorouracil versus intraoperative mitomycin C in high-risk glaucoma filtering surgery: extended follow up. Clin Experiment Ophthalmol. 2003;31(3):199-205. [pmid: 12786769]. Other (specify):Average age below 50
Akingbehin T, Villada JR. Metipranolol-induced adverse reactions: II. Loss of intraocular pressure control. Eye (Lond). 92 ; 6(Pt 3):280-3. Does not address any key questions
Akingbehin T, Villada JR, Walley T. Metipranolol-induced adverse reactions: I. The rechallenge study. Eye (Lond). 92 ;6(Pt 3):277-9. Does not address any key questions
Akman A, Cetinkaya A, Akova YA, Ertan A. Comparison of additional intraocular pressure-lowering effects latanoprost vs brimonidine in primary open-angle glaucoma patients with intraocular pressure uncontrolled by timolol-dorzolamide combination. Medical KQ 3 or KQ 3 and KQ 6 only
Akman A, Cetinkaya A, Akova YA, Ertan A. Comparison of additional intraocular pressure-lowering effects of latanoprost vs brimonidine in primary open-angle glaucoma patients with intraocular pressure uncontrolled by timolol-dorzolamide combination. Medical KQ 3 only
Akopian VS, Kazakova EL. Effectiveness of repeat laser trabeculoplasty in open-angle glaucoma. Foreign language
Alagoz G, Bayer A, Boran C, Serin D, Kukner A, Elcioglu M. Comparison of ocular surface side effects of topical travoprost and bimatoprost. med RCT included only for KQ 6
Alagoz G, Gurel K, Bayer A, Serin D, Celebi S, Kukner S. A comparative study of bimatoprost and travoprost: effect on intraocular pressure and ocular circulation in newly diagnosed glaucoma patients. Medical KQ 3 or KQ 3 and KQ 6 only
Albert DM, Gangnon RE, Zimbric ML, Damico CM, Fisher MR, Gleiser J, Grossniklaus HE, Green WR. A study of iridectomy histopathologic features of latanoprost- and non-latanoprost-treated patients. Arch Ophthalmol. 2004;122(11):1680-5. [pmid: 15534130]. OAG can’t be analyzed separately
Alberta Heritage Foundation for Medical Research. AquaFlow(R) (Structured abstract). Meeting abstract
Albracht DC, LeBlanc RP, Cruz AM, Lamping KA, Siegel LI, Stern KL, Kelley EP, Stoecker JF. A double-masked comparison of betaxolol and dipivefrin for the treatment of increased intraocular pressure. Am J Ophthalmol. 93 ; 116(3):307-13. [pmid: 7200325]. Does not address any key questions
Albritton AE, Sharpe ED, Day DG, Beischel CJ, Rhodes JS, Stewart JA, Stewart WC. Brimonidine Purite 0.15% versus Dorzolamide 2% Each Given Twice Daily to Reduce the Intraocular Pressure in Patients with Open-angle Glaucoma or Ocular Hypertension. Meeting abstract
Alegre N·±ez Juan R, GarcÆa -lvarez Hernbn, Hernbndez Pe±a Eduardo, OrtÆz Berm·dez Osmany. TrabeculectomÆa con 5-fluorouracilo transoperatorio. Foreign language
Alekseev BN, Basov GV, Mostovoi EN. The late results of a trabeculoretraction operation. Foreign language
Alemu B. Trabeculectomy: complications and success in IOP control. Ethiop Med J. 97 ;35(1):1-11. OAG can’t be analyzed separately
Ali FS, Akpek EK. Glaucoma and dry eye. Ophthalmology. 2009;116(6):1232. [pmid: 19486808]. No original data (e.g., systematic review, narrative review, editorial, letter)
Alimgil ML, Benian O. The effect of dorzolamide on intraocular pressure and ocular pulse amplitude: Adjunctive therapy to beta-blockers as a substitute for pilocarpine or as a second-line therapeutic agent in patients with open-angle glaucoma. East J Med. 2002;7(1):1-5. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Alimgil ML, Erda S, Benian O. The additive effect of dipivefrin in patients with wide angle glaucoma treated with long-term beta-blocker therapy in comparison with clonidine. Klin Monbl Augenheilkd. 94; 205(2):114-6. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Allaire C, Trinquand C, Nordmann JP, Dascotte JC, George JL, Lesure P, Rouland JF, Khaitrine L, Sirbat D. Hypotensive action of 0.5% carteolol versus 0.1% timolol in patients with intraocular hypertension. Foreign language
Allen MY, Keole NS, Shin DH, Juzych MS, Song MS, Parrow KA, Swendris RP, O’Grady JM. Comparative study of subconjunctival versus subscleral flap mitomycin C (MMC) versus no adjunctive MMC in primary glaucoma triple procedure (PGTP). Meeting abstract
Allen RC, Hertzmark E, Walker AM, Epstein DL. A double-masked comparison of betaxolol vs timolol in the treatment of open-angle glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Allen RC, Robin AL, Long D, Novack GD, Lue JC, Kaplan G. A combination of levobunolol and dipivefrin for the treatment of glaucoma. Arch Ophthalmol. 88 ;106(7):904-7. Other (specify):not FDA approved, not used
Alm A, Stjernschantz J. Effects on intraocular pressure and side effects of 0005% latanoprost applied once daily, evening or morning. A comparison with timolol. Scandinavian Latanoprost Study Group. Duplicate 8422
Alm A, Stjernschantz J. Effects on intraocular pressure and side effects of 0005% latanoprost applied once daily, evening or morning: A comparison with timolol. Medical KQ 3 or KQ 3 and KQ 6 only
Alm A, Stjernschantz J. Effects on IOP and Side-Effects of 0005% Latanoprost Once Daily, Evening or Morning: A Comparison with Timolol. ‡. Meeting abstract
Alm A, Widengard I. Latanoprost: experience of 2-year treatment in Scandinavia. Medical KQ 3 or KQ 3 and KQ 6 only
Alm A. Can NSAIDs and prostaglandin analogues be combined. Br J Ophthalmol. 2006;90(3):259-60. [pmid: 16488938]. No original data (e.g., systematic review, narrative review, editorial, letter)
Alm A. Comparative phase III clinical trial of latanoprost and timolol in patients with elevated intraocular pressure. Medical KQ 3 or KQ 3 and KQ 6 only
Alm A, Camras CB, Watson PG. Phase III latanoprost studies in Scandinavia, the United Kingdom and the United States. Surv Ophthalmol. 97 ;41(Suppl 2):S105-10. No original data (e.g., systematic review, narrative review, editorial, letter)
Alm A, Grunden JW, Kwok KK. Five-year, multicenter safety study of fixed-combination latanoprost/timolol (Xalacom) for open-angle glaucoma and ocular hypertension. J Glaucoma. 2011. Other (specify):Not an approved medication in the US
Alm A, Villumsen J, Tornquist P, Mandahl A, Airaksinen J, Tuulonen A, Marsk A, Resul B, Stjernschantz J. Intraocular pressure-reducing effect of PhXA41 in patients with increased eye pressure. A one-month study. Ophthalmology. 93 ;100(9):1312-6. discussion 1316–7. Does not address any key questions
Alm A, Widengard I, Kjellgren D, Söderström M, Friström B, Jeijl A, Stjernschantz J. ONCE DAILY APPLICATION OF LATANOPROST CAUSES A MAINTAINED REDUCTION OF INTRAOCULAR PRESSURE IN GLAUCOMA PATIENTS TREATED WITH TIMOLOL. Meeting abstract
de Almeida Homero G. Tratamento prqvio com colÆrio de aspirina na trabeculoplastia com laser de argónio. Foreign language
Almeida Homero Gusmåo de, de Figueiredo Carlos Lucas. Encapsulamento da bolsa filtrante p£s-trabeculectomia: estudo retrospectivo de quatro anos. Foreign language
Al-Mobarak F, Khan AO. Two-year survival of Ahmed valve implantation in the first 2 years of life with and without intraoperative mitomycin-C. Ophthalmology. 2009;116(10):1862-5. [pmid: 19592105]. No subjects with open-angle glaucoma
Almodin Juliana, Pedroso Eduardo Cavalheiro, Cvintal Tadeu, Almodin Flavia. ComparagPo press£rica e visual entre a facoesclerectomia profunda nPo penetrante e a facotrabeculectomia. phacoemulsification with non penetrating deep sclerectomy and phacoemulsification with trabeculectomy: Intraocular pressure and visual results from combined surgery. Foreign language
Alonso MA, Duch S, Cadarso L, Palomar A, De La Camara J. Effect of Levo Moprolol 0.9% drops on intraocular pressure: Application in ocular hypertension and open angle glaucoma. Efecto levo moprolol colirio al 0.9% sobre la presion intraocular: Aplicacion en la hipertension ocular y en el glaucoma cronico simple. Foreign language
Alonso MA, Duch S, Cadarso L, Palomar A, De LCJ. Effect of Levo Moprolol 0.9% drops on intraocular pressure: Application in ocular hypertension and open angle glaucoma. Duplicate
Alpar JJ. Sodium hyaluronate (Healon) in glaucoma filtering procedures. Ophthalmic Surg. 86 ;17(11):724-30. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Altan C, Ozturker C, Bayraktar S, Eren H, Ozturker ZK, Yilmaz OF. Post-trabeculectomy choroidal detachment: not an adverse prognostic sign for either visual acuity or surgical success. Eur J Ophthalmol. 2008;18(5):771-7. [pmid: 18850557]. It is a case series
Altangerel U, Moster MR, Lopes JF, Tong MG, Alvim H, Fontanarosa J. Healon5 Subtenon Under the Bleb in Trabeculectomy Surgery: A Randomized Clinical Trial. Meeting abstract
Altman B, Craven ER, Shams NBK, Haque R, Kapik B, Peloso C. Safety of the docosanoid unoprostone isopropyl 0.15% when used adjunctively with brimonidine tartrate 0.2% or dorzolamide HCL 2.0% in patients with primary open-angle glaucoma or ocular hypertension. Meeting abstract
Alvarado JA, Hollander DA, Juster RP, Lee LC. Ahmed valve implantation with adjunctive mitomycin C and 5-fluorouracil: long-term outcomes. Am J Ophthalmol. 2008;146(2):276-284. [pmid: 18538300]. Data not abstractable
Alvi NP, Cantor LB, Hoop JS, Sanders SP, Bhavnani VD, Brizendine EJ. LONG TERM COMPARISON OF 0.1 VERSUS 0.2 MG/CC OF MITOMYCIN C IN PRIMARY TRABFCULECIOMY. Meeting abstract
Alward WLM, Lewis RA. TRABECULECTOMY VS THERMOSCLEROSTOMY: A TEN-YEAR FOLLOW-UP. Meeting abstract
Alward WL. Additive efficacy of unoprostone isopropyl 0.12% (rescula) to latanoprost 0.005%. Am J Ophthalmol. 2001;132(3):449-51. [pmid: 11554384]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Alward WL. Medical management of glaucoma. N Engl J Med. 98 ; 339(18):1298-307. No original data (e.g., systematic review, narrative review, editorial, letter)
Alwitry A, Abedin A, Patel V, Moodie J, Rotchford A, King AJ. Primary low-risk trabeculectomy augmented with low-dose mitomycin-C. Systematic review
Alwitry A, Moodie J, Rotchford A, Abedin A, Patel V, King AJ. Predictive value of early IOP in mitomycin-C augmented trabeculectomy. J Glaucoma. 2007;16(7):616-21. [pmid: 18091180]. OAG can’t be analyzed separately
Ambresin A, Shaarawy T, Mermoud A. Deep sclerectomy with collagen implant in one eye compared with trabeculectomy in the other eye of the same patient. J Glaucoma. 2002;11(3):214-20. [pmid: 12140398]. It is not a RCT and has less than 100 patients
Amissah-Arthur KN, Rashid A, Quhill F. A reply to Short-term effect of intravitreal anti-VEGFs delivery on intraocular pressure. Br J Ophthalmol. 2010;94(3):393. [pmid: 20215389]. No subjects with open-angle glaucoma, No original data (e.g., systematic review, narrative review, editorial, letter)
Amorim Filho Walter Gomes, Moreira Josq Belmiro de Castro, Rehder Jose Ricardo Carvalho Lima. Controle da pressåo intra-ocular com pilocarpina a 4% nas formas gel e colÆrio. Foreign language
Anand A, Negi S, Khokhar S, Kumar H, Gupta SK, Murthy GV, Sharma TK. Role of early trabeculectomy in primary open-angle glaucoma in the developing world. Eye (Lond). 2007;21(1):40-5. [pmid: 16200053]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Anand N, Arora S, Clowes M. Mitomycin C augmented glaucoma surgery: evolution of filtering bleb avascularity, transconjunctival oozing, and leaks. Br J Ophthalmol. 2006;90(2):175-80. [pmid: 16424529]. Does not address any key questions
Anand N, Kumar A, Gupta A. Primary phakic deep sclerectomy augmented with mitomycin C: long-term outcomes. J Glaucoma. 2011;20:21-7. [pmid: 20179623]. OAG can’t be analyzed separately
Anand N, Menage MJ, Bailey C. Phacoemulsification trabeculectomy compared to other methods of combined cataract and glaucoma surgery. Acta Ophthalmol Scand. 97 ;75(6):705-10. It is combined cataract/glaucoma surgery study published before April 2000
Anand N, Mielke C, Dawda VK. Trabeculectomy outcomes in advanced glaucoma in Nigeria. Duplicate
Anand N, Mielke C, Dawda VK. Trabulectomy outcomes in advanced glaucoma in Nigeria. Eye (Lond). 2001;15(Pt 3):274-8. [pmid: 11450719]. Other (specify):does not state that these are POAG
Anand S, Anand N. Combined phacoemulsification and deep sclerectomy (PDS) with intraoperative mitomycin C (MMC) augmentation. Eye. 2008;22(8):1040-1049. [pmid: 17464299]. OAG can’t be analyzed separately
Andermann C, Mialhe D, Arne JL. Ocular hypotensive effects of a new long acting pilocarpine salt. Clinical results by repeated administration. Foreign language
Andermann C, Mialhe D, Arne JL, Vende D, Bec P. Effect on pressure after instillation of a drop of depot-pilocarpine. Clinical results of its medium-term action. Foreign language
Anderson DR, Drance SM, Schulzer M. Factors that predict the benefit of lowering intraocular pressure in normal tension glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Andreanos D, Georgopoulos GT, Vergados J, Papaconstantinou D, Liokis N, Theodossiadis P. Clinical evaluation of the effect of mitomycin-C in re-operation for primary open angle glaucoma. Included in Wilkins 2010
Andreasson S, Jensen KM. Effect of pindolol on intraocular pressure in glaucoma: pilot study and a randomised comparison with timolol. Br J Ophthalmol. 83 ;67(4):228-30. Other (specify):Pindolol not an intervention of interest
Andreic V, Miljkovic A, Babic N. A comparison of 180 degrees of treatment with diode laser trabeculoplasty in primary open-angle glaucoma and exfoliation glaucoma: a short-term study of 22 patients. Curr Eye Res. 2009;34(3):202-6. [pmid: 19274527]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Ang GS, Wells AP. Goldmann applanation tonometry and dynamic contour tonometry after treatment with prostaglandin analog/prostamide. J Glaucoma. 2010;19(5):346. author reply 347. [pmid: 20543630]. It is not a RCT and has less than 100 patients
Ang GS, Chan KC, Poostchi A, Nicholas S, Birchall W, Wakely L, Wells AP. Comparison of standard trabeculectomy versus microtrabeculectomy as a surgical treatment for glaucoma: a randomised clinical trial. Clin Experiment Ophthalmol. 2011. OAG can’t be analyzed separately
Ang GS, Kersey JP, Shepstone L, Broadway DC. The effect of travoprost on daytime intraocular pressure in normal tension glaucoma: a randomised controlled trial. Unique comparators
Angelo-Nielsen K. Timolol topically and diabetes mellitus. JAMA. 80 ; 244(20):2263. It is a case series
Anghel G, Anghel AC. Opinions about quality of life in glaucoma patients with medications in Romania. Foreign language
Anglade E, Dreyer E. THE EFFECT OF MITOMYCIN C AND 5-FLUOROURACIL ON CORNEAL ENDOTHELIUM IN TRABECULECTOMY SURGERY. Meeting abstract
Anmarkrud N, Bergaust B, Bulie T, Sand AB. Argon laser trabeculoplasty--5 years experience from a local eye department. Acta Ophthalmol Suppl. 87 ;182:34-6. Does not address any key questions
Ansari H, Kempen JH. Proof of concept for combined insertion of fluocinolone acetonide and glaucoma drainage implants for eyes with uveitis and glaucoma. Am J Ophthalmol. 2010;149(5):699-700. [pmid: 20399922]. No original data (e.g., systematic review, narrative review, editorial, letter), No subjects with open-angle glaucoma
Antohi I, Chiseli&#355, &#259 D, Cionca D, Gherman C, Mo&#355, oc I, Gentimir M. The role of iridectomy in glaucoma surgery. Foreign language
Antohi I, Chiselita D, Cionca D, Gherman C, Motoc I, Gentimir M. The role of iridectomy in glaucoma surgery. Foreign language
Aquino MV, Lat-Luna MML, Flores JVPD. Comparison of outcomes and predictors of trabeculectomy using high-dose or low-dose mitomycin C. Asian J Ophthalmol. 2004;6(2):2-5. Data not abstractable
Araie M, Shirato S, Yamazaki Y, Kitazawa Y, Ohashi Y. Nipradilol-Timolol Study Group. Visual field loss in patients with normal-tension glaucoma under topical nipradilol or timolol: subgroup and subfield analyses of the nipradilol-timolol study. Japanese journal of ophthalmology. 2010;54(4):278-85. [pmid: 20700793]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Araie M. A three-year comparative, prospective and randomized study between 0.005% Latanoprost and 0.5% Timolol in Japanese Normal Tension Glaucoma patients. Meeting abstract
Araie M, Azuma I, Kitazawa Y. Influence of topical betaxolol and timolol on visual field in japanese open-angle glaucoma (oag) patients. Meeting abstract
Araie M, Azuma I, Kitazawa Y. Influence of topical betaxolol and timolol on visual field in Japanese open-angle glaucoma patients. Medical KQ 3 or KQ 3 and KQ 6 only
Araie M, Kitazawa Y, Azuma I, Shirato S, Hamanaka T, Tomita G, Origasa H. The efficacy and safety of dose escalation of dorzolamide used in combination with other topical antiglaucoma agents. J Ocul Pharmacol Ther. 2003;19(6):517-25. [pmid: 14733709]. It is not a RCT and has less than 100 patients
Araie M, Shirato S, Yamazaki Y, Kitazawa Y, Ohashi Y. Clinical efficacy of topical nipradilol and timolol on visual field performance in normal-tension glaucoma: a multicenter, randomized, double-masked comparative study. Jpn J Ophthalmol. 2008;52(4):255-64. [pmid: 18773262]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Araie M, Shirato S, Yamazaki Y, Kitazawa Y, Ohashi Y. Visual field loss in patients with normal-tension glaucoma under topical nipradilol or timolol: subgroup and subfield analyses of the nipradilol-timolol study. Jpn J Ophthalmol. 2010;54(4):278-85. [pmid: 20700793]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Araie M, Shoji N, Shirato S, Nakano Y. Postoperative subconjunctival 5-fluorouracil injections and success probability of trabeculectomy in Japanese: results of 5-year follow-up. Jpn J Ophthalmol. 92 ;36(2):158-68. OAG can’t be analyzed separately
Araujo SV, Bond JB, Wilson RP, Moster MR, Schmidt CM Jr, Spaeth GL. Long term effect of apraclonidine. Br J Ophthalmol. 95 ;79(12):1098-101. [pmid: 20935306]. Data not abstractable
Araujo SV, Spaeth GL, Roth SM, Starita RJ. A ten-year follow-up on a prospective, randomized trial of postoperative corticosteroids after trabeculectomy. Ophthalmology. 95 ;102(12):1753-9. Data not abstractable
Arcieri ES, Arcieri RS, Pereira AC, Andreo EG, Finotti IG, Sa Filho WF. Comparing the fixed combination brimonidine-timolol versus fixed combination dorzolamide-timolol in patients with elevated intraocular pressure. Medical KQ 3 or KQ 3 and KQ 6 only
Arcieri ES, Pereira ACA, Andreo EGV, Finotti IGA, Arcieri RS, Sa Filho WF. Fixed Combination Brimonidine-Timolol (Combigan®) versus Fixed Combination Dorzolamide-Timolol (Cosopt®) Each Given Twice Daily to Reduce Intraocular Pressure in Subjects With Open Angle Glaucoma or Ocular Hypertension. Meeting abstract
Arcieri ES, Pierre Filho PT, Wakamatsu TH, Costa VP. The effects of prostaglandin analogues on the blood aqueous barrier and corneal thickness of phakic patients with primary open-angle glaucoma and ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Ardjomand N, Ardjomand N, Komericki P. Efficacy of timolol hydrogel 01% in patients with primary open angle glaucoma and ocular hypertension. Wirkung von timolol hydrogel 01% bei patienten mit primarem offenwinkelglaukom und okularer hypertension. Foreign language
Arend KO, Raber T. Observational study results in glaucoma patients undergoing a regimen replacement to fixed combination travoprost 0.004%/timolol 0.5% in Germany. J Ocul Pharmacol Ther. 2008;24(4):414-20. [pmid: 18665813]. OAG can’t be analyzed separately
Arend O, Harris A, Remky A, Wenzel M, Redbrake C. Dorzolamide and retinal microcirculation in glaucoma with normal intraocular pressure. Meeting abstract
Arend O, Kaup M, Plange N, Remky A, Redbrake C. The intraocular pressure reducing effect by modification of non-penetrating sclerectomy with viscocanalostomy by a combination with amnion-implant and/or 5-Fluorouracil application in patients with glaucoma. Meeting abstract
Arend O, Plange N, Remky A, Redbrake C. Influence on Intraocular Pressure Following Deep Non Pentrating Sclerectomy and Viscocanalostomy in Combination With Amnion Implant and/or 5 Fluorourcil Application in Glaucoma Patients. Meeting abstract
Arend O, Wolter P, Huber K, Harris A, Remky A. Retinal Circulation after Timolol, Latanoprost or Dorzolamide Application in Newly Diagnosed Glaucoma Patients. Meeting abstract
Arias-Puente A, Batuelos J, Garcia-Saenz C, Ragai-Kamel N, Gili P. EFFICACY OF DEEP NON-PENETRATING SCLERECTOMY IN THE SURGICAL TREATMENT OF PRIMARY OPEN ANGLE GLAUCOMA. Meeting abstract
Arici MK, Sayici M, Toker M, Erdogan H, Topalkara A. A short term study of the additive effect of timolol and brimonidine on intraocular pressure. Eye (Lond). 2002;16(1):39-43. [pmid: 11913886]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Arieta Carlos Eduardo Leite, Barbosa Katia Borgia, Rocha Eduardo Melani, Castro Rosane Silvestre de, Jose Newton Kara. Pilocarpina a 2 por cento na prevengåo da elevagåo da pressåo intra-ocular pela aplicagåo de Neodymium Yag Laser em capsulotomia posterior. Foreign language
Arnavielle S, Lafontaine PO, Bidot S, Creuzot-Garcher C, D’Athis P, Bron AM. Corneal endothelial cell changes after trabeculectomy and deep sclerectomy. J Glaucoma. 2007;16(3):324-8. [pmid: 17438428]. It is not a RCT and has less than 100 patients
Arnold PN. No-stitch phacotrabeculectomy. J Cataract Refract Surg. 96 ;22(2):253-60. It is combined cataract/glaucoma surgery study published before April 2000
Arranz-Marquez E, Teus MA. Effect of age on the development of a latanoprost-induced increase in iris pigmentation. Ophthalmology. 2007;114(7):1255-8. [pmid: 17306877]. It is not a RCT and has less than 100 patients
Arrata M, Massin M, Sfeir T. A single dose of maleate of timolol given orally: the effect on the ocular pressure (author’s transl). Foreign language
Arrico L, Taverniti L, Donati S, Recupero SM. A retrospective study on the effects of laser trabeculoplasty in open-angle glaucoma: a 10-year follow-up. Acta Ophthalmol Scand Suppl. 2000;(232):57-8. [pmid: 11235541]. It is a case series
Artigas Alejandro. Implantes de drenaje en Glaucoma. Foreign language
Atanassov MA. Surgical treatment of glaucomas by trabeculectomy--indications and early results. Folia Med (Plovdiv). 2009;51(4):25-8. [pmid: 20232654]. It is not a RCT and has less than 100 patients, Data not abstractable
Atmaca LS, Simsek T. Efficacy of argon laser trabeculoplasty in primary open-angle and pseudoexfoliative glaucoma: Long-term follow-up. Ann Ophthalmol. 2001;33(3):216-220. It is a case series
Attanasio A, Baglio S, Quatrana M, Bartorelli L. Accelerated idioventricular rhythm associated to ophthalmic timolol/dorzolamide solution. Int J Cardiol. 2004;95(2–3):343-5. [pmid: 15193844]. It is a case series
Aung T, Chew PT, Oen FT, Chan YH, Thean LH, Yip L, Lim BA, Soh J, Seah SK. Additive effect of unoprostone and latanoprost in patients with elevated intraocular pressure. Br J Ophthalmol. 2002;86(1):75-9. [pmid: 11801508]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Aung T, Chew PT, Yip CC, Chan YH, See JL, Khng CG, Hoh ST, Ng LH, Lee HM. A randomized double-masked crossover study comparing latanoprost 0.005% with unoprostone 0.12% in patients with primary open-angle glaucoma and ocular hypertension. Am J Ophthalmol. 2001;131(5):636-42. [pmid: 11336940]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Auw-Hädrich C, Bömer TG, Funk J. LIMBUS-BASED VERSUS FORNIX-BASED FLAP IN TRABECULECTOMY: LONG-TERM RESULTS AFTER 6 – 9 YEARS. Meeting abstract
Auw-Haedrich C, Funk J, Boemer TG. Long-term results after filtering surgery with limbal-based and fornix-based conjunctival flaps. Ophthalmic Surgery and Lasers. 98 ;29(7):575-580. Data not abstractable
Avakian A, Renier SA, Butler PJ. Adverse effects of latanoprost on patients with medically resistant glaucoma. Arch Ophthalmol. 98 ;116(5):679-80. It is a case series
AvaliagPo das alteragões anatómicas e funcionais ap£s a trabeculectomia. Foreign language
Avunduk AM, Sari A, Akyol N, Ozturk O, Kapicioglu Z, Erdol H, Imamoglu HI. The one-month effects of topical betaxolol, dorzolamide and apraclonidine on ocular blood flow velocities in patients with newly diagnosed primary open-angle glaucoma. Ophthalmologica. 2001;215(5):361-5. [pmid: 11528262]. Does not address any key questions
Aykan U, Bilge AH, Akin T, Certel I, Bayer A. Laser suture lysis or releasable sutures after trabeculectomy. J Glaucoma. 2007;16(2):240-5. [pmid: 17473738]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Az£car Gabe Ver nica, Ivette Burgos L, Paola Andonie D. TrabeculectomÆa: una retrospectiva de seguimiento de 150 casos. Foreign language
Aziz S, McConnachie A, Montgomery DMI. Initial experience of the Ahmed valved implant in the management of refractory glaucoma [27]. Eye. 2007;21(2):278-279. [pmid: 16858432]. No original data (e.g., systematic review, narrative review, editorial, letter)
Azuara-Blanco A, Katz LJ, Spaeth GL, Wilson RP, Moster MR, Flartey KJ. Effect of latanoprost on intraocular pressure in patients with glaucoma on maximal tolerated medical treatment. Br J Ophthalmol. 97 ;81(12):1116. OAG can’t be analyzed separately
Azuara-Blanco A, Spaeth GL, Augsburger JJ. Oral prednisone in guarded filtration procedures supplemented with antimetabolites. Ophthalmic surgery and lasers. 99 ;30(2):126-32. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Babic N, Andreic V, Miljkovic A, Canadanovic V, Barisic S. Adjunctive therapy with brinzolamide in patients on travoprost treatment. Foreign language
Babighian S, Caretti L, Tavolato M, Cian R, Galan A. Excimer laser trabeculotomy vs 180 degrees selective laser trabeculoplasty in primary open-angle glaucoma. A 2-year randomized, controlled trial. Eye (London, England). 2010;24(4):632-8. Other (specify):not FDA approved
Babighian SR, Tavolato M, Galan A. Comparison of Excimer Laser Trabeculotomy (ELT) versus Selective Laser Trabeculoplasty (SLT) in the Treatment of Primary Open-Angle Glaucoma. 18 Months of Follow-Up. Meeting abstract
Babushkin AE. The influence of the fixation of the scleral flap on the hypotensive effect of trabeculectomy. Foreign language
Bacharach J, Delgado MF, Iwach AG. Comparison of the efficacy of the fixed-combination timolol/dorzolamide versus concomitant administration of timolol and dorzolamide. J Ocul Pharmacol Ther. 2003;19(2):93-6. [pmid: 12804053]. It is not a RCT and has less than 100 patients
Bacharach J, Varma R, Schenker H, Caprioli J, Liu CC, Batoosingh AL. Masked, Randomized, Parallel Comparison of IOP-Lowering Efficacy after Switching to Bimatoprost 0.03% vs Continuing with Latanoprost 0.005%. Meeting abstract
Baez KA, Spaeth GL. Argon laser trabeculoplasty controls one third of patients with progressive, uncontrolled open-angle glaucoma for five years. Trans Am Ophthalmol Soc. 91 ;89:47-56. discussion 56–8. OAG can’t be analyzed separately
Baez KA, Ulbig MW, McHugh D, Holz FW, Spaeth GL. Long-term results of ab externo neodymium:YAG cyclophotocoagulation. Ger J Ophthalmol. 94 ;3(6):395-9. Data not abstractable
Bafa M, Georgopoulos G, Mihas C, Stavrakas P, Papaconstantinou D, Vergados I. The effect of prostaglandin analogues on central corneal thickness of patients with chronic open-angle glaucoma: a 2-year study on 129 eyes. Acta Ophthalmol. 2009. Does not address any key questions
Bagli E, Gartzios C, Asproudis I, Kitsos G. Comparison of one-site versus two-site phacotrabeculectomy without the use of antimetabolites intraoperatively in patients with pseudoexfoliation glaucoma and primary open-angle glaucoma. Included in Gdih 2011
Baiza-Duran LM, Alvarez-Delgado J, et al. The efficacy and safety of two fixed combinations: timolol-dorzolamide-brimonidine versus timolol-dorzolamide. A prospective, randomized, double-masked, multi-center, 6-month clinical trial. Unique comparators
Bakutkin VV, Saprykin PI. The efficacy of optimized sinusotrabeculectomy in primary open-angle glaucoma based on the late results data. Oftalmol Zh. 90(7):414-6. Does not address any key questions
Balazsi AG, Saheb NE, Kasner OP, Overbury O, Faubert J. THE EFFECTS OF TIMOLOL MALEATE ON STATIC VISUAL FIELDS, TEMPORAL MODULATION FIELDS, AND SPATIAL CONTRAST SENSITIVITY IN EARLY GLAUCOMA. Meeting abstract
Balazsil AG, Collin C, Kasner OP, Overbury O, Saheh NE, Toussignant P. THE EFFECT OF LEVOBUNOLOL ON VISUAL SENSITIVITY: A RANDOMIZED DOUBLE-MASKED CLINICAL TRIAL. Meeting abstract
Banitt M, Juzych MS, Chopra V, Hughes BA, Kim C. The effect of the timing of scleral flap suture release on the safety and long-term success of phacotrabeculectomy. Am J Ophthalmol. 2006;141(4):742-4. [pmid: 16564814]. Does not address any key questions
Bansal A, Ramanathan US. Sudden lowering of intraocular pressure may cause retinal bleeding by three different mechanisms. Br J Ophthalmol. 2008;92(8):1158-9. [pmid: 18653616]. No original data (e.g., systematic review, narrative review, editorial, letter)
Barad P, Carlson DW, Alward WL. A RANDOMIZED STUDY OF MITOMYCIN AUGMENTATION IN COMBINED PHACOEMULSIFICATION AND TRABECULECTOMY. Meeting abstract
Barber BL, Santanello NC. Relating spontaneous adverse experience reports to scores on a questionnaire querying tolerability. Excluded drug
Barnebey H, Kwok SY. Patients’ acceptance of a switch from dorzolamide to brinzolamide for the treatment of glaucoma in a clinical practice setting. Clin Ther. 2000;22(10):1204-12. [pmid: 11110231]. Other (specify):Not a RCT
Barnebey H. LONG-TERM EFFICACY OF BRIMONIDINE ON I0P LOWERING. Meeting abstract
Barnebey HS, Pettigrew SC, Mallick S, Andrew RM, Sullivan EK, Wells DT, Landry TA, Bergamini MVW, Robertson SM. Travoprost 0.004%/Timolol 0.5% Study Group. Three Month Comparison of the Safety and Efficacy of Travoprost 0.004%/Timolol 0.5% Ophthalmic Solution to TRAVATAN® and Timolol 0.5%. Meeting abstract
Barnebey HS, Mallick S, Andrew RM, Wells DT, Landry TA, Bergamini MVW. Six Week Comparison Safety and Efficacy of Travoprost 0.004%/Timolol 0.5% Ophthalmic Solution to TRAVATAN® and Timolol 0.5%. Meeting abstract
Barnebey HS, Orengo-Nania S, Flowers BE, Samples J, Mallick S, Landry TA, Bergamini MV. The safety and efficacy of travoprost 0.004%/timolol 0.5% fixed combination ophthalmic solution. Am J Ophthalmol. 2005;140(1):1-7. [pmid: 15990081]. Does not address any key questions
Barnebey H, Mallick S, Andrew RM, Wells D, Landry TA, Bergamini MVA, Wax MB, Robertson SM. Efficacy of Extravan (Travoprost 0.004%/Timolol 0.5% Ophthalmic Solution) Compared to Either Travatan or Timolol 0.5% Alone. Meeting abstract
Barnes EA, Murdoch IE, Subramaniam S, Cahill A, Kehoe B, Behrend M. Neodymium:yttrium-aluminum-garnet capsulotomy and intraocular pressure in pseudophakic patients with glaucoma. Ophthalmology. 2004;111(7):1393-7. [pmid: 15234143]. Data not abstractable
Barnes RM, Mora JS, Best SJ. Beta radiation as an adjunct to low-risk trabeculectomy. Kirwan 2009
Barnes SD, Campagna JA, Dirks MS, Doe EA. Control of intraocular pressure elevations after argon laser trabeculoplasty: comparison of brimonidine 0.2% to apraclonidine 1.0%. Ophthalmology. 99 ;106(10):2033-7. Does not address any key questions
Barnes SD, Dirks MS, Doe EA, Campagna JA, Zimmerman T. CONTROL OF INTRAOCULAR PRESSURE SPIKES AFTER ARGON LASER TRABECULOPLASTY: BRIMNONIDINE 0.2% VS. APRACLONIDINE 1.0%. Meeting abstract
Barnett EM, Fantin A, Wilson BS, Kass MA, Gordon MO. The Incidence of retinal vein occlusion in the ocular hypertension treatment study. Systematic review
Barraquer C. Double-blind trial of timolol against pilocarpine in glaucoma. ESTUDIO DOBLE CIEGO TIMOLOL-PILOCARPINA. Foreign language
Barreiro Jefferson, Pereira Telma, Lima Vagner Loduca, Assis Carlos Augusto Moya. Alteragões oculares ap£s capsulotomia posterior com nd: yag laser: estudo comparativo com e sem uso de colÆrios timolol 0, 5: e dexametasona 0, 1. Foreign language
Barretto Caroline Amorim, RWgo PatrÆcia, Santos Rodrigo Almeida Vieira, Toscano Daniela, Brandt Carlos Teixeira, Dantas Ronaldo Rodrigues. FungPo pulmonar em portadores de esquistossomose mansõnica hepatoesplWnica, usubrios de colÆrio de timolol a 0,5por cento. Foreign language
Barrisbana4flaxCraven ER, Sherwood MB, DuBiner HB. Twelve-Month Randomized Comparison of Fixed Combination Brimonidine 0.2%/Timolol 0.5% With Each Component as Monotherapy. Meeting abstract
Bartkowska-Orlowska M, Pecoldowa K. Experiences with timolol use in cases of glaucoma (author’s transl). Foreign language
Bartlett JD, Evans DW. Contrast Sensitivity Improvements in Brimonidine-Treated Primary Open-Angle Glaucoma Patients Suggest a Neuroprotective Mechanism. Meeting abstract
Bartlett JD, Boan K, Corliss D, Gaddie IB. Efficacy of silicone punctal plugs as adjuncts to topical pharmacotherapy of glaucoma--a pilot study. Punctal Plugs in Glaucoma Study Group. J Am Optom Assoc. 96 ;67(11):664-8. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Bartlett J, Olivier M, Richardson T, Whitaker R, Greenidge K, Pensy D. CENTRAL NERVOUS SYSTEM EFFECTS OF CARTEOLOL HYDROCHLORIDE AND TIMOLOL MALEATE IN BLACK WOMEN. Meeting abstract
Bartlett J, Than T, Bergamini M. EFFICACY AND SAFETY OF TRAVOPROST COMPARED TO LATANOPROST AND TIMOLOL IN PATIENTS WITH OPEN-ANGLE GLAUCOMA (OAG) OR OCULAR HYPERTENSION (OH). Meeting abstract
Barton K, Gedde SJ, Budenz DL, Feuer WJ, Schiffman J. Ahmed Baerveldt Comparison Study Group. The Ahmed Baerveldt Comparison Study methodology, baseline patient characteristics, and intraoperative complications. Ophthalmology. 2011;118(3):435-42. [pmid: 20932581]. OAG can’t be analyzed separately
Barton K. Bleb dysesthesia. J Glaucoma. 2003;12(3):281-4. [pmid: 12782850]. Does not address any key questions
Barton K, Franks WA, Vunce C, Lauande-Pimentel R, Maurino V, Pavesio CE. Long-term outcome of MMC vs 5FU trabeculectomy in uveitic glaucoma. Meeting abstract
Barton K, Gedde SJ, Budenz DL, Feuer WJ, Schiffman J. The Ahmed Baerveldt Comparison Study Methodology, Baseline Patient Characteristics, and Intraoperative Complications. Ophthalmology. 2010. OAG can’t be analyzed separately
Barton K, Gedde SJ, Budenz DL, Feuer WJ, Schiffman J. The Ahmed Baerveldt Comparison Study methodology, baseline patient characteristics, and intraoperative complications. Ophthalmology. 2011;118:435-42. [pmid: 20932581]. OAG can’t be analyzed separately
Batchelor ED, O’Day DM, Shand DG, Wood AJ. Interaction of topical and oral timolol in glaucoma. Ophthalmology. 79 ;86(1):60-5. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Bateman DN, Clark R, Azuara-Blanco A, Bain M, Forrest J. The effects of new topical treatments on management of glaucoma in Scotland: an examination of ophthalmological health care (Brief record). British Journal of Ophthalmology. 2002;86(5):551-554. [pmid: 11973253]. Does not address any key questions
Bateman DN, Clark R, Azuara-Blanco A, Bain M, Forrest J. The impact of new drugs on management of glaucoma in Scotland: observational study. BMJ. 2001;323(7326):1401-2. [pmid: 11744564]. Does not address any key questions
Batra JD, Patnaik B, Singh G, Kalsi R, Jain BS, Agarwal DP. An investigation of the mechanism of function of trabeculectomy (operation). Indian J Ophthalmol. 81 ;29(3):173-6. Does not address any key questions
Batterbury M, Wishart PK. Is high initial aqueous outflow of benefit in trabeculectomy?. EYE. 93 ;7(1):109-112. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Battista R, Yan DB. DBYAN Medicine Professional Corportation. Comparison of 24-Hour Post-Dose Efficacy of Travoprost and Latanoprost When Morning-Dosed in Open-Angle Glaucoma. Meeting abstract
Bauchiero L, Demarie A, Belli L, Brogliatti B. Deep sclerectomy and viscocanalostomy: critical revision of the results obtained during the learning curve. Acta Ophthalmol Scand Suppl. 2002;236:64-6. [pmid: 12390152]. It is not a RCT and has less than 100 patients
Baudouin C, Rouland JF, Nordmann JP, Bron A, Pelen F. Efficacy of first- or second-line latanoprost on intraocular pressure and ocular symptoms in patients with open-angle glaucoma or ocular hypertension. Foreign language
Baumert S, Pillunat LE, Meitinger C, Lang GK. EFFECT OF LASER TRABECULOPLASTY AND TRABECULECOTMY ON OCULAR HEMODYNAMICS IN PRIMARY OPEN ANGLE GLAUCOMA. Meeting abstract
Bayer AU, Erb C, Ferrari F, Knorr M, Thiel HJ. The Tubingen Glaucoma Study. Glaucoma filtering surgery--a retrospective long-term follow-up of 254 eyes with glaucoma. Ger J Ophthalmol. 95 ;4(5):289-93. Data not abstractable
Bayer A, Erdem U, Mumcuoglu T, Akyol M. Two-site phacotrabeculectomy versus bimanual microincision cataract surgery combined with trabeculectomy. Eur J Ophthalmol. 2009;19(1):46-54. [pmid: 19123148]. Other (specify):Control group is not an intervention of interest
Bayer A, Henderer JD, Kwak T, Myers J, Fontanarosa J, Spaeth GL. Clinical predictors of latanoprost treatment effect. J Glaucoma. 2005;14(4):260-3. [pmid: 15990603]. It is a case series
Bayer A, Weiler W, Oeverhaus U, Skrotzki FE, Stewart WC. Two-year follow-up of latanoprost 0.005% monotherapy after changing from previous glaucoma therapies. J Ocul Pharmacol Ther. 2004;20(6):470-8. [pmid: 15684807]. Data not abstractable
Bazarov KhB. Effectiveness of trabeculectomy. Foreign language
Beano F, Orgul S, Stumpfig D, Gugleta K, Flammer J. An evaluation of the effect of unoprostone isopropyl 0.15% on ocular hemodynamics in normal-tension glaucoma patients. Graefes Arch Clin Exp Ophthalmol. 2001;239(2):81-6. [pmid: 11372549]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Bearn PE. Disappearance of staghorn calculi following withdrawal of treatment with acetazolamide. Br J Urol. 89 ;63(3):329. It is a case series
Beatty S, Kheterpal S, Eagling EM, O’Neill EC. Day-case trabeculectomies: safety and efficacy. Acta Ophthalmol Scand. 96 ;74(2):132-4. Does not address any key questions
Bec P, Arne JL, Secheyron P, Fontan P, Mialhe JP. Our experience with timolol in the treatment of open-angle glaucoma. Foreign language
Bechetoille A. When and how should one operate on primary open-angle glaucoma?. Annee Ther Clin Ophtalmol. 86 ;37:255-64. No original data (e.g., systematic review, narrative review, editorial, letter)
Bechetoille A, Denis P, Nordmann JP, Sellem E, Valtot F. Chronic open-angle glaucoma. Foreign language
Becker HI, Walton RC, Diamant JI, Zegans ME. Anterior uveitis and concurrent allergic conjunctivitis associated with long-term use of topical 0.2% brimonidine tartrate. Arch Ophthalmol. 2004;122(7):1063-6. [pmid: 15249377]. It is a case series
Beckers HJ, Schouten JS, Webers CA, van der Valk R, Hendrikse F. Side effects of commonly used glaucoma medications: comparison of tolerability, chance of discontinuation, and patient satisfaction. Graefes Arch Clin Exp Ophthalmol. 2008;246(10):1485-90. [pmid: 18575878]. Other (specify): unable to abstract OAG; good PRO
Beckman H, Meinert CL, Ritch R, Sternberg AL, Vela-Thomas MA. The Glaucoma Laser Trial (GLT). 2. Results of argon laser trabeculoplasty versus topical medicines. Duplicate
Beehler CC, Stewart WC, Macdonald DK, Croyle TA, Ostrov CS, Rosanelli EG, Crandall AS, Iacono TL, Lue JC, Kelley EP. A Comparison of the Ocular Hypotensive Efficacy of Twice-Daily 0.25% Levobunolol to 0.5% Timolol in Patients Previously Treated with 0.5% Timolol. Medical KQ 3 or KQ 3 and KQ 6 only
Behrens-Baumann W, Kimmich F, Walt JG, Lue J. A comparison of the ocular hypotensive efficacy and systemic safety of 0.5% levobunolol and 2% carteolol. Unique comparators
Bellucci R, Luraschi M. Trabeculectomy and phacoemulsification: one-way and two-way approach compared after one year. Acta Ophthalmol Scand Suppl. 98(227):50-1. It is combined cataract/glaucoma surgery study published before April 2000
Bellucci R, Perfetti S, Babighian S, Morselli S, Bonomi L. Filtration and complications after trabeculectomy and after phacotrabeculectomy. Acta Ophthalmol Scand Suppl. 97(224):44-5. It is combined cataract/glaucoma surgery study published before April 2000
Belyea DA, Dan JA, Stamper RL, Lieberman MF, Spencer WH. Late onset of sequential multifocal bleb leaks after glaucoma filtration surgery with 5-fluorouracil and mitomycin C. Am J Ophthalmol. 97 ;124(1):40-5. [pmid: 6696018]. It is a case series
Benedict WL, Shami M. Impending macular hole associated with topical pilocarpine. Am J Ophthalmol. 92 ;114(6):765-6. It is a case series
Benedikt O, Zirm M, Harnoncourt K. Relations between metabolic acidosis and intraocular pressure after inhibition of carboanhydrase with acetazolamide (author’s transl). Albrecht Von Graefes Arch Klin Exp Ophthalmol. 74 ;190(3):247-55. It is a case series
BenEzra D, Chirambo MC. Trabeculectomy. Ann Ophthalmol. 78 ;10(8):1101-5. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Bengtsson B, Heijl A. A long-term prospective study of risk factors for glaucomatous visual field loss in patients with ocular hypertension. J Glaucoma. 2005;14(2):135-8. [pmid: 15741815]. Does not address any key questions
Bengtsson B, Heijl A. Lack of long-term drift in timolol’s effectiveness in patients with ocular hypertension. Medical KQ 3 only
Bensinger RE, Keates EU, Gofman JD, Novack GD, Duzman E. Levobunolol. A three-month efficacy study in the treatment of glaucoma and ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Bensinger R, Shin DH, Kass MA, Podos SM, Becker B. Pilocarpine ocular inserts. Invest Ophthalmol. 76 ;15(12):1008-10. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Bergea B, Svedbergh B. Primary argon laser trabeculoplasty vs. pilocarpine. Short-term effects. Acta Ophthalmol (Copenh). 92 ;70(4):454-60. Data not abstractable
Bergea B, Bodin L, Svedbergh B. Impact of intraocular pressure regulation on visual fields in open-angle glaucoma. Excluded drug
Bergea B, Bodin L, Svedbergh B. Primary argon laser trabeculoplasty vs pilocarpine. II: Long-term effects on intraocular pressure and facility of outflow. Study design and additional therapy. Acta Ophthalmol (Copenh). 94 ;72(2):145-54. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Bergea B, Bodin L, Svedbergh B. Primary argon laser trabeculoplasty vs pilocarpine. III. Long-term effects on visual fields. Acta Ophthalmol Scand. 95 ;73(3):207-15. Does not address any key questions
Bergea B, Bodin L, Svedbergh B. Primary argon laser trabeculoplasty vs pilocarpine. IV. Long-term effects on optic nerve head. Acta Ophthalmol Scand. 95 ;73(3):216-21. Does not address any key questions
Berger WE. Betaxolol in patients with glaucoma and asthma. Am J Ophthalmol. 87 ;103(4):600-1. No original data (e.g., systematic review, narrative review, editorial, letter)
Bergstrand IC, Heijl A, Harris A. Dorzolamide and ocular blood flow in previously untreated glaucoma patients: a controlled double-masked study. Medical KQ 3 or KQ 3 and KQ 6 only
Bernstein P. A comparison of latanoprost, bimatoprost, and travoprost in patients with elevated intraocular pressure: a 12-week, randomized, masked-evaluator, multicenter study. Am J Ophthalmol. 2004;137(2):387-8. author reply 388–9. [pmid: 14962451]. No original data (e.g., systematic review, narrative review, editorial, letter)
Berson FG, Epstein DL. Separate and combined effects of timolol maleate and acetazolamide in open-angle glaucoma. Am J Ophthalmol. 81 ;92(6):788-91. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Berson FG, Epstein DL, Grant WM, Hutchinson BT, Dobbs PC. Acetazolamide dosage forms in the treatment of glaucoma. Arch Ophthalmol. 80 ;98(6):1051-4. It is not a RCT and has less than 100 patients
Best UP, Domack H, Schmidt V. Long-term results after selective laser trabeculoplasty -- a clinical study on 269 eyes. Klin Monbl Augenheilkd. 2005;222(4):326-31. [pmid: 15844043]. It is a case series
Best UP, Domack H, Schmidt V. Pressure reduction after selective laser trabeculoplasty with two different laser systems and after argon laser trabeculoplasty--a controlled prospective clinical trial on 284 eyes. Foreign language
Beuerle S, Philippin H, Funk J. Combined cataract and glaucoma surgery. Trabeculectomy vs Erb:YAG goniotomy. Foreign language
Bevin TH, Molteno ACB, Herbison P. Otago glaucoma surgery outcome study: Long-term results of 841 trabeculectomies. Clin Exp Ophthalmol. 2008;36(8):731-737. OAG can’t be analyzed separately
Bhandari A, Crabb DP, Poinoosawmy D, Fitzke FW, Hitchings RA, Noureddin BN. Effect of surgery on visual field progression in normal-tension glaucoma. Ophthalmology. 97 ;104(7):1131-7. It is not a RCT and has less than 100 patients
Bhatt R, Whittaker KW, Appaswamy S, Desai A, Fitt A, Sandramouli S. Prospective survey of adverse reactions to topical antiglaucoma medications in a hospital population. Eye (Lond). 2005;19(4):392-5. [pmid: 15297863]. It is not a RCT and has less than 100 patients
Bhavnani V, Cantor L, Hoop J, Dobler A, Sanders S, Samuelson T, Sponsel W. PHACOEMULSIFICATION, INTRAOCULAR LENS IMPLANTATION, AND TRABECULECTOMY, WITH OR WITHOUT MITOMYCIN C. Meeting abstract
Bhistikul RB, Dreyer EB. A PROSPECTIVE ANALYSIS OF ANTERIOR SEGMENT CHANGES AT ONE YEAR AFTER M1TOMYCIN C OR 5-Fluorouracil SUPPLEMENTED TRABECULECTOMY. Meeting abstract
Bhojwani SC, Jones DK. Comparative study of aqueous and oily pilocarpine in the production of ocular hypotension. Br J Ophthalmol. 81 ;65(8):530-2. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Bhorade AM, Wilson BS, Gordon MO, Palmberg P, Weinreb RN, Miller E, Chang RT, Kass MA. Ocular Hypertension Treatment Study Group. The utility of the monocular trial: data from the ocular hypertension treatment study. Ophthalmology. 2010;117(11):2047-54. [pmid: 20619460]. Other (specify): Assessment of statistical method not effectiveness
Bhorade AM, Wilson BS, Gordon MO, Palmberg P, Weinreb RN, Miller E, Chang RT, Kass MA. The utility of the monocular trial: data from the ocular hypertension treatment study. Systematic review
Bhosle MJ, Reardon G, Camacho FT, Anderson RT, Balkrishnan R. Medication adherence and health care costs with the introduction of latanoprost therapy for glaucoma in a medicare managed care population (Brief record). American Journal of Geriatric Pharmacotherapy. 2007;5(2):100-111. [pmid: 17719512]. Other (specify):adherence rate
Bhosle MJ, Reardon G, Camacho FT, Anderson RT, Balkrishnan R. Medication adherence and health care costs with the introduction of latanoprost therapy for glaucoma in a Medicare managed care population. Am J Geriatr Pharmacother. 2007;5(2):100-11. [pmid: 17719512]. Does not address any key questions
Bias MF, Barad JP, Carlson DW, Alward WLM. THREE YEAR FOLLOW-UP OF MITOMYCIN VS. PLACEBO IN COMBINED PHACOEMULSIFICATION AND TRABECULECTOMY. Meeting abstract
Bifani M, Ragucci A, Giacoia P, Iuliano A, Intravaja A, Costagliola C. Brimonidine tartrate and intraocular pressure. A preliminary study on concentration and duration of action in healthy volunteers and in patients with primary open angle glaucoma. Effetto della brimonidina sulla pressione oculare. Studio sulla concentrazione ottimale e sulla durata di azione in volontari sani ed in pazienti affetti da glaucoma primario ad angolo aperto. Foreign language
Bindlish R, Condon GP, Schlosser JD, D’Antonio J, Lauer KB, Lehrer R. Efficacy and safety of mitomycin-C in primary trabeculectomy: five-year follow-up. Ophthalmology. 2002;109(7):1336-41. discussion 1341–2. [pmid: 12093659]. OAG can’t be analyzed separately
Birmingham AT, Galloway NR, Walker DA. Intraocular pressure reduction in chronic simple glaucoma by continuous infusion of dilute pilocarpine solution. Br J Ophthalmol. 79 ;63(12):808-12. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Birnbacher T. 46 years of experience in the conservative treatment of glaucoma. Klin Monbl Augenheilkd. 66 ;148(4):490-500. It is not a RCT and has less than 100 patients
Birt CM. Quality of diurnal intraocular pressure control in primary open-angle patients treated with latanoprost compared with surgically treated glaucoma patients: A prospective trial. Evid.-Based Ophthalmol. 2008;9(4):252-253. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Birt CM. Selective laser trabeculoplasty retreatment after prior argon laser trabeculoplasty: 1-year results. Can J Ophthalmol. 2007;42(5):715-9. [pmid: 17891199]. Does not address any key questions
Birt CM, Buys YM, Ahmed II, Trope GE. Prostaglandin efficacy and safety study undertaken by race (The Pressure study). Medical KQ 3 or KQ 3 and KQ 6 only
Bischoff P. Experiences with timolol in treatment of glaucoma (author’s transl). Klin Monbl Augenheilkd. 78 ;173(2):202-7. It is not a RCT and has less than 100 patients
Bischoff P. Long-term results with timolol. Klin Monbl Augenheilkd. 80 ;176(4):551-4. It is a case series
Bischoff P. Experiences with Timolol in treatment of glaucoma. ERFAHRUNGEN MIT TIMOLOL IN DER GLAUKOMTHERAPIE. Duplicate
Bissig A, Rivier D, Zaninetti M, Shaarawy T, Mermoud A, Roy S. Ten years follow-up after deep sclerectomy with collagen implant. J Glaucoma. 2008;17(8):680-6. [pmid: 19092466]. Other (specify):No control
Blasini M, Shields MB. Apraclonidine hydrochloride as an adjunct to timolol maleate therapy. Journal of Glaucoma. 92 ;1(3):148-52. Does not address any key questions
Blaul G. Local beta-blockers during pregnancy. Klin Monbl Augenheilkd. 81 ;179(2):128-9. It is a case series
Bleckmann H, Dorow P. Effect of various beta blockers on intraocular pressure and ventilation. Fortschr Ophthalmol. 86 ;83(5):567-9. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Bleckmann H, Dorow P. Indications and contraindications of beta blockaders in the treatment of glaucoma. Dtsch Med Wochenschr. 84 ;109(5):180-3. [pmid: 13619416]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Bleckmann H, Dorow P. Therapeutic consequences of glaucoma treatment with different beta blockers in patients with obstructive respiratory tract diseases. Klin Monbl Augenheilkd. 86 ;188(6):568-72. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Bleckmann H, Dorow P. Treatment with betaxolol and placebo eyedrops in patients with glaucoma and reactive airway diseases. Klin Monbl Augenheilkd. 87 ;191(3):199-202. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Bleckmann H, Dorow P. Therapeutic consequences of glaucoma treatment with different beta-blockers in patients with obstructive respiratory tract disease. THERAPEUTISCHE KONSEQUENZEN EINER GLAUKOMBEHANDLUNG MIT UNTERSCHIEDLICHEN BETABLOCKERN BEI PATIENTEN MIT OBSTRUKTIVER ATEMWEGSERKRANKUNG. foreign language
Blika S, Saunte E. Timolol maleate in the treatment of glaucoma simplex and glaucoma capsulare. A three-year follow up study. Unique comparators
Blini M, Rossi GC, Trabucchi G, Curatola MR, David A, Radaelli R, Merlo G, Ratiglia R. Ocular hypotensive efficacy and safety of travoprost 0.004% in inadequately controlled primary open-angle glaucoma or ocular hypertension: short-term, multicenter, prospective study. Curr Med Res Opin. 2009;25(1):57-63. [pmid: 19210139]. Other (specify):Study design does not match KQ (KQ3)
Blondeau P, Rousseau JA. Allergic reactions to brimonidine in patients treated for glaucoma. Can J Ophthalmol. 2002;37(1):21-6. [pmid: 11865954]. Data not abstractable
Blondeau P. Sodium hyaluronate in trabeculectomy: a retrospective study. Can J Ophthalmol. 84 ;19(7):306-9. Other (specify):Not an intervention of interest
Blondeau P, Roberge JF, Asselin Y. Long-term results of low power, long duration laser trabeculoplasty. Am J Ophthalmol. 87 ;104(4):339-42. It is not a RCT and has less than 100 patients
Bloom HR, Cech JM, Eston AB, Finegan JT, Gingold MP, Meyer L, Varr WF, Weinberg DA, Wilson C, Zalta AH. Additive effect of betaxolol and epinephrine in primary open angle glaucoma. Arch Ophthalmol. 87 ;105(10):1317-8. No original data (e.g., systematic review, narrative review, editorial, letter)
Bloom PA, Noureddin BN, Sharma K, Hitchings RA, Khaw PT. A Matched Comparison Between Tube Surgery, Nd:YAG and Diode Laser Cyclophotocoagulation in the Management of Refractory Glaucoma. Meeting abstract
Bloom PA, Tsai JC, Sharma K, Miller MH, Rice NS, Hitchings RA, Khaw PT. “Cyclodiode”. Trans-scleral diode laser cyclophotocoagulation in the treatment of advanced refractory glaucoma. Ophthalmology. 97 ;104(9):1508-19. discussion 1519–20. It is a case series
Bloomberg LB. Modified trabeculectomy/trabeculotomy with no-stitch cataract surgery. J Cataract Refract Surg. 96 ;22(1):14-22. It is combined cataract/glaucoma surgery study published before April 2000
Bluestein E, Stewart W. TIGHT VERSUS LOOSE SCLERAL FLAP SUTURE CLOSURE IN TRABECULECTOMY SURGERY. Meeting abstract
Bluestein EC, Stewart WC. Tight versus loose scleral flap closure in trabeculectomy surgery. Doc Ophthalmol. 93 ;84(4):379-85. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Bluestein EC, Stewart WC. Trabeculectomy with 5-fluorouracil vs single-plate Molteno implantation. Ophthalmic Surg. 93 ;24(10):669-73. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Blumetti B, Brodell RT, Helms SE, Brodell LP, Bredle DL. Contact dermatitis to levobunolol eyedrops superimposed on IgE-mediated rhinoconjunctivitis. Ann Allergy Asthma Immunol. 2006;97(6):817-8. [pmid: 17201244]. It is a case series
Blyth CPJ, Moriarty AP, McHugh JDA. Diode laser trabeculoplasty versus argon laser trabeculoplasty in the control of primary open angle glaucoma. Rolim de Moura 2009
Bobrow JC. Cataract extraction and lens implantation with and without trabeculectomy: an intrapatient comparison. Trans Am Ophthalmol Soc. 98 ;96:521-56. It is combined cataract/glaucoma surgery study published before April 2000
Bobrow JC. Prospective intrapatient comparison of extracapsular cataract extraction and lens implantation with and without trabeculectomy. Am J Ophthalmol. 2000;129(3):291-6. [pmid: 10704542]. It is combined cataract/glaucoma surgery study published before April 2000
Boger WP III, Steinert R, Puliafito C, Langston pD. Long-term experience with timolol ophthalmic solution in patients with open-angle glaucoma. Letter to the editor
Boger WP III, Steinert R, Puliafito C, Pavan Langston D. Timolol and pilocarpine ophthalmic solutions in therapy of open angle glaucoma: a double blind clinical study. INVEST.OPHTHAL.VISUAL SCI. 77 ;16(sup):109-110. Other (specify):pilocarpine
Boger WP 3rd, Steinert RF, Puliafito CA, Pavan-Langston D. Clinical trial comparing timolol ophthalmic solution to pilocarpine in open-angle glaucoma. Excluded drug
Boger WP 3rd. Timolol: short term “escape” and long term “drift”. Ann Ophthalmol. 79 ;11(8):1239-42. No original data (e.g., systematic review, narrative review, editorial, letter)
Bojic L, Bagatin J, Ivanisevic M, Hozo I, Racic G, Karelovic D. Influence of betaxolol and timolol on the venous tone in glaucoma patients. Medical KQ 3 only
Bojic L, Mandic Z, Novak-Laus K, Sonicki Z, Karelovic D. A study of replacement of timolol-pilocarpine with latanoprost in pseudoexfoliation glaucoma. Coll Antropol. 2003;27(2):729-34. [pmid: 14746165]. Other (specify):Not a drug currently used
Boles Carenini B, Boldrini E, Brogliatti B. Real advantages of preservative-free preparations in special containers for long-term glaucoma therapy. Acta Ophthalmol Scand Suppl. 2002;236:57-9. [pmid: 12390147]. No original data (e.g., systematic review, narrative review, editorial, letter)
Boles Carenini B, Brogliatti B, Dorigo MT, Vadala G, Protti R, Bellone A. Prepared association of metipranolol 0.1% + pilocarpine 2% and of timolol 0.5% + pilocarpine 2%. Comparison of clinical efficacy and topical tolerability in the treatment of patients affected by POAG tonometrically uncontrolled with beta-blocker alone (two-centre study). Acta Ophthalmol Scand Suppl. 97(224):54-5. Data not abstractable
Bonanomi MT, Sunaga AH, Suzanna R J·nior. Cirurgia filtrante no glaucoma agudo primario. Resultados cirurgicos. Foreign language
Bonomi L, Marchini G, de Franco I, Perfetti S. Prospective study of the lens changes after trabeculectomy. Dev Ophthalmol. 89 ;17:97-100. It is not a RCT and has less than 100 patients
Bonomi L, Marchini G, Marraffa M, De Franco I, Perfetti S, Ferri E. Effects of the association of alpha and beta-blocking agents in glaucoma. J Ocul Pharmacol. 92 ;8(4):279-83. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Bonomi L, Perfetti S, Bellucci R, Massa F, Noya E. Ocular hypotensive action of labetalol in rabbit and human eyes. Albrecht Von Graefes Arch Klin Exp Ophthalmol. 81 ;217(3):175-81. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Boozman FW 3rd, Carriker R, Foerster R, Allen RC, Novack GD, Batoosingh AL. Long-term evaluation of 0.25% levobunolol and timolol for therapy for elevated intraocular pressure. Unique comparators
Borggrefe J, Grehn F, Lieb WE. COMBINED CATARACT - GLAUCOMA SURGERY: A PROSPECTIVE RANDOMIZED COMPARISON OF TWO TECHNIQUES. Meeting abstract
Borggrefe J, Lieb W, Grehn F. A prospective randomized comparison of two techniques of combined cataract-glaucoma surgery. Graefes Arch Clin Exp Ophthalmol. 99 ;237(11):887-92. It is combined cataract/glaucoma surgery study published before April 2000
Bosem ME, Lusky M, Weinreb RN. Short-term effects of levobunolol on ocular pulsatile flow. Am J Ophthalmol. 92 ;114(3):280-6. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Botz N, Heider W. Long-term influence of pre-, intra-, and postoperative factors on the intraocular pressure in combined cataract and glaucoma surgery. Untersuchung des einflusses pra-, intra- und postoperativer faktoren auf die langfristige drucksenkende wirkung bei kombinierter katarakt- und glaukomoperation. Ophthalmologe. 2004;101(12):1202-1208. [pmid: 15156342]. It is a case series
Bourgeois H. Epidemiologic and tonometric results of a multicenter study of 5,872 patients with ocular hypertension or open-angle glaucoma treated with betaxolol. Foreign language
Bourgeois H. Results of a large epidemiological multicenter study conducted on 5,872 patients with intraocular hypertension or open angle chronic glaucoma and treated with betaxolol. Foreign language
Bournias T, Lai J. Comparison of Brimonidine Purite 0.15% vs. Dorzolamide 2% and Brinzolamide 1 % as Adjunctive Therapy to Hypotensive Lipids. Meeting abstract
Bournias TE, Abraham C. Pressure-Lowering Efficacy of Bimatoprost and Latanoprost: Effect of Baseline Mean Diurnal IOP. Meeting abstract
Bournias TE, Lai J. Brimonidine tartrate 0.15%, dorzolamide hydrochloride 2%, and brinzolamide 1% compared as adjunctive therapy to prostaglandin analogs. Medical KQ 3 only
Bournias TE, Lee D, Gross R, Mattox C. Ocular hypotensive efficacy of bimatoprost when used as a replacement for latanoprost in the treatment of glaucoma and ocular hypertension. J Ocul Pharmacol Ther. 2003;19(3):193-203. [pmid: 12828838]. Other (specify):study design does not match KQ (KQ3)
Boyle JE, Ghosh K, Gieser DK, Adamsons IA. A randomized trial comparing the dorzolamide-timolol combination given twice daily to monotherapy with timolol and dorzolamide. Medical KQ 3 or KQ 3 and KQ 6 only
Boyle JE, Ghosh K, Gieser DK, Adamsons IA. A randomized trial comparing the dorzolamide-timolol combination given twice daily to monotherapy with timolol and dorzolamide. Dorzolamide-Timolol Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
Boyle J, Connor J, Polis A, Adamsons I. THE LONG-TERM SAFETY OF TRUSOPT AS MONOTHERAPY AND ADJUNCTIVE THERAPY WITH TIMOLOL AND/OR PILOCARPINE. Meeting abstract
Boyle J, Reines S, Strohmaier K, Snyder E, Adamsons I. A CLINICAL TRIAL COMPARING PATIENT PREFERENCE AND IMPACT ON DAILY LIFE OF TRUSOPT AND PILOCARPINE. Meeting abstract
Bradbury JA, Rennie IG, Parsons MA. Adrenaline dacryolith: detection by ultrasound examination of the nasolacrimal duct. Br J Ophthalmol. 88 ;72(12):935-7. It is a case series
Brancato R, Carassa F, Trabucchi G. DIODE vs. ARGON LASER TRABECULOPLASTY: A CONTROLLED CLINICAL TRIAL. Meeting abstract
Brancato R, Carassa R, Trabucchi G. Diode laser compared with argon laser for trabeculoplasty. Rolim de Moura 2009
Brancato R, Menchini U, Pece A, Bandello F, Serini P, Fantaguzzi S. Laser trabeculoplasty: argon laser or krypton laser?. Foreign language
Brandt JD, Phase III. 3-Month Comparison of Timolol with AGN-192024: A New Ocular Hypotensive Lipid (HTL) for Glaucoma Management. Meeting abstract
Brandt JD, Cantor LB, Katz LJ, Batoosingh AL, Chou C, Bossowska I. Bimatoprost/timolol fixed combination: a 3-month double-masked, randomized parallel comparison to its individual components in patients with glaucoma or ocular hypertension. J Glaucoma. 2008;17(3):211-6. [pmid: 18414107]. OAG can’t be analyzed separately
Brandt JD, VanDenburgh AM, Chen K, Whitcup SM. Comparison of once- or twice-daily bimatoprost with twice-daily timolol in patients with elevated IOP : a 3-month clinical trial. Medical KQ 3 or KQ 3 and KQ 6 only
Brasil MV, Rockwood EJ, Smith SD. Comparison of silicone and polypropylene Ahmed Glaucoma Valve implants. J Glaucoma. 2007;16(1):36-41. [pmid: 17224747]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Bregeat P, Hamard H, Couderc JL, Lebuisson DA, Lefrancois A. Cataract and trabeculectomy. Indications. Short term results. Foreign language
Breusegem C, Fieuws S, Zeyen T, Stalmans I. The effect of trabeculectomy on ocular pulse amplitude. Invest Ophthalmol Vis Sci. 2010;51(1):231-5. [pmid: 19643974]. It is not a RCT and has less than 100 patients, Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Breusegem C, Spielberg L, Van Ginderdeuren R, Vandewalle E, Renier C, Van de Veire S, Fieuws S, Zeyen T, Stalmans I. Preoperative nonsteroidal anti-inflammatory drug or steroid and outcomes after trabeculectomy: a randomized controlled trial. Ophthalmology. 2010;117(7):1324-30. [pmid: 20382428]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Breusegem C, Spielberg L, Van Ginderdeuren R, Vandewalle E, Renier C, Van de Veire S, Fieuws S, Zeyen T, Stalmans I. Preoperative nonsteroidal anti-inflammatory drug or steroid and outcomes after trabeculectomy: a randomized controlled trial. Systematic review
Briggs MC, Jay JL. Age over 46 years does not affect the pressure lowering effect of trabeculectomy in primary open angle glaucoma. Br J Ophthalmol. 99;83(3):280-4. It is a case series
Brinchmann-Hansen O, Anmarkrud N. Pilocarpine medication in open-angle glaucoma. A study using pilocarpine eyedrops and an ocular therapeutic system. Acta Ophthalmol (Copenh). 79;57(1):55-62. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Brincker P, Kessing SV. Limbus-based versus fornix-based conjunctival flap in glaucoma filtering surgery. Acta Ophthalmol (Copenh). 92;70(5):641-4. Data not abstractable
Brinzolamide--a new topical carbonic anhydrase inhibitor for glaucoma. Med Lett Drugs Ther. 98;40(1036):95-6. No original data (e.g., systematic review, narrative review, editorial, letter)
Britman NA. Cardiac effects of topical timolol. N Engl J Med. 79; 300(10):566. It is a case series
Britt MT, LaBree LD, Lloyd MA, Minckler DS, Heuer DK, Baerveldt G, Varma R. Randomized clinical trial of the 350-mm2 versus the 500-mm2 Baerveldt implant: longer term results: is bigger better?. Ophthalmology. 99;106(12):2312-8. Animal or in vitro data
Brittain CJ, Saxena R, Waldock A. Prospective comparative switch study from timolol 0.5% and latanoprost 0.005% to bimatoprost 0.03%. Adv Ther. 2006;23(1):68-73. [pmid: 16644608]. Does not address any key questions
Broadway DC, Bloom PA, Bunce C, Thiagarajan M, Khaw PT. Needle revision of failing and failed trabeculectomy blebs with adjunctive 5-fluorouracil: survival analysis. Ophthalmology. 2004;111(4):665-73. [pmid: 15051196]. Does not address any key questions
Broadway DC, Grierson I, Hitchings RA. Local effects of previous conjunctival incisional surgery and the subsequent outcome of filtration surgery. Am J Ophthalmol. 98;125(6):805-18. Other (specify):Mean age under 50
Broadway DC, Grierson I, O’Brien C, Hitchings RA. Adverse effects of topical antiglaucoma medication. II. The outcome of filtration surgery. Arch Ophthalmol. 94;112(11):1446-54. OAG can’t be analyzed separately
Broadway DC, Iester M, Schulzer M, Douglas GR. Survival analysis for success of Molteno tube implants. Br J Ophthalmol. 2001;85(6):689-95. [pmid: 11371490]. Data not abstractable
Broadway DC, Salmon J, Migdal CS, Franks WA, Barton K, Khaw PT. ADJUNCTIVE ANTI-TG Fß2 HUMAN MONOCLONAL ANTIBODY AS A NOVEL AGENT TO PREVENT SCARRING FOLLOWING PHACOTRABECULECTOMY. Meeting abstract
Broadway D, Grierson I, Hitchings R. Adverse effects of topical antiglaucomatous medications on the conjunctiva. Br J Ophthalmol. 93; 77(9):590-6. No original data (e.g., systematic review, narrative review, editorial, letter)
Broadway D, Grierson I, Hitchings R. Racial differences in the results of glaucoma filtration surgery: are racial differences in the conjunctival cell profile important?. Br J Ophthalmol. 94;78(6):466-75. It is not a RCT and has less than 100 patients
Broadway D, Miglior S, Myers JS. Fluctuating intraocular pressure. J Glaucoma. 2005;14(3):249-51. [pmid: 15870610]. It is a case series
Brogliatti B, Rolle T, Vizzeri GM, Cipullo D. Comparison of the efficacy on intraocular pressure and retinal blood flow of a beta-blocker (timolol maleate) against the fixed association of a topical carbonic anhydrase (dorzolamide) and a beta-blocker (timolol maleate). Acta Ophthalmol Scand Suppl. 2000;(232):47-9. [pmid: 11235534]. Other (specify):kq 1 and 3 other trial
Bron A. Comparison of latanoprost monotherapy with timolol-dorzolamide combination in patients with open-angle glaucoma or ocular hypertension. Foreign language
Bron AM, Denis P, Nordmann JP, Rouland JF, Sellem E, Johansson M. Additive IOP-reducing effect of latanoprost in patients insufficiently controlled on timolol. Medical KQ 3 only
Bron AM, Garcher CP, Sirbat D, Allaire CM, Lablache-Combier MJ, Trinquand CJ. Comparison of two fixed beta-blocker-pilocarpine combinations. The Carteolol-Pilocarpine Study Group. Duplicate
Bron AM, Garcher CP, Sirbat D, Allaire CM, Lablache-Combier MJ, Trinquand CJM. Comparison of two fixed beta-blocker-pilocarpine combinations. Duplicate
Bron AM, Lippa EA, Hofmann HM, Feicht BI, Royer JG, Brunner-Ferber FL, Panebianco DL, Von Denffer HA. MK-927: a topically effective carbonic anhydrase inhibitor in patients. Arch Ophthalmol. 89;107(8):1143-6. Does not address any key questions
Bron A, Chiambaretta F, Pouliquen P, Rigal D, Rouland JF. Efficacy and safety of substituting a twice-daily regimen of timolol with a single daily instillation of nonpreserved beta-blocker in patients with chronic glaucoma or ocular hypertension. Foreign language
Bron A, Chiambaretta F, Pouliquen P, Rigal D, Rouland J-F. Efficacy and safety of substituting a twice-daily regimen of timolol with a single daily instillation of nonpreserved beta-blocker in patients with chronic glaucoma or ocular hypertension. Interet de la substitution d’un traitement journalier de 2 instillations de timolol par 1 instillation quotidienne de betabloquant non conserve chez des patients presentant un glaucome chronique ou une hypertonie oculaire. Duplicate
Bron A, Velasque L, Rebica H, Pouliquen P, Elena PP, Rouland JF. Comparison of once-daily nonpreserved timolol and timolol maleate gel-forming solution associated with latanoprost. Foreign language
Bron A, Velasque L, Rebica H, Pouliquen P, Elena P-P, Rouland J-F. Comparison of once-daily nonpreserved timolol and timolol maleate gel-forming solution associated with latanoprost. Comparaison du timolol sans conservateur et du timolol a delivrance prolongee donnes une fois par jour en association a du latanoprost. Duplicate
Bronner A, Annonier P, Gerhard JP, Flament J, Simony N. Late results of trabeculectomy in chronic simple glaucoma. Apropos of the operations performed at the Ophthalmologic Clinic of Strasbourg from 1975 to 1981. Foreign language
Brooks AM, Gillies WE. Design and results of trabeculectomy operation for use with 5-fluorouracil. Ophthalmic Surg. 92;23(4):242-5. Data not abstractable
Brooks AM, Gillies WE. Laser trabeculoplasty--argon or diode?. Aust N Z J Ophthalmol. 93; 21(3):161-4. Data not abstractable
Brooks AMV, Elder J, McNab AA, McCombe MF, Madhok P, Gillies WE. Preventing a high rise in intraocular pressure after laser trabeculoplasty. AUST. NEW ZEALAND J OPHTHALMOL. 87; 15(2):113-117. OAG can’t be analyzed separately
Brooks AM, West RH, Gillies WE. Argon laser trabeculoplasty five years on. Aust N Z J Ophthalmol. 88;16(4):343-51. It is a case series
Brown HS, Meltzer G, Merrill RC, Fisher M, Ferre C, Place VA. Visual effects of pilocarpine in glaucoma comparative study of administration by eyedrops or by ocular therapeutic systems. Arch Ophthalmol. 76;94(10):1716-9. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Bruno CA, Radenbaugh PA, Trzcinka A, Kim DS, John DA, Lutz D, Cantor LB, Niziol LM, Musch DC, Moroi SE. Effect of Amniotic Membrane on Trabeculectomy Outcome in a Prospective, Randomized Pilot Study of Patients at High Risk for Filtration Failure. Meeting abstract
Bryant J. Laser trabeculoplasty as primary therapy for glaucoma (Structured abstract). Abstract only
Bucci MG. Intraocular pressure-lowering effects of latanoprost monotherapy versus latanoprost or pilocarpine in combination with timolol: a randomized, observer-masked multicenter study in patients with open-angle glaucoma. Italian Latanoprost Study Group. Excluded drug
Bucci MG, Centofanti M, Oddone F, Parravano M, Balacco Gabrieli C, Pecori-Giraldi J, Librando A, Paone E, Bores LD. Pilot study to evaluate the efficacy and safety of pneumatic trabeculoplasty in glaucoma and ocular hypertension. Eur J Ophthalmol. 2005;15(3):347-52. [pmid: 15945003]. Other (specify):No control
Bucci MG, Cichetti MP, D’Andrea D. Ocular hypotensive effects of timolol/dapiprazole vs timolol/pilocarpine in glaucoma patients. Glaucoma. 88;10:141-3. Does not address any key questions
Bucci MG, Quaranta L, Quaranta CA, Nascimbeni G, Semeraro F, Quaranta M, Braga O, Cassamali M, Manni GL. INVESTIGATION ON THE ADDICTIVE EFFECT OF TIMOLOL AND METIPRANOLOL. Meeting abstract
Buchan JC, Siddiqui S, Gilmour D. Once daily drop regimes help reduce involuntary non-compliance. Graefes Arch Clin Exp Ophthalmol. 2007;245(2):327-8. [pmid: 17955593]. It is not a RCT and has less than 100 patients
Budenz DL, Barton K, Feuer WJ, Schiffman J, Costa VP, Godfrey DG, Buys YM. Ahmed Baerveldt Comparison Study Group. Treatment outcomes in the Ahmed Baerveldt Comparison Study after 1 year of follow-up. Ophthalmology. 2011;118(3):443-52. [pmid: 20932583]. No subjects with open-angle glaucoma
Budenz DL. A clinician’s guide to the assessment and management of nonadherence in glaucoma. Systematic review
Budenz DL, Barton K, Feuer WJ, Schiffman J, Costa VP, Godfrey DG, Buys YM. Treatment Outcomes in the Ahmed Baerveldt Comparison Study after 1 Year of Follow-up. Ophthalmology. 2010. No subjects with open-angle glaucoma
Budenz DL, Barton K, Feuer WJ, Schiffman J, Costa VP, Godfrey DG, Buys YM. Treatment outcomes in the Ahmed Baerveldt Comparison Study after 1 year of follow-up. Ophthalmology. 2011;118:443-52. [pmid: 20932583]. No subjects with open-angle glaucoma
Budenz DL, Gedde SJ, Schiffman JC, Feuer WJ, Herndon LW, Brandt JD. Tube versus Trabeculectomy Study Group. Surgical Complications in the Tube versus Trabeculectomy (TVT) Study during the First Three Years of Follow-Up. Meeting abstract
Budenz DL, Pyfer M, Singh K, Gordon J, Piltz-Seymour J, Keates EU. Comparison of phacotrabeculectomy with 5-fluorouracil, mitomycin-C, and without antifibrotic agents. Ophthalmic Surg Lasers. 99;30(5):367-74. It is not a RCT and has less than 100 patients
Bunce C, Hitchings R. Medical vs surgical therapy in preventing visual field loss. Ophthalmology. 2003;110(2):249. author reply 249–50. [pmid: 12578758]. No original data (e.g., systematic review, narrative review, editorial, letter)
Bunin AIa, Ermakova VN, Gurtovaia EE. Hypersecretory glaucoma. Foreign language
Buquicchio R, Foti C, Cassano N, Ventura M, Vena GA. Allergic contact dermatitis from timolol complicating choroidal melanoma-related glaucoma. Eur J Dermatol. 2009;19(1):74-5. [pmid: 19171534]. Does not address any key questions
Burchfield JC, Kolker AE, Cook SG. Endophthalmitis following trabeculectomy with releasable sutures. Arch Ophthalmol. 96; 114(6):766. It is a case series
Burggraf GW, Munt PW. Topical timolol therapy and cardiopulmonary function. Can J Ophthalmol. 80;15(4):159-60. No original data (e.g., systematic review, narrative review, editorial, letter)
Buys YM, Trope GE. Prospective study of sub-Tenon’s versus retrobulbar anesthesia for inpatient and day-surgery trabeculectomy. Ophthalmology. 93;100(10):1585-9. Does not address any key questions
Buys YM, Chipman ML, Zack B, Rootman DS, Slomovic AR, Trope GE. Prospective randomized comparison of one- versus two-site Phacotrabeculectomy two-year results. Ophthalmology. 2008;115(7):1130-1133. e1. [pmid: 18171584]. OAG can’t be analyzed separately
Buys YM, Zack B, Chipman M, Trope GE, Rootman DS, Slomovic AR. Prospective Randomized Comparison of One- Versus Two-Site Phacotrabeculectomy. Two Year Data. Meeting abstract
Buys YM, Zack B, Slomovic AR, Rootman DS, Trope GE. Prospective Randomized Comparison of One- versus Two-Site Phacotrabeculectomy, Two Year Results. Meeting abstract
Buzarovska KB, Jordanova VD, Vukosavljevic M, Dzajkovska E. Visual acuty after trabeculectomy. Foreign language
Buzek J. Effect of drugs, used in the conservative treatment of glaucoma, on immediate adaptation. Foreign language
Bylsma SS. Trabeculectomy with antimetabolites vs nonpenetrating deep sclerectomy with collagen implant: new randomized protocol. Meeting abstract
Caca I, Simsek H, Unlu K, Ari S, Keklikci U. A comparison of latanoprost monotherapy with a combination therapy of timolol/dorzolamide in patients with primary open-angle glaucoma. Ann Ophthalmol (Skokie). 2006;38(2):111-5. [pmid: 17416939]. Other (specify):No concurrent control
Cackett P, Vallance J, Cobb C, Devlin H, Simpson A, Sanders R. South-East Scotland trabeculectomy survey. Eye (Lond). 2007;21(1):46-51. [pmid: 16215540]. It is a case series
Cai Y, Fu P, Wu JA, Li MY. A randomized parallel-group study comparing latanoprost treatment with timolol in patients with open angle glaucoma or ocular hypertension. Meeting abstract
Calenda E, Tourrel F. Sinoatrial block induced by timolol eyedrops. Can J Ophthalmol. 2007;42(1):149. [pmid: 17361266]. It is a case series
Calissendorff BM, Hamberg-Nystrom H. Pressure control in glaucoma patients after cataract surgery with intraocular lens. Eur J Ophthalmol. 92;2(4):163-8. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Calissendorff B, Maren N, Wettrell K, Ostberg A. Timolol versus pilocarpine separately or combined with acetazolamide-effects on intraocular pressure. Acta Ophthalmol (Copenh). 80;58(4):624-31. Other (specify):pilocarpine
Calugaru D, Calugaru M. Bimatoprost therapy in glaucoma. Systematic review
Calugaru D, Calugaru M. Monotherapy with lipid structural derivatives in glaucoma. Systematic review
Cameli N, Vicenzi C, Tosti A. Allergic contact conjunctivitis due to timolol in eyedrops. Contact Dermatitis. 91;25(2):129-30. It is a case series
Campagna P, Macri A, Rolando M, Calabria G. Chronic topical eye preservative-free beta-blocker therapy effect on the ocular surface in glaucomatous patients. Acta Ophthalmol Scand Suppl. 97(224):53. It is not a RCT and has less than 100 patients
Campbell SH, Hickey-Dwyer M, Harding SP. Double-masked three-period crossover investigation of timolol in control of raised intraocular pressure. Medical KQ 3 or KQ 3 and KQ 6 only
Camras CB. United States Latanoprost-Brimonidine Study Group. Efficary and Safety of Latanoprost or Brimonidine in Patients with Ocular Hypertension or Primary Open Angle Glaucoma. Meeting abstract
Camras CB, Wax M, Ritch R, Weinre RN, Robin AL, Higginbotham EJ. Latanoprost. A Potent Ocular Hypotensive Prostaglandin Analog, Increases Pigmentation in Peripherally Hypopigmented Irides. Meeting abstract
Camras CB, Hedman K. Rate of response to latanoprost or timolol in patients with ocular hypertension or glaucoma. Medical KQ 3 only
Camras CB, Sheu WP. Latanoprost or brimonidine as treatment for elevated intraocular pressure: multicenter trial in the United States. Medical KQ 3 only
Camras CB. The Brinzolamid Primary Therapy Study Group. A TRIPLE-MASKED. PRIMARY THERAPY STUDY OF THE EFFICACY AND SAFETY OF BID AND TID-DOSED BRINZOLAMIDE 1% COMPARED TO TID-DOSED DORZOlAMIDE 2% AND BID-DOSED TIMOLOL 0.5%. Meeting abstract
Camras CB. the United States Latanoprost Study Group. RATE OF RESPONSE TO LATANOPROST OR TIMOLOL IN PATIENTS WITH OCULAR HYPERTENSION OR GLAUCOMA. Meeting abstract
Camras CB. Brimonidine and latanoprost as adjunctive therapy. Ophthalmology. 2003;110(1):6-8. author reply 8–9. [pmid: 12511334]. No original data (e.g., systematic review, narrative review, editorial, letter)
Camras CB. Brimonidine and latanoprost as adjunctive therapy. Ophthalmology. 2004;111(2):410-1. [pmid: 15019405]. No original data (e.g., systematic review, narrative review, editorial, letter)
Camras CB. CME and anterior uveitis with latanoprost use. Ophthalmology. 98;105(11):1978-81. No original data (e.g., systematic review, narrative review, editorial, letter)
Camras CB. Comparison of latanoprost and timolol in patients with ocular hypertension and glaucoma: a six-month masked, multicenter trial in the United States. The United States Latanoprost Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
Camras CB, Alm A, Watson P, Stjernschantz J. Latanoprost, a prostaglandin analog, for glaucoma therapy. Efficacy and safety after 1 year of treatment in 198 patients. Latanoprost Study Groups. Ophthalmology. 96;103(11):1916-24. Other (specify):Study design does not match KQ
Camras CB, Schumer RA, Marsk A, Lustgarten JS, Serle JB, Stjernschantz J, Bito LZ, Podos SM. Intraocular pressure reduction with PhXA34, a new prostaglandin analogue, in patients with ocular hypertension. Arch Ophthalmol. 92;110(12):1733-8. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Camras CB, Wax MB, Ritch R, Weinreb R, Robin AL, Higginbotham EJ, Lustgarten J, Stewart WC, Sherwood M, Krupin T, Wilensky J, Cioffi GA, Katz LJ, Schumer RA, Kaufman PL, Minckler D, Zimmerman T, Stjernschantz J. Latanoprost treatment for glaucoma: effects of treating for 1 year and of switching from timolol. United States Latanoprost Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
Camras CB, Wax MB, Ritch R, Weinreb R, Robin AL, Higginbotham EJ, Lustgarten J, Stewart WC, Sherwood M, Krupin T, Wilensky J, Cioffi GA, Katz LJ, Schumer RA, Kaufman PL, Minckler D, Zimmerman T, Stjernschantz J. Latanoprost treatment for glaucoma: Effects of treating for 1 year and of switching from timolol. Medical KQ 3 or KQ 3 and KQ 6 only
Canadian Glaucoma Study Group. Canadian Glaucoma Study: 1. Study design, baseline characteristics, and preliminary analyses. Canadian journal of ophthalmology. Journal canadien d’ophtalmologie. 2006;41(5):566-75. [pmid: 17016527]. Does not address any key questions
Cankaya AB, Teberik P, Acaroglu G. Alterations in anterior chamber depth in primary open-angle glaucoma patients during latanoprost therapy. Acta Ophthalmol. 2009. It is not a RCT and has less than 100 patients, Does not address any key questions
Cantor LB. AGN 192024 Study Groups, 1. & 2. 6-Month comparison of AGN 192024 once-daily and twice-daily with timolol twicedaily in patients with elevated IOP. Meeting abstract
Cantor LB, Hoop J, Morgan L. Bimatoprost-Travoprost Study Group. IOP-Lowering Efficacy of Bimatoprost 0.03% and Travoprost 0.004% in Patients With Glaucoma or Ocular Hypertension. Meeting abstract
Cantor LB. COMPARISON OF BRIMONIDINE0.2% VERSUS BETAXOLOL 0.25% FOR CONTROL OF INTRAOCULAR PRESSURE. Meeting abstract
Cantor LB, Alvi NP, Hoop JS, Katz LJ, Flartey K, Brizendine EI, Bhavnani VD. COMPARISON OF ONCE DAILY LEVOBUNOLOL 0.5%. VERSUS TIMOLOL XE O.5% FOR THE CONTROL OF INTRAOCULAR PRESSURE AND PATIENT COMFORT. Meeting abstract
Cantor LB, Boeglin RJ, Kramer DM, Phillips CA. THE EFFECT OF TOPICAL FLURBIPROFEN ON TRABECULECTOMY. Meeting abstract
Cantor LB, Hoop J, Katz LJ, Flartey K. Comparison of the clinical success and quality-of-life impact of brimonidine 0.2% and betaxolol 0.25 % suspension in patients with elevated intraocular pressure. Medical KQ 3 only
Cantor LB, Hoop J, Katz LJ, Flartey K. Alphagan/Betaxolol Clinical Success Study Group. Comparison of the clinical success and quality-of-life impact of brimonidine 0.2% and betaxolol 0.25 % suspension in patients with elevated intraocular pressure. Medical KQ 3 or KQ 3 and KQ 6 only
Cantor LB, Hoop J, Morgan L, Wudunn D, Catoira Y. Intraocular pressure-lowering efficacy of bimatoprost 0.03% and travoprost 0.004% in patients with glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Cantor LB, Katz LJ, Flartey KJ, Spaeth GL, WuDunn D, Hoop JS, Lakhani V, Alvi NP. COMPARISON OF THE EFFECT OF ALPHAGAN 0.2% VERSUS TRUSOPT 2.0% IN COMBINATION WITH BETA-BLOCKERS. Meeting abstract
Cantor LB, Liu CC, Batoosingh AL, Hollander DA. Safety and tolerability of brimonidine purite 0.1% and brimonidine purite 0.15%: a meta-analysis of two phase 3 studies. Systematic review
Cantor LB, Phillips CA, Kramer D, Boeglin RJ, Manatunga A, Holleman E. Effect of topical flurbiprofen on trabeculectomy. J Glaucoma. 95;4(2):98-102. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Cantor LB, Safyan E, Liu CC, Batoosingh AL. Brimonidine-purite 0.1% versus brimonidine-purite 0.15% twice daily in glaucoma or ocular hypertension: a 12-month randomized trial. Unique comparators
Cantor LB, WuDunn D, Alvi NP, Hoop JS, Katz LJ, Flartey K, Brizendine EJ. COMPARISON OF TWICE DAILY BETAXOLOL 0.25% VERSUS BRIMONIDINE 0.2% FOR THE CONTROL OF INTRAOCULAR PRESSURE. Meeting abstract
Cantor LB, WuDunn D, Cortes A, Hoop J, Knotts S. Ocular hypotensive efficacy of bimatoprost 0.03% and travoprost 0.004% in patients with glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Cantor L, Burgoyne J, Sanders S, Bhavnani V, Hoop J, Brizendine E. The effect of mitomycin C on Molteno implant surgery: a 1-year randomized, masked, prospective study. J Glaucoma. 98;7(4):240-6. OAG can’t be analyzed separately
Caporossi A, Balestrazzi A, Malandrini A, Tosi GM, Caporossi T, Frezzotti P, Lomurno L. A randomized prospective study comparing trabeculectomy with and without the use of a new removable suture. Int Ophthalmol. 2009;29(5):359-65. [pmid: 18553060]. OAG can’t be analyzed separately
Caprioli J, Coleman AL. Intraocular pressure fluctuation a risk factor for visual field progression at low intraocular pressures in the advanced glaucoma intervention study. Ophthalmology. 2008;115(7):1123-1129. e3. [pmid: 18082889]. Does not address any key questions
Caprioli J. The treatment of normal-tension glaucoma. Am J Ophthalmol. 98;126(4):578-81. No original data (e.g., systematic review, narrative review, editorial, letter)
Caprioli J, Park HJ, Weitzman M. Temporal corneal phacoemulsification combined with superior trabeculectomy: a controlled study. Trans Am Ophthalmol Soc. 96;94:451-63. discussion 463–8. It is not a RCT and has less than 100 patients
Carassa RG, Bettin P, Fiori M, Brancato R. Viscocanalostomy vs. trabeculectomy: evaluation of postoperative visual field evolution. Meeting abstract
Carassa RG, Bettin P, Brancato R. Viscocanalostomy: a pilot study. Acta Ophthalmol Scand Suppl. 98(227):51-2. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Carassa RG, Bettin P, Fiori M, Brancato R. Viscocanalostomy versus trabeculectomy in white adults affected by open-angle glaucoma: a 2-year randomized, controlled trial. Cheng 2009 and Chai 2010
Carassa RG, Bettin P, Fiori M, Brancato R. Viscocanalostomy vs Trabeculectomy.. Three Years After. Meeting abstract
Carassa RG, Bettin P, Fiori M, Sannace C, Brancato R. Viscocanalostomy vs. trabeculectomy: a 12-month randomized prospective trial. Meeting abstract
Cardascia N, Vetrugno M, Trabucco T, Cantatore F, Sborgia C. Effects of travoprost eye drops on intraocular pressure and pulsatile ocular blood flow: A 180-day, randomized, double-masked comparison with latanoprost eye drops in patients with open-angle glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Carenini BB, Brogliatti B, Spinelli D, Orzalesi N, Gandolfo E, Bonomi L, Brusini P, Guerra R, Salvi G, Fiore P, Balestrazzi E, Boccassini S, Bucci M, Montrone F, Esposito G, Gelso P, Ferreri G. Latanoprost in monotherapy compared with Timolol and Dorzolamide in association as hypotensive agents in primary open-angle glaucoma and ocular hypertension. An open, randomized, multicentric, Italian study. Acta Ophthalmol. Scand. Suppl. 99;77(229):53. Data not abstractable
Carlson DW, Alward WL, Barad JP, Zimmerman MB, Carney BL. A randomized study of mitomycin augmentation in combined phacoemulsification and trabeculectomy. Ophthalmology. 97;104(4):719-24. It is combined cataract/glaucoma surgery study published before April 2000
Carlsson AM, Chauhan BC, Lee AA, Leblanc RP. Intraocular pressure and progression of glaucomatous visual field loss. Medical KQ 3 or KQ 3 and KQ 6 only
Carlsson AM, Chauhan BC, Lee AA, LeBlanc RP. The effect of brimonidine tartrate on retinal blood flow in patients with ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Carlsson AM, Chauhan BC, Lee AA, Leblanc RP. The effect of brimonidine tartrate on retinal blood flow in patients with ocular hypertension. KQ 3 and KQ 6 medical
Caronia RM, Liebmann JM, Friedman R, Cohen H, Ritch R. Trabeculectomy at the inferior limbus. Arch Ophthalmol. 96;114(4):387-91. OAG can’t be analyzed separately
Carpineto P, Ciancaglini M, Zuppardi E, Doronzo E, Mastropasqua L. The role of the uveoscleral outflow in the management of pigmentary glaucoma: a 24-month study comparing latanoprost with timolol. Medical KQ 3 only
Carrasco Font C, Arias Puente A, Garcia Saenz MC, Villarejo Diaz-Maroto I. Efficiency of brimonidine 0.2% and dorzolamide 2% as adjunctive therapy to beta-blockers. Arch Soc Esp Oftalmol. 2004;79(4):163-8. [pmid: 15124072]. It is not a RCT and has less than 100 patients
Carstocea B, Gafencu O, Armegioiu M, Ionita N, Postaliu D, Paiu M, Stanca H. Difficulties in cataract surgery of patient with old glaucoma. Foreign language
Casiraghi JF, Moussalli MA, Lavena PI. Perimetric changes after surgery in advanced glaucoma. Foreign language
Cassels-Brown A, Diggory P, Vail A. TIMOLOL OR BETAXOLOL FOR ELDERLY NEW GLAUCOMA PATIENTS. Meeting abstract
Cassidy H. Clinical evaluation of timolol maleate in glaucoma. [abstract]. Meeting Abstact
Casson RJ, Liu L, Graham SL, Morgan WH, Grigg JR, Galanopoulos A, Crawford A, House PH. Efficacy and safety of bimatoprost as replacement for latanoprost in patients with glaucoma or ocular hypertension: a uniocular switch study. Medical KQ 3 or KQ 3 and KQ 6 only
Castanheira Vera Regina Cardoso. Trabeculectomia em glaucoma em fase final. Foreign language
Castro Pedro, Durbn Nieves, Aizp·rua Ricardo. CirugÆa con y sin mitomicina C en glaucoma primario de bngulo abierto: control de la presi£n intraocular y complicaciones. Foreign language
Cates CA, Jeffrey MN. Granulomatous anterior uveitis associated with 0.2% topical brimonidine. Eye (Lond). 2003;17(5):670-1. [pmid: 12855989]. It is a case series
Catoira YM, Harris A, Siesky B, Cantor L, Kagemann L, Garzozi H, Lusky M, Tsai P. Intraocular Pressure Correlates with Visual Function in Primary Open Angle Glaucoma Patients. Meeting abstract
Cellini M, Baldi A, Tagliavini M. Comparative efficacy of timolol and betaxolol in the treatment of open angle glaucoma. Annali De Ottamologica E Clinica Oculista. 88;114:267-72. Other (specify):non-english
Cellini M, Profazio V, Possati GL, Toscano FM, Mangiafico P, Santiago L. Effect of 5-fluorouracil and mitomycin con ocular hydrodynamic. EFFETTO DEL 5-FLUOROURACILE E DELLA MITOMICINA C SULL’IDRODINAMICA OCULARE. Foreign language
Centofanti M, Oddone F, Gandolfi S, Hommer A, Boehm A, Tanga L, Sangermani C, Sportelli V, Haustein M, Manni G, Rossetti L. Comparison of Travoprost and Bimatoprost plus timolol fixed combinations in open-angle glaucoma patients previously treated with latanoprost plus timolol fixed combination. American journal of ophthalmology. 2010;150(4):575-80. [pmid: 20688314]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Centofanti M, Gregorio AD, Manni GL, Pasisi V, Bucci MG. COMPARATIVE ACUTE EFFECTS OF 0.2% BRIMONIDINE VERSUS 2% DORZOLAMIDE COMBINED TO BETA BLOCKERS IN OCULAR HYPERTENSION. Meeting abstract
Centofanti M, Manni GL, Napoli D, Bucci MG. Comparative effects of intraocular pressure between systemic and topical carbonic anhydrase inhibitors: a clinical masked, cross-over study. Pharmacol Res. 97;35(5):481-5. Other (specify):Study design does not match KQ
Centofanti M, Manni GL, Napoli D, Bucci MG. Comparative effects on intraocular pressure between systemic and topical carbonic anhydrase inhibitors: A clinical masked, cross-over study. PHARMACOL RES. 97;35(5):481-485. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Centofanti M, Manni G, Gregori D, Cocco F, Lorenzano D, Bucci MG. Comparative acute effects of brimonidine 0.2% versus dorzolamide 2% combined with beta-blockers in glaucoma. Graefes Arch Clin Exp Ophthalmol. 2000;238(4):302-5. [pmid: 10853928]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Centofanti M, Oddone F, Chimenti S, Tanga L, Citarella L, Manni G. Prevention of dermatologic side effects of bimatoprost 0.03% topical therapy. Am J Ophthalmol. 2006;142(6):1059-60. [pmid: 17157592]. Does not address any key questions
Centofanti M, Oddone F, Gandolfi S, Hommer A, Boehm A, Tanga L, Sangermani C, Sportelli V, Haustein M, Manni G, Rossetti L. Comparison of Travoprost and Bimatoprost plus timolol fixed combinations in open-angle glaucoma patients previously treated with latanoprost plus timolol fixed combination. Non-FDA-approved drug combination
Centofanti M, Oddone F, Vetrugno M, Manni G, Fogagnolo P, Tanga L, Ferreri P, Rossetti L. Efficacy of the fixed combinations of bimatoprost or latanoprost plus timolol in patients uncontrolled with prostaglandin monotherapy: a multicenter, randomized, investigator-masked, clinical study. Eur J Ophthalmol. 2009;19(1):66-71. [pmid: 19123151]. Other (specify):Neither drug is fda-approved
Chadha V, Cruickshank I, Swingler R, Sanders R. Advanced glaucomatous visual loss and oral steroids. BMJ. 2008;337:a670. [pmid: 18676441]. It is a case series
Chagnon A, Bonnefoy C, Mandirac, Ourgaud M. 3 years’ use of timolol in chronic open-angle glaucoma. Foreign language
Chai C, Loon SC. Meta-analysis of viscocanalostomy versus trabeculectomy in uncontrolled glaucoma. Systematic review
Chakib A, Ouarrach N, Haloui M, Elbelhadji M, Amraoui A. Viscocanalostomy: preliminary clinical results. Foreign language
Chan K, Testa M, McCluskey P. Ocular comfort of combination glaucoma therapies: brimonidine 0.2%/timolol 0.5% compared with dorzolamide 2%/timolol 0.5%. J Ocul Pharmacol Ther. 2007;23(4):372-6. [pmid: 17803436]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Chandrasekaran S, Cumming RG, Rochtchina E, Mitchell P. Associations between elevated intraocular pressure and glaucoma, use of glaucoma medications, and 5-year incident cataract: The Blue Mountains Eye Study. Ophthalmology. 2006;113(3):417-424. [pmid: 16458969]. OAG can’t be analyzed separately
Chang L, Thiagarajan M, Moseley M, Woodruff S, Bentley C, Khaw PT, Bloom P. Intraocular pressure outcome in primary 5FU phacotrabeculectomies compared with 5FU trabeculectomies. J Glaucoma. 2006;15(6):475-81. [pmid: 17106358]. It is not a RCT and has less than 100 patients
Charap AD, Shin DH, Petursson G, Cinotti D, Wortham E 4th, Brown RH, Silverstone DE, Atkins JM, Eto CY, Lue JC, et al. Effect of varying drop size on the efficacy and safety of a topical beta blocker. Ann Ophthalmol. 89;21(9):351-7. No subjects with open-angle glaucoma
Charleux J, Villa J. Triple procedure: operation of glaucoma, cataract and intra-ocular lens implantation. Review of 120 cases. Ophtalmologie. 87;1(3):365-7. It is combined cataract/glaucoma surgery study published before April 2000
Charron RC, Feldman F. Acetazolamide therapy with renal complications. Can J Ophthalmol. 74;9(3):282-4. It is a case series
Chatterjee S, Ansari MW. Microsurgical trabeculectomy in Ghana. Br J Ophthalmol. 72;56(10):783-7. It is not a RCT and has less than 100 patients
Chaudhry IA, Pasha MA, O’Connor DJ, Weitzman ML, Caprioli J. Randomized, controlled study of low-dose 5-fluorouracil in primary trabeculectomy. Am J Ophthalmol. 2000;130(6):700-3. [pmid: 11124286]. OAG can’t be analyzed separately
Chauhan BC, Drance SM, Douglas GR. The effect of long-term intraocular pressure reduction on the differential light sensitivity in glaucoma suspects. Invest Ophthalmol Vis Sci. 88;29(10):1478-85. Does not address any key questions
Chauhan BC, Drance SM, Douglas GR. The time-course of intraocular pressure in timolol-treated and untreated glaucoma suspects. Medical KQ 3 or KQ 3 and KQ 6 only
Chauhan BC, Nicolela MT, Artes PH. Incidence and rates of visual field progression after longitudinally measured optic disc change in glaucoma. Systematic review
Chauhan DC, Carlsson A, Lee A, LeBlanc RP. EFFECT OF BRIMONIDINE TARTRATE ON RETINAL BLOOD FLOW IN OCULAR HYPERTENSION. Meeting abstract
Cheetham JK, Tang-Liu D, Yu A, VanDenburgh A, Acheampong A, Yu D. Long-term Systemic Exposure Of Lumigan In Patients With Glaucoma Or Ocular Hypertension. Meeting abstract
Chen CW, Huang HT, Bair JS, Lee CC. Trabeculectomy with simultaneous topical application of mitomycin-C in refractory glaucoma. J Ocul Pharmacol. 90;6(3):175-82. Data not abstractable
Chen E, Golchin S, Blomdahl S. A comparison between 90 degrees and 180 degrees selective laser trabeculoplasty. J Glaucoma. 2004;13(1):62-5. [pmid: 14704546]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Chen H, Ge J, Liu X, Lu F. The clinical analysis of 260 combined surgery of glaucoma and cataract. Foreign language
Chen H, Zhang SX, Liu L, Lin D, Tang X, Sun L, Wang T, Wang H, Wang NL. Intermediate-term and long-term clinical evaluation of the Ahmed glaucoma valve implantation. Foreign language
Chen MJ, Chou JC, Hsu WM, Liu JH. The efficacy and safety of brimonidine 0.2% compared with timolol 0.5% in glaucoma: a randomized clinical trial on Taiwanese patients. Medical KQ 3 or KQ 3 and KQ 6 only
Chen MJ, Lin SC, Chen MJ. Effect of a YAG laser iridotomy on intraocular pressure in pigmentary glaucoma. Br J Ophthalmol. 2002;86(12):1443-4. [pmid: 12446385]. It is a case series
Chen PC, Schuman JS, Mattox C, Weiss HS, Krug JH Jr, Gross FJ, Coleman AL, Zonderman J. A Randomized Prospective Clinical Trial Comparing Surface-Modified with Standard Krupin Valves with Disk. Meeting abstract
Chen PC, Schuman JS, Mattox C, Zondermann J, Weiss HS, Krug JH, Gross FJ, Coleman AL. A RANDOMIZED PROSPECTIVE CLINICAL TRIAL COMPARING SURFACE MODIFIED TO STANDARD KRUPIN VALVES WITH DISK. Meeting abstract
Chen PP. Blindness in patients with treated open-angle glaucoma. Ophthalmology. 2003;110(4):726-733. [pmid: 12689894]. Does not address any key questions
Chen PP, Musch DC, Niziol LM. The Effect of Early Posttrabeculectomy Intraocular Pressure Spike in the Collaborative Initial Glaucoma Treatment Study. J Glaucoma. 2010. Other (specify):No control group, Does not address any key questions (see below for questions), Does not address any key questions (see below for questions)
Chen PP, Weaver YK, Budenz DL, Feuer WJ, Parrish RK 2nd. Trabeculectomy function after cataract extraction. Ophthalmology. 98;105(10):1928-35. It is combined cataract/glaucoma surgery study published before April 2000
Chen SY, Kuang GP, Xie LL, Zhu JD, Tan XL, Wu ZQ. Application of releasable suture in combined phacoemulsification and trabeculectomy. Foreign language
Chen TC, Ang RT, Grosskreutz CL, Pasquale LR, Fan JT. Brimonidine 0.2% versus apraclonidine 0.5% for prevention of intraocular pressure elevations after anterior segment laser surgery. Ophthalmology. 2001;108(6):1033-8. [pmid: 11382625]. Does not address any key questions
Chen TC, Pasquale LR, Walton DS, Grosskreutz CL. Diode laser transscleral cyclophotocoagulation. Int Ophthalmol Clin. 99; 39(1):169-76. No original data (e.g., systematic review, narrative review, editorial, letter)
Chen YF, Yang CH, Hung PT. A six-week, parallel, randomized, double-blind study comparing the efficacy and safety of the 0.5% timolol/2.0% MK-507 combination b.i.d. to the concomitant administration of 0.5% timolol b.i.d. and 2.0% MK-507 b.i.d. J Ocul Pharmacol Ther. 2003;19(5):417-23. [pmid: 14583134]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Cheng JW, Cai JP, Wei RL. Meta-analysis of medical intervention for normal tension glaucoma. Systematic review
Cheng JW, Cai JP, Li Y, Wei RL. A meta-analysis of topical prostaglandin analogs in the treatment of chronic angle-closure glaucoma. Systematic review
Cheng JW, Li Y, Wei RL. Systematic review of intraocular pressure-lowering effects of adjunctive medications added to latanoprost. Systematic review
Cheng JW, Xi GL, Wei RL, Cai JP, Li Y. Efficacy and tolerability of latanoprost compared to dorzolamide combined with timolol in the treatment of patients with elevated intraocular pressure: a meta-analysis of randomized, controlled trials. Systematic review
Cheng JW, Xi GL, Wei RL, Cai JP, Li Y. Efficacy and tolerability of nonpenetrating filtering surgery in the treatment of open-angle glaucoma: a meta-analysis. Systematic review
Cheng JW, Xi GL, Wei RL, Cai JP, Li Y. Efficacy and tolerability of nonpenetrating glaucoma surgery augmented with mitomycin C in treatment of open-angle glaucoma: a meta-analysis. Systematic review
Cher I. Transfer to timolol: selective use of a new mode of therapy. Aust J Ophthalmol. 80;8(2):165-72. Does not address any key questions
Cherkunov BF, Kolesnikova MA, Kunin VD. Immediate and long-term results of modified trabeculectomy. Foreign language
Chevrier RL, Assalian A, Duperre J, Lesk MR. Apraclonidine 0.5% versus brimonidine 0.2% for the control of intraocular pressure elevation following anterior segment laser procedures. Ophthalmic Surg Lasers. 99;30(3):199-204. Does not address any key questions
Chia WL, Goldberg I. Comparison of extracapsular and phaco-emulsification cataract extraction techniques when combined with intra-ocular lens placement and trabeculectomy: short-term results. Aust N Z J Ophthalmol. 98;26(1):19-27. It is combined cataract/glaucoma surgery study published before April 2000
Chiba T, Kashiwagi K, Chiba N, Ishijima K, Furuichi M, Kogure S, Abe K, Tsukahara S. Comparison of iridial pigmentation between latanoprost and isopropyl unoprostone: a long term prospective comparative study. Br J Ophthalmol. 2003;87(8):956-9. [pmid: 12881333]. Other (specify):Unoprostone
Chihara E, Hayashi K. Different modes of intraocular pressure reduction after three different nonfiltering surgeries and trabeculectomy. Jpn J Ophthalmol. 2011:107-14. [pmid: 21400054]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Chihara E, Dong J, Ochiai H, Hamada S. Effects of tranilast on filtering blebs: a pilot study. J Glaucoma. 2002;11(2):127-33. [pmid: 11912360]. It is a case series
Chihara E, Nishida A, Kodo M, Yoshimura N, Matsumura M, Yamamoto M, Tsukada T. Trabeculotomy ab externo: an alternative treatment in adult patients with primary open-angle glaucoma. Foreign language
Chihara E, Okazaki K, Takahashi H, Shoji T, Adachi H, Hayashi K. Modified deep sclerectomy (D-lectomy MMC) for primary open-angle glaucoma: preliminary results. J Glaucoma. 2009;18(2):132-9. [pmid: 19225350]. Other (specify):Study design does not match KQ
Chiou SH, Hsu WM, Liu JH, Liu JL, Chen MR, Tsai DC, Chou CK. Comparative study of timolol gel versus timolol solution for patients with glaucoma. Zhonghua Yi Xue Za Zhi (Taipei). 2000;63(10):737-43. [pmid: 11076430]. Other (specify):Not a comparison of interest
Chisalita D, Poiata I. The progression of primary operated glaucoma. Foreign language
Chisalita D, Poiata I, Cozma D. Postoperative flat anterior chamber. The therapeutic approach. Foreign language
Chiselita D. Non-penetrating deep sclerectomy versus trabeculectomy in primary open-angle glaucoma surgery. Cheng 2009
Chiselita D, Antohi I, Medvichi R, Danielescu C, Marcu C, Trifina A, Ciobanu C. The influence of cataract surgery on the efficacy of trabeculectomy in patients with open-angle glaucoma. Foreign language
Chiselita D, Apatachioae I, Poiata I. The ocular hypotensive effect of the combination of latanoprost with dorzolamide. Foreign language
Chiselita D, Poiata I, Tiutiuca C, Stanciu D, Vancea PP. Primary trabeculectomy in the surgery of primary open angle glaucoma. Foreign language
Chiselita D, Vancea PP, Poiata I. The effect of chronic beta-blocker treatment on the evolution of primary open-angle glaucoma. Foreign language
Chiselita D, Vancea PP, Bogdanici C, Branisteanu D. A comparison of the long-term results and complications of trabeculectomy. Foreign language
Cho SW, Kim JM, Park KH, Choi CY. Effects of brimonidine 0.2%-timolol 0.5% fixed-combination therapy for glaucoma. Jpn J Ophthalmol. (5; status =Department of Ophthalmology, Sungkyunkwan University School of Medicine, Kangbuk Samsung Hospital, Seoul, Korea. ). 2010;54:407-13. [pmid: 21052902]. It is not a RCT and has less than 100 patients
Choplin N. Brimonidine Study Group. VISUAL FIELD RESULTS FROM A ONE-YEAR MULTI-CENTER RANDOMIZED DOUBLE-MASKED STUDY COMPARING BRIMONIDINE TARTRATE TO TIMOLOL MALEATE IN THE TREATMENT OF OCULAR HYPERTENSION AND GLAUCOMA. Meeting abstract
Choplin NT, Monroe JF. Surgically-induced astigmatism in combined ECCE with filtering procedures compared to ECCE alone. Ophthalmic Surg. 92; 23(2):81-4. It is combined cataract/glaucoma surgery study published before April 2000
Choplin NT. RESPONSE TO EPINEPHRINE IN PATIENTS FAILING TO RESPOND TO DIPIVALYL-EPINEPHRINE. Meeting abstract
Choplin NT, Dirks MS, Tepedino M, Batoosingh A, Bernstein P, Whitcup SM. Bimatoprost/Lantanoprost Study Group. Comparison of Clinically Relevant Response Rates to Bimatoprost and Latanoprost in Patients with Ocular Hypertension or Glaucoma. Meeting abstract
Choplin NT, Ulrich GG, Riffenburgh RH. ANALYSIS OF OBSERVED DIFFERENCES IN INDIVIDUAL RESPONSES TO METIPRANOLOL 0.3% AND TIMOLOL 0.5% IN LOWERING INTRAOCULAR PRESSURE (IOP) IN OPEN ANGLE GLAUCOMA AND OCULAR HYPERTENSION. Meeting abstract
Choplin N, Bernstein P, Batoosingh AL, Whitcup SM. A randomized, investigator-masked comparison of diurnal responder rates with bimatoprost and latanoprost in the lowering of intraocular pressure. Surv Ophthalmol. 2004;49(Suppl 1):S19-25. [pmid: 15016558]. Does not address any key questions
Chou SY, Chou CK, Kuang TM, Hsu WM. Incidence and severity of iris pigmentation on latanoprost-treated glaucoma eyes. Eye (Lond). 2005;19(7):784-7. [pmid: 15359238]. It is a case series
Chou S-Y, Chou C-K, Kuang T-M, Hsu W-M. Incidence and severity of iris pigmentation on latonoprost-treated glaucoma eyes. Eye. 2005;19(7):784-787. [pmid: 15359238]. It is a case series
Choudhary A, Wishart PK. Non-penetrating glaucoma surgery augmented with mitomycin C or 5-fluorouracil in eyes at high risk of failure of filtration surgery: long-term results. Clin Experiment Ophthalmol. 2007;35(4):340-7. [pmid: 17539786]. It is not a RCT and has less than 100 patients
Choudhri S, Wand M, Shields MB. A comparison of dorzolamide-timolol combination versus the concomitant drugs. Am J Ophthalmol. 2000;130(6):832-3. [pmid: 11124307]. It is not a RCT and has less than 100 patients
Christ T, Kessler C. SINGLE COMBINATION OR SEPARATE SOLUTIONS IN GLAUCOMA TREATMENT ?. Meeting abstract
Christ T. Glaucoma-combined therapy. KOMBINATIONSTHERAPIE DES GLAUKOMS. SPEKTRUM AUGENHEILKD. 94; 8(5):227-230. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Christakis C, Mangouritsas N. Comparative studies of the pressure-lowering effect of timolol and phospholine iodide. VERGLEICHSUNTERSUCHUNGEN MIT TIMOLOL UND PHOSPHOLINE-JODID BEI APHAKIEGLAUKOM. Duplicate
Chung AN, Aung T, Wang JC, Chew PT. Surgical outcomes of combined phacoemulsification and glaucoma drainage implant surgery for Asian patients with refractory glaucoma with cataract. Am J Ophthalmol. 2004;137(2):294-300. [pmid: 14962420]. It is not a RCT and has less than 100 patients
Chung PY, Schuman JS, Netland PA, Lloyd-Muhammad RA, Jacobs DS. Five-year results of a randomized, prospective, clinical trial of diode vs argon laser trabeculoplasty for open-angle glaucoma. Rolim de Moura 2009
Churkin VE, Abramov VG, Vakurin EA. Longitudinal observations of patients with open-angle glaucoma following trabeculectomy. Foreign language
Ciancaglini M, Carpineto P, Agnifili L, Nubile M, Fasanella V, Mattei PA, Mastropasqua L. Conjunctival characteristics in primary open-angle glaucoma and modifications induced by trabeculectomy with mitomycin C: an in vivo confocal microscopy study. Br J Ophthalmol. 2009;93(9):1204-9. [pmid: 19570768]. It is not a RCT and has less than 100 patients
Ciancaglini M, Carpineto P, Agnifili L, Nubile M, Toto L, Mastropasqua L. A 12-week study evaluating the efficacy of bimatoprost 0.03% in patients with pseudoexfoliative and open-angle glaucoma. Eur J Ophthalmol. 2009;19(4):594-600. [pmid: 19551674]. It is not a RCT and has less than 100 patients
Ciappetta R, Frezzotti P, Nuti A, Traversi C, Frezzotti R. ADDITIVITY OF LATANOPROST AND PILOCARPINE TO TIMOLOL IN POAG PATIENTS. Meeting abstract
Cillino S, Di Pace F, Casuccio A, Lodato G. Deep sclerectomy versus punch trabeculectomy: effect of low-dosage mitomycin C. Cheng 2009
Cillino S, Di Pace F, Casuccio A, Calvaruso L, Morreale D, Vadala M, Lodato G. Deep sclerectomy versus punch trabeculectomy with or without phacoemulsification: a randomized clinical trial. Chang 2010
Cillino S, Di Pace F, Casuccio A, Cillino G, Lodato G. Deep sclerectomy versus trabeculectomy with low-dosage mitomycin C: four-year follow-up. Cheng 2009
Cillino S, Zeppa L, Di Pace F, Casuccio A, Morreale D, Bocchetta F, Lodato G. E-PTFE (Gore-Tex) implant with or without low-dosage mitomycin-C as an adjuvant in penetrating glaucoma surgery: 2 year randomized clinical trial. Duplicate of 7849
Cimino L, Gandolfi SA. DEEP SCLERECTOMY WITHOUT ABSORBABLE IMPLANT AND WITH UNSUTURED SUPERFICIAL FLAP: PROSPECTIVE RANDOMIZED CLINICAL - TRIAL vs. TRABECULECTOMY WITH RELEASABLE SUTURES. Meeting abstract
Cinotti A, Cinotti D, Grant W, Jacobs I, Galin M, Silverstone D, Shin D, Esters J, Lee J, Bouchey R, et al. Levobunolol vs timolol for open-angle glaucoma and ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Cioffi GA, Latina MA, Schwartz GF. Argon versus selective laser trabeculoplasty. J Glaucoma. 2004;13(2):174-7. [pmid: 15097266]. No original data (e.g., systematic review, narrative review, editorial, letter)
Clark JB, Brooks AM, Harper CA, Mantzioros N, Gillies WE. A comparison of the efficacy of betaxolol and timolol in ocular hypertension with or without adrenaline. Aust N Z J Ophthalmol. 89; 17(2):173-7. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Clearkin L. Adverse effects of topical antiglaucoma medication. Arch Ophthalmol. 95;113(7):849-50. No original data (e.g., systematic review, narrative review, editorial, letter)
Clergeau G, Pechereau A. Value of timoptol in primary open-angle glaucoma patients over 60. Comments on 100 cases. Foreign language
Clineschmidt CM, Shedden AH. THREE MONTH, PARALLEL, RANDOMIZED, DOUBLE-MASKED, PLACEBOCONTROLLED, MULTICENTER STUDY OF THE EFFECT OF ADDING TRUSOPT® TO 0.5% TIMOPTIC-XETM IN PATIENTS WITH ELEVATED IOP. Meeting abstract
Clineschmidt CM, Snyder E, Adamsons I. A Randomized Trial Comparing the Dorzolamide/Timolol Combination to Monotherapy with Timolol or Dorzolamide In Patients Inadequately Controlled on Timolol Alone. Meeting abstract
Clineschmidt CM, Strahlman JR, Anderson K. the Timolol/Mk 07 Combination Study Group. COMPARISON OF A FIXED COMBINATION OF DORZOLAMIDE AND TIMOLOL (BID) TO CONCOMITANT ADMINISTRATION OF DORZOLAMIDE (TID) PLUS TIMOLOL (BID) IN PATENTS WITH OPEN-ANGLE GLAUCOMA FOR THREE MONTHS. Meeting abstract
Clineschmidt CM, Williams RD, Snyder E, Adamsons IA. A randomized trial in patients inadequately controlled with timolol alone comparing the dorzolamide-timolol combination to monotherapy with timolol or dorzolamide. Medical KQ 3 or KQ 3 and KQ 6 only
Clineschmidt CM, Williams RD, Snyder E, Adamsons IA. A randomized trial in patients inadequately controlled with timolol alone comparing the dorzolamide-timolol combination to monotherapy with timolol or dorzolamide. Dorzolamide-Timolol Combination Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
Cohen AM, Prialnik M, Ben-Nissan DS, Savir H. Methazolamide-associated temporary leukopenia and thrombocytopenia. DICP. 89; 23(1):58-9. It is a case series
Cohen JS, Greff L. Efficacy and Safety of Long-Term Bimatoprost Treatment in Glaucoma and Ocular Hypertension. Meeting abstract
Cohen JS, Greff LJ, Novack GD, Wind BE. A placebo-controlled, double-masked evaluation of mitomycin C in combined glaucoma and cataract procedures. Ophthalmology. 96; 103(11):1934-42. It is combined cataract/glaucoma surgery study published before April 2000
Cohen JS, Gross RL, Cheetham JK, VanDenburgh AM, Bernstein P, Whitcup SM. Two-year double-masked comparison of bimatoprost with timolol in patients with glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Cohen JS, Gross RL, Sherwood MB, Cheetham JK, VanDenburgh A, Bernstein P, Whitcup SM. 2-Year Comparison of Bimatoprost with Timolol in Patients with Glaucoma or Ocular Hypertension. Meeting abstract
Cohen JS, Novack GD, Li ZL. The role of mitomycin treatment duration and previous intraocular surgery on the success of trabeculectomy surgery. J Glaucoma. 97;6(1):3-9. OAG can’t be analyzed separately
Cohen JS, Novack GD, Zink JM. Intraocular pressure and visual field damage as risk factors for visual field progression in filtering surgery. Ophthalmic Surg Lasers Imaging. 2010;41(4):452-8. [pmid: 20608614]. Data not abstractable
Cohen J, Brandt J, Cheetham J, Bernstein P, Whitcup SM. Comparing Bimatoprost to Timolol in Patients With Glaucoma or Ocular Hypertension: Results After Two Years. Meeting abstract
Cohen Ralph, Almeida Geraldo Vicente de, Rehder Jose Ricardo CL. Eficbcia e seguranga do carteolol a 2 por cento no tratamento da hipertensåo ocular crónica. Foreign language
Cohen Ralph, Mandia Junior Carmo, Almeida Geraldo Vicente de. Betaxolol a 0,25 por cento suspensåo iónica x betaxolol a 0,5 por cento: estudo comparativo. Foreign language
Coleman AL, Vandenburgh AM, Whitcup SM. A 3-month comparison of bimatoprost (a prostamide) with timolol/dorzolamide in patients with glaucoma or ocular hypertension. Meeting abstract
Coleman AL, Lerner F, Bernstein P, Whitcup SM. A 3-month randomized controlled trial of bimatoprost (LUMIGAN) versus combined timolol and dorzolamide (Cosopt) in patients with glaucoma or ocular hypertension. Ophthalmology. 2003;110(12):2362-8. [pmid: 14644719]. Animal or in vitro data
Coleman AL, Lerner F, Bernstein P, Whitcup SM. A 3-month randomized controlled trial of bimatoprost (LUMIGAN) versus combined timolol and dorzolamide (Cosopt) in patients with glaucoma or ocular hypertension. Ophthalmology. 2003;110(12):2362-8. [pmid: 14644719]. Data not abstractable
Coleman AL, Mosaed S, Kamal D. Medical therapy in pregnancy. J Glaucoma. 2005;14(5):414-6. [pmid: 16148592]. No original data (e.g., systematic review, narrative review, editorial, letter)
Collignon P. Cardiovascular and pulmonary effects of beta-blocking agents: implications for their use in ophthalmology. Surv Ophthalmol. 89; 33(Suppl):455-6. discussion 459–60. Does not address any key questions
Collignon-Brach J, Weekers R. Timolol (author’s transl). Foreign language
Collignon-Brach J. Early visual field changes with beta-blocking agents. Surv Ophthalmol. 89;33(Suppl):429-30. discussion 435–6. Data not abstractable
Collignon-Brach J. Long-term effect of ophthalmic beta-adrenoceptor antagonists on intraocular pressure and retinal sensitivity in primary open-angle glaucoma. Vass-2007
Collignon-Brach J. Longterm effect of topical beta-blockers on intraocular pressure and visual field sensitivity in ocular hypertension and chronic open-angle glaucoma. Vass-2007
Colvin Trucco Ricardo. CirugÆa combinada: extracapsular, implante de lente intraocular y trabeculectomÆa. Foreign language
Colvin Trucco Ricardo. CirugÆa combinada: facoemulsificaci£n, lente intraocular y trabeculectomÆa. Foreign language
Comparison of glaucomatous progression between untreated patients with normal-tension glaucoma and patients with therapeutically reduced intraocular pressures. Collaborative Normal-Tension Glaucoma Study Group. Am J Ophthalmol. 98;126(4):487-97. Does not address any key questions (see below for questions) Does not address any key questions
Comparison of latanoprost, bimatoprost, and travoprost. Medical KQ 3 or KQ 3 and KQ 6 only Medical KQ 3 or KQ 3 and KQ 6 only
Congdon N, Friedman D. The INGOTT Indian Glaucoma Trial. Meeting abstract
Connor J, Strahlman ER, Lippa EA, Tipping R, Hutzelmann J. Dorzolamide/Timolol/Placebo Comparison Study Group. A PLACEBO-CONTROLLED CLINICAL TRIAL OF 0.7% DORZOLAMIDE (MK-507) AND TIMOLOL. Meeting abstract
Connor MA, Knape RM, Oltmanns MH, Smith MF. Trainee glaucoma surgery: experience with trabeculectomy and glaucoma drainage devices. Ophthalmic Surg Lasers Imaging. 2010;41(5):523-31. [pmid: 20672770]. OAG can’t be analyzed separately, Does not address any key questions
Constad WH, Fiore P, Samson C, Cinotti AA. Use of an angiotensin converting enzyme inhibitor in ocular hypertension and primary open-angle glaucoma. Am J Ophthalmol. 88; 105(6):674-7. Other (specify):not FDA approved
Corbel M. Tolerance for timolol maleate. Foreign language
Coronel Mariano. Diatermia transescleral en el manejo del glaucoma neovascular. Foreign language
Correlagåo entre os achados a biomicroscopia ultra-sónica de bolhas filtrantes com ou sem mitomicina C com a pressåo intra-ocular. 1999. Foreign language.
Costa VP, Comegno PC, Malta RF, Vasconcelos J, Gullo RM, Bernardi L, Kara-José N. Low Dose Intraoperative Mitomycin C (MMC) in Primary Trabeculectomy. Meeting abstract
Costa VP, Azuara-Blanco A, Netland PA, Lesk MR, Arcieri ES. Efficacy and safety of adjunctive mitomycin C during Ahmed Glaucoma Valve implantation: a prospective randomized clinical trial. Ophthalmology. 2004;111(6):1071-6. [pmid: 15177955]. Animal or in vitro data
Costa VP, Comegno PE, Vasconcelos JP, Malta RF, Jose NK. Low-dose mitomycin C trabeculectomy in patients with advanced glaucoma. J Glaucoma. 96;5(3):193-9. Other (specify):Includes angle-closure glaucoma
Costa VP, Smith M, Spaeth GL, Gandham S, Markovitz B. Loss of visual acuity after trabeculectomy. Ophthalmology. 93; 100(5):599-612. Data not abstractable
Costa VP, Wilson RP, Moster MR, Schmidt CM, Gandham S. Hypotony maculopathy following the use of topical mitomycin C in glaucoma filtration surgery. Ophthalmic Surg. 93;24(6):389-94. It is a case series
Costa Vital Paulino, Soriano Danilo Sone, Carvalho Celso Antonio de. Efeitos a curto prazo da apraclonidina 1 sobre a pressåo intraocular de pacientes com glaucoma crónico de Gngulo aberto. Foreign language
Costa Vital Paulino, Vasconcellos Josq Paulo, Comegno Paulo EC, Josq Newton Kara. O uso da mitomicina C em cirurgia combinada. Arq. bras. oftalmol. 99; 62(5):577-80. It is combined cataract/glaucoma surgery study published before April 2000
Costagliola C, Campa C, Perri P, Parmeggiani F, Romano MR, Incorvaia C. Topical and oral ketorolac administration increases the intraocular pressure-lowering effect of latanoprost. Curr Eye Res. 2008;33(5):477-82. [pmid: 18568885]. It is not a RCT and has less than 100 patients
Costagliola C, Parmeggiani F, Antinozzi PP, Caccavale A, Cotticelli L, Sebastiani A. The influence of diclofenac ophthalmic solution on the intraocular pressure-lowering effect of topical 0.5% timolol and 0.005% latanoprost in primary open-angle glaucoma patients. Excluded drug
Costagliola C, Parmeggiani F, Caccavale A, Sebastiani A. Nimesulide oral administration increases the intraocular pressure-lowering effect of latanoprost in patients with primary open-angle glaucoma. Am J Ophthalmol. 2006;141(2):379-81. [pmid: 16458700]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Costagliola C, Parmeggiani F, Ciancaglini M, D’Oronzo E, Mastropasqua L, Sebastiani A. Ocular perfusion pressure and visual field indice modifications induced by alpha-agonist compound (clonidine 0.125%, apraclonidine 1.0% and brimonidine 0.2%) topical administration. An acute study on primary open-angle glaucoma patients. Ophthalmologica. 2003;217(1):39-44. [pmid: 12566871]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Costagliola C, Parmeggiani F, Virgili G, Lamberti G, Incorvaia C, Perri P, Campa C, Sebastiani A. Circadian changes of intraocular pressure and ocular perfusion pressure after timolol or latanoprost in Caucasians with normal-tension glaucoma. Graefes Arch Clin Exp Ophthalmol. 2008;246(3):389-96. [pmid: 18004586]. Other (specify):applies to KQ3 but not RCT
Costagliola C, Prete AD, Incorvaia C, Fusco R, Parmeggiani F, Di Giovanni A. Ocular surface changes induced by topical application of latanoprost and timolol: a short-term study in glaucomatous patients with and without allergic conjunctivitis. Graefes Arch Clin Exp Ophthalmol. 2001;239(11):809-14. [pmid: 11789860]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Cotran PR, Roh S. One-site vs. two-site combined phacoemulsification and trabeculectomy. Meeting abstract
Cotran PR, Roh S. Phacotrabeculectomy: Comparison of One-site and Two-site Surgery With 3 Year Follow-up. Meeting abstract
Cotran PR, Roh S. One-site vs. Two-site Phacotrabeculectomy: Results After One Year of Follow-up. Meeting abstract
Cotran PR, Roh S, McGwin G. Randomized comparison of 1-Site and 2-Site phacotrabeculectomy with 3-year follow-up. Included in Gdih 2011
Coulangeon LM, Sole M, Menerath JM, Sole P. Aqueous humor flow measured by fluorophotometry. A comparative study of the effect of various beta-blocker eyedrops in patients with ocular hypertension. Foreign language
Coviltir V, Grigoras O, Zorila C, Mircea D. Comparative results of nonpenetrante profound sclerectomy converted in trabeculectomy with standard trabeculectomy. Foreign language
Craven ER, Goni Francisco G, Chou C. Efficacy and Safety of the IOP-Lowering Fixed Combination Brimonidine 0.2%/Timolol 0.5%. Meeting abstract
Craven ER, Liu CC, Batoosingh A, Schiffman RM, Whitcup SM. A randomized, controlled comparison of macroscopic conjunctival hyperemia in patients treated with bimatoprost 0.01% or vehicle who were previously controlled on latanoprost. Clin Ophthalmol. status =Glaucoma Consultants of Colorado, Denver, CO, USA. ercraven@glaucdocs.com. 2010;4:1433-40. [pmid: 21188155]. OAG can’t be analyzed separately
Craven ER, Walters TR, Williams R, Chou C, Cheetham JK, Schiffman R. Brimonidine and timolol fixed-combination therapy versus monotherapy: a 3-month randomized trial in patients with glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Crichton A. BRIMONIDINE TARTRATE 0.2% COMPARED WITH TIMOLOL 0.5% ADMINISTERED TWICE-DAILY IN PATIENTS WITH OPEN-ANGLE GLAUCOMA OR OCULAR HYPERTENSION. Meeting abstract
Crick RP, Newson RB, Shipley MJ, Blackmore H, Bulpitt CJ. The progress of the visual field in chronic simple glaucoma and ocular hypertension treated topically with pilocarpine or with timolol. Eye (Lond). 90; 4(Pt 4):563-71. Other (specify):pilocarpine
Crick RP, Vogel R, Reynolds PM, Mills KB, Sass W. The effect of topical treatment by timolol versus pilocarpine on visual field progression in chronic simple glaucoma. Journal of Glaucoma. 93; 2(A):S12-14. Data not abstractable
Cronemberger Sebastiåo, Calixto Nassin, Soares Jose Francisco. Estudo comparativo do efeito do timolol, do betaxolol e do levobunolol sobre a curva dibria de pressåo intra-ocular de pacientes glaucomatosos. Foreign language
Cucea R. Filtering surgery in primary hypertensive glaucoma. Foreign language
Curran MP. Bimatoprost: a review of its use in open-angle glaucoma and ocular hypertension. Drugs Aging. 2009;26(12):1049-71. [pmid: 19929032]. No original data (e.g., systematic review, narrative review, editorial, letter)
Cvenkel B, Stewart JA, Nelson LA, Stewart WC. Dorzolamide/timolol fixed combination versus latanoprost/timolol fixed combination in patients with primary open-angle glaucoma or ocular hypertension. Curr Eye Res. 2008;33(2):163-8. [pmid: 18293187]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Cvetkovic D, Parunovic A, Kontic D. Conjunctival changes in long-term topical drug therapy of glaucoma. Foreign language
Cyriac IC, Samuel F, Katz LJ, Smith M. INFLUENCE OF SCLERAL CAUTERY ON SUCCESS OF TRABECULECTOMY. Meeting abstract
Czechowicz-Janicka K, Staszkiewicz J, Strzalkowska M, Krajewska M, Popiolek B, Christman A. The influence of 0.85% RS-timolol and 0.5% S-timolol on intraocular pressure and systemic arterial blood pressure, heart rate, ECG, expiratory capacity in patients with ocular hypertension and primary open-angle glaucoma. Foreign language
Dabrowska J. Side effects of antiglaucomatous drugs. Foreign language
Dahan E, Ravinet E, Ben-Simon GJ, Mermoud A. Comparison of the efficacy and longevity of nonpenetrating glaucoma surgery with and without a new, nonabsorbable hydrophilic implant. Ophthalmic Surg Lasers Imaging. 2003;34(6):457-63. [pmid: 14620748]. It is not a RCT and has less than 100 patients
Dahlen K, Epstein DL, Grant WM, Hutchinson BT, Prien EL Jr, Krall JM. A repeated dose-response study of methazolamide in glaucoma. Arch Ophthalmol. 78 ;96(12):2214-8. It is not a RCT and has less than 100 patients
Dallas NL, Sponsel WE, Hobley AJ. A comparative evaluation of timolol maleate and pilocarpine in the treatment of chronic open angle glaucoma. Eye (Lond). 88 ;2(Pt 3):243-9. Other (specify):pilocarpine
Damji KF, Bovell AM, Hodge WG, Rock W, Shah K, Buhrmann R, Pan YI. Selective laser trabeculoplasty versus argon laser trabeculoplasty: results from a 1-year randomised clinical trial. Br J Ophthalmol. 2006;90(12):1490-4. [pmid: 16899528]. OAG can’t be analyzed separately
Damji KF, Shah KC, Rock WJ, Bains HS, Hodge WG. Selective laser trabeculoplasty v argon laser trabeculoplasty: a prospective randomised clinical trial. Br J Ophthalmol. 99 ;83(6):718-22. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Dancheva LD, Zhukova VN. Remote results in the treatment of the initial stage of glaucoma with miotics. Foreign language
D’Andrea A, D’Andrea D, Ferreri G. Clinical use of a topical carbonic anhydrase inhibitor in patients affected by chronic simple glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
D’Andrea A, De Natale R, Mancini A. The metipranolol 0.3% in the therapy of glaucoma. Foreign language
Danias J, Podos SM. Comparison of glaucomatous progression between untreated patients with normal-tension glaucoma and patients with therapeutically reduced intraocular pressures. The effectiveness of intraocular pressure reduction in the treatment of normal-tension glaucoma. Am J Ophthalmol. 99; 127(5):623-5. No original data (e.g., systematic review, narrative review, editorial, letter)
Danielescu C. Management of pseudoexfoliative glaucoma in a tertiary center in Romania. Foreign language
Dansby-Kelly AF. Preparation for the use of mitomycin C in a trabeculectomy procedure. Insight. 2010;35(1):8-9. [pmid: 20218261]. No original data (e.g., systematic review, narrative review, editorial, letter)
Das JC, Chaudhuri Z, Sharma P, Bhomaj S. The Ahmed Glaucoma Valve in refractory glaucoma: experiences in Indian eyes. Eye (Lond). 2005;19(2):183-90. [pmid: 15258600]. Data not abstractable
Dasgupta S, Oates V, Bookhart BK, Vaziri B, Schwartz GF, Mozaffari E. Population-based persistency rates for topical glaucoma medications measured with pharmacy claims data. Am J Manag Care. 2002;8(10 Suppl):S255-61. [pmid: 12188168]. OAG can’t be analyzed separately
Dashevsky AV, Lanzl IM, Kotliar KE. Non-penetrating intracanalicular partial trabeculectomy via the ostia of Schlemm’s canal. Graefes Arch Clin Exp Ophthalmol. (4; status =Private Eye Clinic, Munich, Germany.). 2011;249:565-73. [pmid: 20862489]. Other (specify):Not one of our accepted surgeries
Dastur YK. The role of early trabeculectomy in the control of chronic simple glaucoma. J Postgrad Med. 94 ;40(2):74-7. It is not a RCT and has less than 100 patients
Dastur YK, Dasgupta S, Chitale A, Firke P, Patel J, Sethi S, Patwardhan V. The role of initial 5-fluorouracil trabeculectomy in primary glaucoma. J Postgrad Med. 94 ;40(4):197-201. Does not address any key questions
Dausch D, Michelson W, Lorenz ED. Long-term study of the pressure-lowering effect of Timolol (author’s transl). Klin Monbl Augenheilkd. 79; 174(1):127-35. It is not a RCT and has less than 100 patients
David R, Foerster RJ, Ober M, Cohen JS, Kelley EP, Lue JC, Novack GD. Glaucoma treatment with once-daily levobunolol. Medical KQ 3 or KQ 3 and KQ 6 only
David R, Livingston DG, Luntz MH. Ocular hypertension--a long-term follow-up of treated and untreated patients. Br J Ophthalmol. 77; 61(11):668-74. It is not a RCT and has less than 100 patients
David R, Ober M, Masi R, Elman J, Novack GD, Sears ML, Batoosingh AL. Treatment of elevated intraocular pressure with concurrent levobunolol and pilocarpine. Can J Ophthalmol. 87; 22(4):208-11. Other (specify):all had pilo
David R, Zangwill L, Briscoe D, Dagan M, Yagev R, Yassur Y. Diurnal intraocular pressure variations: an analysis of 690 diurnal curves. Br J Ophthalmol. 76(5):280-3. [pmid: 1356429]. Does not address any key questions
Davidson SI, Akingbehin T. Compliance in ophthalmology. Trans Ophthalmol Soc U K. 80 ;100(Pt 2):286-90. Does not address any key questions
Davidson SI. Systemic effects of eye drops. Trans Ophthalmol Soc U K. 74; 94(2):487-95. No original data (e.g., systematic review, narrative review, editorial, letter)
Davis AR, Diggory P, Seward HC. Prevalence of chronic hypokalaemia amongst elderly patients using acetozolamide and diuretics. Eye (Lond). 95; 9(Pt 3):381-2. It is not a RCT and has less than 100 patients
Day DG, Schacknow PN, Sharpe ED, Ellyn JC, Kulze JC, Threlkeld AB, Jones ED, Brown RH, Jenkins JN, Stewart WC. A persistency and economic analysis of latanoprost, bimatoprost, or beta-blockers in patients with open-angle glaucoma or ocular hypertension (Structured abstract). Journal of Ocular Pharmacology and Therapeutics. 2004;20(5):383-392. [pmid: 15650513]. Does not address any key questions
Day DG, Hollander DA. Brimonidine purite 0.1% versus brinzolamide 1% as adjunctive therapy to latanoprost in patients with glaucoma or ocular hypertension. Curr Med Res Opin. 2008;24(5):1435-42. [pmid: 18402717]. OAG can’t be analyzed separately
Day DG, Schacknow PN, Sharpe ED, Ellyn JC, Kulze JC 3rd, Threlkeld AB, Jones ED, Brown RH, Jenkins JN, Stewart WC. A persistency and economic analysis of latanoprost, bimatoprost, or beta-blockers in patients with open-angle glaucoma or ocular hypertension. Unique comparators
Day DG, Schacknow PN, Wand M, Sharpe ED, Stewart JA, Leech J, Stewart WC. Timolol 0.5%/dorzolamide 2% fixed combination vs timolol maleate 0.5% and unoprostone 0.15% given twice daily to patients with primary open-angle glaucoma or ocular hypertension. Am J Ophthalmol. 2003;135(2):138-43. [pmid: 12566015]. Other (specify):unoprostone
Day DG, Sharpe ED, Atkinson MJ, Stewart JA, Stewart WC. The clinical validity of the treatment satisfaction survey for intraocular pressure in ocular hypertensive and glaucoma patients. Eye (Lond). 2006;20(5):583-90. [pmid: 15933751]. Does not address any key questions
Day DG, Sharpe ED, Beischel CJ, Jenkins JN, Stewart JA, Stewart WC. Safety and efficacy of bimatoprost 0.03% versus timolol maleate 0.5%/dorzolamide 2% fixed combination. Unique comparators
Dayanir V, Ozcura F, Kir E, Topaloglu A, Ozkan SB, Aktunc T. Medical control of intraocular pressure after phacoemulsification. J Cataract Refract Surg. 2005;31(3):484-8. [pmid: 15811735]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
de Barros DS, Da Silva RS, Siam GA, Gheith ME, Nunes CM, Lankaranian D, Tittler EH, Myers JS, Spaeth GL. Should an iridectomy be routinely performed as a part of trabeculectomy? Two surgeons’ clinical experience. Eye (Lond). 2009;23(2):362-7. [pmid: 17992195]. It is not a RCT and has less than 100 patients
DE CARVALHO CA, LAWRENCE C, STONE HH. Acetazolamide (diamox) therapy in chronic glaucoma; a three-year follow-up study. AMA Arch Ophthalmol. 58 ;59(6):840-9. It is not a RCT and has less than 100 patients
De Carvalho CA, Betinjane AJ, Atanes M, Helal J Jr. Effects of pilocarpine oculosert system on pupillary diameter, visual acuity, refraction and intra ocular pressure. EFEITOS DO SISTEMA OCUSERT PILOCARPINA (P 20 E P 40) SOBRE O DIAMETRO PUPILAR, ACUIDADE VISUAL, REFRACAO E PRESSAO INTRA OCULAR. Foreign language
de Galleani B. Evaluation of three concentrations of beta-blocker eyedrops. Criteria for choosing and efficacy. Ophtalmologie. 89; 3(3):220-2. Does not address any key questions
de Grood PM, Gimbrere JS. Life-threatening status asthmaticus following use of timolol-containing eye drops (Timoptol). Foreign language
De Jong LA. Ex-PRESSTM Positioned Under a Scleral Flap, Trabeculectomy and ExPRESSTM Positioned Under Conjunctiva in Patients With Open Angle Glaucoma. A Prospective Comparison Randomized 3-Arms Study. Meeting abstract
De Negri Pescosolido N, Vitangeli MC, Bucci MG. The combination of adrenalin and oxprenolol in the treatment of glaucoma. L’ASSOCIAZIONE ADRENALINA-OXPRENOLOLO NELLA TERAPIA DEL GLAUCOMA. Foreign language
De Popa DP, Andreescu G, Albu C. Tearing in a patient with glaucoma. Foreign language
De Vivero C, Lanigan LP, Wormald R, Migdal CS, Hitchings RA. Long-Term Success Rates of Trabeculectomy as Initial Therapy Compared With Trabeculectomy After Initial Medical Treatment. Meeting abstract
DeBry PW, Perkins TW, Heatley G, Kaufman P, Brumback LC. Incidence of late-onset bleb-related complications following trabeculectomy with mitomycin. Arch Ophthalmol. 2002;120(3):297-300. [pmid: 11879132]. Other (specify):case series
D’Eliseo D, Pastena B, Longanesi L, Grisanti F, Negrini V. Comparison of deep sclerectomy with implant and combined glaucoma surgery. Hondur-2008
Delorme E, Vial T, Rabilloud M, de Carlan H, Evreux JC. Retroperitoneal fibrosis with eye-drops containing timolol. J Urol (Paris). 90 ;96(8):449-51. It is not a RCT and has less than 100 patients
Demailly Ph, Lehner MA, Etienne R. Result of a medium-term double blind study comparing timolol maleate and epinephrine in 120 patients with chronic open angle glaucoma. RESULTAT D’UNE ETUDE A MOYEN TERME EN DOUBLE AVEUGLE COMPARANT LE MALEATE DE TIMOLOL A L’EPINEPHRINE SUR 120 PATIENTS PORTEURS D’UN GLAUCOME CHRONIQUE A ANGLE OUVERT. Foreign language
Demailly Ph, Lehner MA, Pigot C. Timolol maleate: its long term affects in treatment of chronic open angle glaucoma. LE MALEATE DE TIMOLOL: RESULTAT DE SON ACTION A LONG TERME DANS LE TRAITEMENT DU GLAUCOME CHRONIQUE PRIMITIF A ANGLE OUVERT. Foreign language
Demailly P, Kretz G. Daunorubicin versus 5-fluorouracil in surgical treatment of primary open angle glaucoma: a prospective study. Int Ophthalmol. 92 ;16(4–5):367-70. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Demailly P, Lecherpie F. Metipranolol 0.1%: effect of a single dose on the nycthemeral pressure curve in an eye with chronic primary open-angle glaucoma. J Fr Ophtalmol. 87; 10(6–7):447-9. Other (specify):not a true 24hour study
Demailly P, Moulin F. Argon laser trabecular photocoagulation in the treatment of primary open-angle glaucoma. Annee Ther Clin Ophtalmol. 88 ;39:131-40. discussion 141–53. No original data (e.g., systematic review, narrative review, editorial, letter)
Demailly Ph, Lehner MA, Duperre J. A new beta-blocker in the treatment of chronic open angle glaucoma, timolol maleate. The effect on ocular tension of a single drop. UN NOUVEAU BETA-BLOQUANT DANS LE TRAITEMENT DU GLAUCOME CHRONIQUE A ANGLE OUVERT: LE MALEATE DE TIMOLOL. EFFET TENSIONNEL DE L’INSTILLATION D’UNE GOUTTE. Foreign language
Demailly P, Allaire C, Bron V, Trinquand C. Effectiveness and Tolerance of beta-Blocker/Pilocarpine Combination Eye Drops in Primary Open-Angle Glaucoma and High Intraocular Pressure. J Glaucoma. 95 ;4(4):235-41. Other (specify):not FDA approved
Demailly P, Aubrier G, Abadie P. Timolol and functional perimetric prognosis of primary open-angle glaucoma. Foreign language
Demailly P, Gruber D, Kretz G. Treatment of chronic primary open-angle glaucoma. Long-term functional results. J Fr Ophtalmol. 89; 12(8–9):527-34. It is a case series
Demailly P, Jeanteur-Lunel MN, Berkani M, Ecoffet M, Kopel J, Kretz G, Lavat P. Non-penetrating deep sclerectomy combined with a collagen implant in primary open-angle glaucoma. Medium-term retrospective results. Foreign language
Demailly P, Kretz G, Gruber D. Trabeculectomy and trabeculo-retraction in the treatment of chronic primary open-angle glaucoma. Long-term tonometric results. J Fr Ophtalmol. 89; 12(8–9):535-42. It is not a RCT and has less than 100 patients
Demailly P, Lavat P, Kretz G, Jeanteur-Lunel MN. Non-penetrating deep sclerectomy (NPDS) with or without collagen device (CD) in primary open-angle glaucoma: middle-term retrospective study. Int Ophthalmol. 96–97; 20(1–3):131-40. Other (specify):and the prospective part does not report harms
Demailly P, Lehner MA, Duperre J. A new beta-blocking agent in the treatment of chronic glaucoma: timolol maleate. Foreign language
Demailly P, Lehner MA, Duperre J. A new beta-blocking agent in the treatment of chronic open-angle glaucoma: timolol maleate. Effect of instillation of 1 drop on the intraocular pressure. Foreign language
Demailly P, Lehner MA, Pigot C. Timolol maleate: results of its long-term action in the treatment of chronic primary open-angle glaucoma. Foreign language
Demailly P, Lehrer M, Kretz G. Argon laser trabeculoretraction in chronic open-angle glaucoma with normal pressure. A prospective study on the tonometric and perimetric effect. Foreign language
Demailly P, Pigot C, Arrata M. Effect of daily instillations of timolol on the nycthemeral tension in subjects with chronic open-angle glaucoma (author’s transl). Foreign language
Demailly P, Valtot F, Kopel J, Ecoffet M. Results 1 year after trabeculoretraction by 360 degree argon laser in the treatment of open-angle glaucoma. J Fr Ophtalmol. 85 ;8(1):11-8. OAG can’t be analyzed separately
Demailly Philippe, Berkani M, Jeanteur Lunel MN, Zogheib R. Non penetrating deep scleroctomy (N.P.D.S.) with or without collagen device (C.D) in primary open-angle glaucoma: middle-term retrospective study. Foreign language
Demailly Philippe, Kretz G, Zogheib R. Argon laser trabeculoplasty: long term results. Arch. chil. oftalmol. 97 ;54(2):111-3. No original data (e.g., systematic review, narrative review, editorial, letter)
Demeter S, Hailey D. Non-penetrating glaucoma surgery using AquaFlow(TM) collagen implants (Structured abstract). Duplicate
Denis P, Andrew R, Wells D, Friren B. A comparison of morning and evening instillation of a combination travoprost 0.004%/timolol 0.5% ophthalmic solution. Eur J Ophthalmol. 2006;16(3):407-15. [pmid: 16761242]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Denis P, Demailly P, Saraux H. Clinical evaluation of betaxolol in ophthalmic suspension with or without preservative agent in patients with glaucoma or ocular hypertension. J Fr Ophtalmol. 93 ;16(5):297-303. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Denis P, Lafuma A, Jeanbat V, Laurendeau C, Berdeaux G. Intraocular pressure control with latanoprost/timolol and travoprost/timolol fixed combinations : a retrospective, multicentre, cross-sectional study. Clin Drug Investig. 2008;28(12):767-76. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Denis P, Launois R, Devaux M, Berdeaux G. Comparison of diurnal intraocular pressure control by latanoprost versus travoprost : results of an observational survey. Clin Drug Investig. 2006;26(12):703-14. Other (specify):Study design not good for KQ (KQ3-24h study)
Denis P, Le Pen C, Umuhire D, Berdeaux G. Treatment carryover impacts on effectiveness of intraocular pressure lowering agents, estimated by a discrete event simulation model. Eur J Ophthalmol. 2008;18(1):44-51. [pmid: 18203084]. No original data (e.g., systematic review, narrative review, editorial, letter)
Denk PO, Dieter M, Knorr M. Prognostic value of anterior chamber hemorrhage following glaucoma filtering surgery. Klin Monbl Augenheilkd. 99 ;214(3):156-9. Data not abstractable
Derick RJ, Evans J, Baker ND. Combined phacoemulsification and trabeculectomy versus trabeculectomy alone: a comparison study using mitomycin-C. Ophthalmic Surg Lasers. 98 ;29(9):707-13. It is combined cataract/glaucoma surgery study published before April 2000
Derick RJ, Robin AL, Tielsch J, Wexler JL, Kelley EP, Stoecker JF, Novack GD, Coleman AL. Once-daily versus twice-daily levobunolol (0.5%) therapy. A crossover study. Unique comparators
Derick RJ, Robin AL, Walters TR, Barnebey HS, Choplin N, Schuman J, Kelley EP, Chen K, Stoecker JF. Brimonidine tartrate: a one-month dose response study. Unique comparators
Derick RJ, Walters TR, Robin AL, Barnebey HS, Choplin NT, Kelley EP, Stoecker JF. BRIMONIDINE TARTRATE: A ONE MONTH DOSE RESPONSE STUDY. Meeting abstract
D’Ermo F, Bonomi L. Trabeculectomy. Results in the treatment of glaucomas. Ophthalmologica. 73 ;166(4):311-20. OAG can’t be analyzed separately
Desai RU, Pekmezci M, Tam D, Song J, Lin SC. Resident-performed Ahmed(trademark) glaucoma valve surgery. Duplicate of 170
Desvignes P. Results of medical treatment in chronic open angle glaucoma. Foreign language
Detry-Morel M, De Hoste F. Treatment of glaucoma with carbonic anhydrase inhibitors in eyewash: medium term retrospective experience with dorzolamide. Foreign language
Detry-Morel M, Dutrieux C. Treatment of glaucoma with brimonidine (Alphagan 0.2%). Foreign language
Detry-Morel M, Dutrieux C. Experience with topical brimonidine (Alphagan(registered trademark) 0,2%) in the treatment of glaucomas. Traitement des glaucomes par la brimonidine (Alphagan(registered trademark) 0,2 %). Foreign language
Detry-Morel M, Kallay O Jr. Role of argon laser trabeculoplasty in the treatment of open-angle glaucoma: a 7-year retrospective experience. Bull Soc Belge Ophtalmol. 90 ;239:119-29. It is a case series
Detry-Morel M. Non penetrating deep sclerectomy (NPDS) with SKGEL implant and/or 5-fluorouracile (5-FU). Bull Soc Belge Ophtalmol. 2001;(280):23-32. [pmid: 11486461]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Detry-Morel M, Muschart F, Pourjavan S. Micropulse diode laser (810 nm) versus argon laser trabeculoplasty in the treatment of open-angle glaucoma: comparative short-term safety and efficacy profile. Bull Soc Belge Ophtalmol. 2008;(308):21-8. [pmid: 18700451]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Devloo S, Deghislage C, Van Malderen L, Goethals M, Zeyen T. Non-penetrating deep sclerectomy without or with autologous scleral implant in open-angle glaucoma: medium-term results. Graefes Arch Clin Exp Ophthalmol. 2005;243(12):1206-12. [pmid: 16003517]. It is not a RCT and has less than 100 patients
Devonport H, Manners TD. Comparison of viscocanalostomy with trabeculectomy in the management of chronic open angle glaucoma. Meeting abstract
Di Staso S, Taverniti L, Genitti G, Marangolo L, Aiello A, Giuffre L, Balestrazzi E. Combined phacoemulsification and deep sclerectomy vs phacoemulsification and trabeculectomy. Acta Ophthalmol Scand Suppl. 2000;(232):59-60. [pmid: 11235542]. It is combined cataract/glaucoma surgery study published before April 2000
Di Tizio A, Catone E, Glorialanza G. Our results in the treatment of open angle glaucoma with timolol maleate. NOSTRI RISULTATI NEL TRATTAMENTO DEL GLAUCOMA AD ANGOLO APERTO CON IL TIMOLOLO MALEATO. Foreign language
Di Tizio A, Mutolo A, Glorialanza G. Epinephrine-oxprenolol association in the treatment of open angle glaucoma. ASSOCIAZIONE ADRENALINA E OXPRENOLOLO NELLA TERAPIA DEL GLAUCOMA AD ANGOLO APERTO. Foreign language
Diafas SG, Day D, Stewart JA, Stewart WC. The use of dorzolamide versus other hypotensive agents to prevent glaucomatous progression. Unique comparators
Dickens CJ, Nguyen N, Mora JS, Iwach AG, Gaffney MM, Wong PC, Tran H. Long-term results of noncontact transscleral neodymium:YAG cyclophotocoagulation. Ophthalmology. 95 ;102(12):1777-81. Data not abstractable
Dickstein K, Hapnes R, Aarsland T. Comparison of aqueous and gellan ophthalmic timolol with placebo on the 24-hour heart rate response in patients on treatment for glaucoma. Am J Ophthalmol. 2001;132(5):626-32. [pmid: 11704023]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Dienstbier E, Ruzickova E, Cepelik J. Metipranolol in the treatment of glaucoma. Introductory clinical study (author’s transl). Foreign language
Diestelhorst M, Almegard B. Comparison of two fixed combinations of latanoprost and timolol in open-angle glaucoma. Graefes Arch Clin Exp Ophthalmol. 98 ;236(8):577-81. Other (specify):not FDA approved
Diestelhorst M. German Latanoprost Study Group. COMPARISON OF FIXED-RATIO COMBINATIONS OF LATANOPROST AND TIMOLOL. A RANDOMISED, DOUBLE-MASKED MULTICENTRE STUDY IN GLAUCOMA PATIENTS WITH TIMOLOL AND LATANOPROST AS CONTROLS. Meeting abstract
Diestelhorst M, Krieglstein GK. The effect of betablockers with and without ISA on tonographic outflow facility. Int Ophthalmol. 89; 13(1–2):63-5. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Diestelhorst M, Larsson LI. A 12 week study comparing the fixed combination of latanoprost and timolol with the concomitant use of the individual components in patients with open angle glaucoma and ocular hypertension. Non-FDA-approved drug combination
Diestelhorst M, Larsson LI. A 12-week, randomized, double-masked, multicenter study of the fixed combination of latanoprost and timolol in the evening versus the individual components. Ophthalmology. 2006;113(1):70-6. [pmid: 16263174]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Diestelhorst M. The additive intraocular pressure-lowering effect of latanoprost 0005% daily once and pilocarpine 2% t.i.d. in patients with open-angle glaucoma or ocular hypertension. a 6-month, randomized, multicenter study. German Latanoprost Study Group. Excluded drug
Diestelhorst M. The additive intraocular pressure-lowering effect of latanoprost 0005% daily once and pilocarpine 2% t.i.d. in patients with open-angle glaucoma or ocular hypertension. A 6-month, randomized, multicenter study. Graefe’s Arch Clin Exp Ophthalmol. 2000;238(5):433-439. Other (specify):pilocarpine
Diestelhorst M, Bechetoille A, Lippa E, Brunner-Ferber F, Krieglstein GK. Stereospecificity of lowering intraocular pressure using a locally administered carbonic anhydrase inhibitor. Fortschr Ophthalmol. 90 ;87(2):131-3. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Diestelhorst M, Khalili MA, Krieglstein GK. Trabeculectomy: retrospective follow-up of 700 eyes. Int Ophthalmol 98–99. 22(4):211-20. OAG can’t be analyzed separately
Diestelhorst M, Roters S, Krieglstein GK. THE EFFECT OF LATANOPROST (PHXA41) ON THE INTRAOCULAR PRESSURE AND AQUEOUS HUMOR PROTEIN CONCENTRATION A RANDOMIZED, DOUBLE MASKED COMPARISON OF 50 μg/ml vs 15 μg/ml WITH TIMOLOL 0.5% AS CONTROL. Meeting abstract
Diestelhorst M, Roters S, Krieglstein GK. The effect of latanoprost 0005% once daily versus 0.0015% twice daily on intraocular pressure and aqueous humour protein concentration in glaucoma patients. A randomized, double-masked comparison with timolol 0.5%. Medical KQ 3 or KQ 3 and KQ 6 only
Diestelhorst M, Schaefer CP, Beusterien KM, Plante KM, Fain JM, Mozaffari E, Dhawan R. Persistency and clinical outcomes associated with latanoprost and beta-blocker monotherapy: evidence from a European retrospective cohort study. Medical KQ 3 only
Diggory P, Franks W. Glaucoma: systemic side effects of topical medical therapy--a common and under recognized problem. J R Soc Med. 94 ;87(10):575-6. No original data (e.g., systematic review, narrative review, editorial, letter)
Diggory P, Cassels-Brown A, Fernandez C. Topical beta-blockade with intrinsic sympathomimetic activity offers no advantage for the respiratory and cardiovascular function of elderly people. Age Ageing. 96 ;25(6):424-8. No subjects with open-angle glaucoma
Diggory P, Cassels-Brown A, Vail A, Abbey L, Hillman JS. Changing from Timolol to the Cardioselective Betaxolo Improves Lung Function and Exercise Tolerance in the Elderly. Meeting abstract
Diggory P, Heyworth P, Chau G, McKenzie S, Sharma A. Unsuspected bronchospasm in association with topical timolol--a common problem in elderly people: can we easily identify those affected and do cardioselective agents lead to improvement?. Age Ageing. 94 ;23(1):17-21. Data not abstractable
Diggory P, Heyworth P, Chau G, McKenzie S, Sharma A, Luke I. Improved lung function tests on changing from topical timolol: non-selective beta-blockade impairs lung function tests in elderly patients. Eye (Lond). 93 ;7(Pt 5):661-3. It is not a RCT and has less than 100 patients
Ding Q, Tan R, Zheng C, Xu W. Comparative analysis of the formation of functional filtration bleb in different incision of conjunctiva flap after trabeculectomy. Foreign language
Dinslage S, Diestelhorst M, Krieglstein GK. A new transdermal alternative for pilocarpine in the treatment of glaucoma. Meeting abstract
Dinslage S, Diestelhorst M, Hille T, Otto K. A new transdermal delivery system for pilocarpine in glaucoma treatment. Ger J Ophthalmol. 96 ;5(5):275-80. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Dirks M. 6-Month Bimatoprost-Latanoprost Study Group. Comparison of IOP-Lowering Efficacy of Bimatoprost and Latanoprost in Patients with Glaucoma or Ocular Hypertension: A Six-month Randomized Clinical Trial. Meeting abstract
Dirks M. Briminodine Study Group. LONG-TERM SAFETY AND IOP-LOWERING EFFICACY OF BRIMONIDINE TARTRATE 0.2% IN GLAUCOMA AND OCULAR HYPERTENSION. Meeting abstract
Dirks M, John WG. Evaluation of Glaucoma Medication Safety, Efficacy and Patient-Reported Outcomes after 12 Months. Meeting abstract
Dirks MS, Girkin CA, Tello C, Choplin NT, Batoosingh A, Bernstein P, Whitcup S. Bimatoprost/Latanoprost Study Group. Comparing the IOP-Lowering Efficacy of Bimatoprost and Latanoprost Within Separate Glaucoma or Ocular Hypertension Patient Subsets. Meeting abstract
Dirks MS, Johnson-Pratt L, Polis A, DeLucca P, Kolodny A, Fletcher C, Cassel D, Boyle D, Skobieranda F. A Comparison of Efficacy, Tolerability, and Patient-Reported Measures Between Cosopt® and the Concomitant Administration of Alphagan® and Timolol. Meeting abstract
Dirks M, Conner C, Barnes SD. A COST MINIMIZATION ANALYSIS COMPARING BRIMONIDINE TO APRACLONIDINE IN IOP CONTROL FOLLOWING ALT. Meeting abstract
Dirks M, Noecker R, Williams R, Earl M. A Comparison of the IOP Lowering Efficacy of Bimatoprost and Latanoprost in the Treatment of Normal Tension Glaucoma. Meeting abstract
Dobler A, Pederson J. MITOMYCIN VS. 5-FLUOROURACIL IN GLAUCOMA FILTERING SURGERY. Meeting abstract
Dobromyslov AN, Alekseev VN, Zagorul’ko AM. The expediency of peripheral iridectomy in the surgical treatment of open-angle glaucoma. Foreign language
Doherty MD, Wride NK, Birch MK, Figueiredo FC. Choroidal detachment in association with topical dorzolamide: is hypotony always the cause. Clin Experiment Ophthalmol. 2009;37(7):750-2. [pmid: 19788679]. It is a case series
Doi LM, Melo LAS Jr, Prata JA Jr. EFFECTS ON INTRAOCULAR PRESSURE IN PRIMARY OPEN-ANGLE GLAUCOMA AFTER COMBINED THERAPY WITH LATANOPROST AND BIMATOPROST: A RANDOMIZED CLINICAL TRIAL. Meeting abstract
Doi LM, Melo LA Jr, Prata JA Jr. Effects of the combination of bimatoprost and latanoprost on intraocular pressure in primary open angle glaucoma: a randomised clinical trial. Unique comparators
Domingo Gordo B, Urcelay Segura JL, Acero Pena A, Luezas Morcuende JJ, Arrevola Velasco L. Dorzolamide: hypotensive efficacy in combination with beta-blockers. Long-term results. Foreign language
Domingo Regany E, Quilis Salcedo M, Massague Camins C. Timolol: adverse cardiorespiratory effects. Foreign language
Dong DQ, Chen G, Hou XW. Clinical observation of the combination of phacoemulsification and trabeculectomy. Foreign language
Donohue EK, Wilensky JT. Trusopt, a topical carbonic anhydrase inhibitor. J Glaucoma. 96;5(1):68-74. No original data (e.g., systematic review, narrative review, editorial, letter)
Donoso R, Armas R, Charlín R, Eggers A, Schweikart A, Varela H, López JP. Randomized prospective study of single intraoperatory exposure A 5-FU in primary trabeculectomy in open angle glaucoma. Archivos Chilenos de. Oftalmología. 1998;55(2):17-25. Other (specify):Non-english
Rodrigo Donoso R, Monsalve Rudy, Monsalve Pablo, Armas Rodolfo, CharlÆn Raimundo, Eggers Koster Andrqs, Khaw Peng, Schhweikart Adolfo, Varela Hernbn, Wilkins Marck. 5-Fluorouracilo intraoperatorio en trabeculectomÆa primaria. Foreign language
Donoso R, Rodriguez A. Combined versus sequential phacotrabeculectomy with intraoperative 5-fluorouracil. J Cataract Refract Surg. 2000;26(1):71-4. [pmid: 10646149]. It is not a RCT and has less than 100 patients
Donoso Rodrigo, RodrÆguez Alonso. Facoemulsificaci£n y trabeculectomÆa con 5-fluorouracil intraoperatorio: operaci£n combinada versus secuencial: un estudio caso control. Foreign language
Donoso Rodrigo, Armas Rodolfo, CharlÆn Raimundo, Eggers Andrqs, Schweikart Adolfo, Varela Hernbn, L£pez Juan Pablo. Estudio prospectivo randomizado de exposici£n intraoperatoria ·nica A 5-FU en trabeculectomÆa primaria en glaucoma de bngulo abierto. Foreign language
Dorigo MT, Cerin O, Fracasso G, Altafini R. Cardiovascular effects of befunolol, betaxolol and timolol eye drops. Int J Clin Pharmacol Res. 90;10(3):163-6. Does not address any key questions
Dorner GT, Rainer G, Garhofer G, Findl O, Georgopoulos M, Polak K, Petternel V, Vass C, Pfleger T, Schmetterer L. Changing antiglaucoma therapy from timolol to betaxolol: Effect on optic disk blood flow. Meeting abstract
Dorzolamide hydrochloride. DRUGS FUTURE. 96;21(4):413-414. No original data (e.g., systematic review, narrative review, editorial, letter)
Douglas GR, Wijsman K. Effects of laser trabeculoplasty on intraocular pressure in the medically untreated eye. Canadian journal of ophthalmology. Journal canadien d’ophtalmologie. 87;22(3):157-60. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Downes SM, Mission GP, Jones HS, O’Neill EC. The predictive value of post-operative intraocular pressures following trabeculectomy. Eye (Lond). 94;8(Pt 4):394-7. Does not address any key questions
Draeger J, Haselmann G, Weber B. The influence of pilocarpine upon the aqueous humour dynamics using ocusert with continuous delivery rate (author’s transl). Klin Monbl Augenheilkd. 75;167(4):527-33. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Draeger J, Haselmann G, Weber B. The influence of pilocarpine upon the aqueous humour dynamics using ocusert with continuous delivery rate. DER EINFLUSS VON PILOCARPIN AUF DIE KAMMERWASSERDYNAMIK BEI VERWENDUNG VON MEDIKAMENTENTRAGERN MIT KONTINUIERLICHER ABGABERATE. Duplicate
Drake MV, Wilson MR, Harris D, Goodwin L. Levobunolol compared to dipivefrin in African American patients with open angle glaucoma. J Ocul Pharmacol. 93;9(2):91-5. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Drance SM. A comparison of the effects of betaxolol, timolol, and pilocarpine on visual function in patients with open-angle glaucoma. J Glaucoma. 98;7(4):247-52. Other (specify):pilocarpine
Drance SM, Nash PA. The dose response of human intraocular pressure to pilocarpine. Can J Ophthalmol. 71;6(1):9-13. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Drance SM, Bensted M, Schulzer M. Pilocarpine and intraocular pressure. Duration of effectiveness of 4 percent and 8 percent pilocarpine instillation. Arch Ophthalmol. 74;91(2):104-6. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Drance SM, Crichton A, Mills RP. Ocular Perfusion Pressure in Normal Tension Glaucoma Patients After Latanoprost or Timolol Treatment. Meeting abstract
Drance SM, Douglas GR, Wijsman KJ, Schulzer M. Adrenergic and adrenolytic effects on intraocular pressure. Graefes Arch Clin Exp Ophthalmol. 91;229(1):50-1. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Drance SM, Mitchell DW, Schulzer M. The effects of ocusert pilocarpine on anterior chamber depth, visual acuity and intraocular pressure in man. Can J Ophthalmol. 77;12(1):24-8. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Duan X, Jiang Y, Mo X. Long-term follow-up study on Hunan aqueous drainage implantation for refractory glaucoma. Foreign language
Duan X, Jiang Y, Qing G. Long-term follow-up study on Hunan aqueous drainage implantation combined with mitomycin C for refractory glaucoma. Foreign language
DuBiner HB, Shapiro AM. Efficacy and Tolerability of Brimonidine vs. Latanoprost as First-Line Therapy for Glaucoma or Ocular Hypertension. Meeting abstract
DuBiner HB, Kothe AC, Sharma V, Mallick S, Andrew RM, Sullivan EK, Weiner AL, DeSantis LM, Krueger S, Bergamini MVW. Study Group. A comparison of the diurnal IOP-lowering efficacy of levobetaxolol 0.5% vs. brimonidine 0.2% in patients with open-angle glaucoma or ocular hypertension. Meeting abstract
Dubiner HB, Gross R, Ochsner K, Peace J, Smith S, Walters T, Weiss M, Dickerson J. TRAVATAN®Z AND TRAVATAN® PROVIDE SIMILAR LONG-LASTING IOP-LOWERING EFFICACY. Meeting abstract
DuBiner HB, Hill R, Kaufman H, Keates EU, Zimmerman TJ, Mandell AI, Mundorf TK, Bahr RL, Schwartz LW, Towey AW, Hurvitz LM, Starita RJ, Sassani JW, Ropo A, Gunn R, Stewart WC. Timolol hemihydrate vs timolol maleate to treat ocular hypertension and open-angle glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
DuBiner HB, Mroz M, Shapiro AM, Dirks MS. A comparison of the efficacy and tolerability of brimonidine and latanoprost in adults with open-angle glaucoma or ocular hypertension: a three-month, multicenter, randomized, double-masked, parallel-group trial. Medical KQ 3 or KQ 3 and KQ 6 only
DuBiner H, Cooke D, Dirks M, Stewart WC, VanDenburgh AM, Felix C. Efficacy and safety of bimatoprost in patients with elevated intraocular pressure: a 30-day comparison with latanoprost. Non-FDA-approved drug combination
DuBiner H, Mroz M, Shapiro A. EFFICACY AND TOLERABILITY OF BRIMONIDINE VERSUS LATANOPROST AS FIRST-LINE THERAPY FOR GLAUCOMA OR OCULAR HYPERTENSION. Meeting abstract
Duch S, Duch C, Pasto L, Ferrer P. Changes in depressive status associated with topical beta-blockers. Int Ophthalmol. 92; 16(4–5):331-5. It is not a RCT and has less than 100 patients
Ducousso F, Coulon P, Kovalski JL, Barach D, Ballion JC, Bazin S, Roques JC, Verin P. Combined cataract-glaucoma operations. Extracapsular extraction and trabeculectomy versus phacoemulsification and trabeculectomy. J Fr Ophtalmol. 94; 17(8–9):475-85. It is combined cataract/glaucoma surgery study published before April 2000
Duff GR, Newcombe RG. The 12-hour control of intraocular pressure on carteolol 2% twice daily. Medical KQ 3 or KQ 3 and KQ 6 only
Duff GR, Watt AH, Graham PA. A comparison of the effects of oral nadolol and topical timolol on intraocular pressure, blood pressure, and heart rate. Br J Ophthalmol. 87;71(9):698-700. Data not abstractable
Duff G, Graham P, Watt A. Comparison of ocular and cardiovascular effects of oral nadolol and topical timolol in patients at risk of glaucoma. [abstract]. British Journal of Pharmacology. 86;89:711. Does not address any key questions
Dunker S, Schmucker A, Maier H. Tolerability, quality of life, and persistency of use in patients with glaucoma who are switched to the fixed combination of latanoprost and timolol. Adv Ther. 2007;24(2):376-86. [pmid: 17565929]. Other (specify):not FDA approved combination
Dunn M. Timolol-induced bronchospasm. JAMA. 82;247(1):27-8. No original data (e.g., systematic review, narrative review, editorial, letter)
Durante A, Aurilia P, Guarnaccia G, Boles Carenini B. The hypotensive efficacy of dorzolamide HCL-timolol maleate 0.50% vs concomitant use of the two drugs. Medical KQ 3 only
Duzman E, Ober M, Scharrer A, Leopold IH. A clinical evaluation of the effects of topically applied levobunolol and timolol on increased intraocular pressure. Medical KQ 3 or KQ 3 and KQ 6 only
Duzman E, Quinn CA, Warman A, Warman R. One-month crossover trial comparing the intraocular pressure control of 3.4% Piloplex twice daily with 2.0% pilocarpine four times daily. Acta Ophthalmol (Copenh). 82;60(4):613-21. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Easty DL, Nemeth-Wasmer G, Vounatsos JP, Girard B, Besnainou N, Pouliquen P, Delval L, Rouland JF. Comparison of a non-preserved 0.1% T-Gel eye gel (single dose unit) with a preserved 0.1% T-Gel eye gel (multidose) in ocular hypertension and glaucomatous patients. Medical KQ 3 or KQ 3 and KQ 6 only
Eckhardt B, Hutz W. Revision suture in covered goniotrepanation. Ophthalmologe. 93;90(6):578-80. It is a case series
Ecoffet M, Demailly Ph. Middle-term double blind study in the treatment of chronic open angle glaucoma: Comparison between Metipranolol and Timolol. RESULTATS D’UNE ETUDE A MOYEN TERME A DOUBLE INSU COMPARANT LE METIPRANOLOL AU TIMOLOL DANS LE TRAITEMENT DU GLAUCOME PRIMITIF A ANGLE OUVERT. Foreign language
Ecoffet M, Demailly P. Mid-term results of a double-blind study comparing metipranolol to timolol in the treatment of primary open-angle glaucoma. J Fr Ophtalmol. 87; 10(6–7):451-4. It is not a RCT and has less than 100 patients
Ederer F, Gaasterland DA, Dally LG, Kim J, VanVeldhuisen PC, Blackwell B, Prum B, Shafranov G, Allen RC, Beck A. The Advanced Glaucoma Intervention Study (AGIS): 13. Comparison of treatment outcomes within race: 10-year results. Ophthalmology. 2004;111(4):651-64. [pmid: 15051195]. OAG can’t be analyzed separately
Edmunds B, Bunce CV, Thompson JR, Salmon JF, Wormald RP. Factors associated with success in first-time trabeculectomy for patients at low risk of failure with chronic open-angle glaucoma. Ophthalmology. 2004;111(1):97-103. [pmid: 14711719]. Does not address any key questions
Edmunds B, Thompson JR, Salmon JF, Wormald RP. The National Survey of Trabeculectomy. II. Variations in operative technique and outcome. Eye (Lond). 2001;15(Pt 4):441-8. [pmid: 11767016]. Other (specify):No control group
Edmunds B, Thompson JR, Salmon JF, Wormald RP. The National Survey of Trabeculectomy. III. Early and late complications. Eye (Lond). 2002;16(3):297-303. [pmid: 12032721]. Other (specify):case series
Eendebak GR, Boen-Tan TN, Bezemer PD. Long-term follow-up of laser trabeculoplasty. Doc Ophthalmol. 90; 75(3–4):203-14. Other (specify):Study design does not match KQ
Egbert PR, Fiadoyor S, Budenz DL, Dadzie P, Byrd S. Diode laser transscleral cyclophotocoagulation as a primary surgical treatment for primary open-angle glaucoma. Arch Ophthalmol. 2001;119(3):345-50. [pmid: 11231767]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Egbert PR, Williams AS, Singh K, Dadzie P, Egbert TB. A prospective trial of intraoperative fluorouracil during trabeculectomy in a black population. Am J Ophthalmol. 93;116(5):612-6. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Egge K, Zahl PH. Survival of glaucoma patients. Acta Ophthalmol Scand. 99;77(4):397-401. Does not address any key questions
Eggers Koster Andrqs, Kychenthal B Andrqs. acotrabeculectomÆa. Foreign language
Egorov EA, Khiva SA. Effectiveness of timolol maleate in hypotensive therapy of glaucoma. Foreign language
Egorov EA, Shmeleva IA. Results of the clinical study of a new adrenergic beta blocker levobunolol hydrochloride in healthy subjects and in patients with glaucoma. Foreign language
Egorov EA, Tsibaneva EV, Egorov AE. Efficacy of pilocarpine and timolol maleate combination in therapy of glaucoma. Foreign language
Egorov E, Ropo A. Adjunctive use of tafluprost with timolol provides additive effects for reduction of intraocular pressure in patients with glaucoma. Duplicate
Egorov E, Ropo A. Investigators. Adjunctive use of tafluprost with timolol provides additive effects for reduction of intraocular pressure in patients with glaucoma. European journal of ophthalmology. 2009;19(2):214-22. [pmid: 19253237]. Other (specify):tafluprost
Egorov VV, Sorokin EL, Smoliakova GP. Differentiated approaches to the treatment of nonstabilized primary open-angle glaucoma with normalized intraocular pressure considering its pathogenic features. Foreign language
Ehrnrooth P, Lehto I, Puska P, Laatikainen L. Effects of early postoperative complications and the location of trephined block on long-term intraocular pressure control after trabeculectomy. Graefes Arch Clin Exp Ophthalmol. 2003;241(10):803-8. [pmid: 14605901]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Ehrnrooth P, Lehto I, Puska P, Laatikainen L. Long-term outcome of trabeculectomy in terms of intraocular pressure. Acta Ophthalmol Scand. 2002;80(3):267-71. [pmid: 12059864]. Other (specify):No control group
Ehrnrooth P, Puska P, Lehto I, Laatikainen L. Progression of visual field defects and visual loss in trabeculectomized eyes. Graefes Arch Clin Exp Ophthalmol. 2005;243(8):741-7. [pmid: 15700183]. It is a case series
Eid TM. Combined viscocanalostomy-trabeculectomy for management of far-advanced glaucoma: evaluation of the early postoperative course. Ophthalmic Surg Lasers Imaging. 2008;39(5):358-66. [pmid: 18831416]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Eisenberg D. CME and anterior uveitis with latanoprost use. Ophthalmology. 1978;98;105(11). author reply 1980–1. No original data (e.g., systematic review, narrative review, editorial, letter)
Eisenberg DL. Additive efficacy of unoprostone isopropyl 0.12% (rescula) to latanoprost 0.005%. Am J Ophthalmol. 2001;132(3):448-9. [pmid: 11554383]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Eisenberg D. Latanoprost versus bimatoprost. Ophthalmology. 2003;110(9):1861-2. author reply 1862. [pmid: 13129903]. No original data (e.g., systematic review, narrative review, editorial, letter)
Eisenberg D. Randomized clinical trial comparing intraocular pressure-lowering efficacy of bimatoprost and latanoprost in patients with ocular hypertension or glaucoma. Am J Ophthalmol. 2003;136(1):217. author reply 217–8. [pmid: 12834708]. No original data (e.g., systematic review, narrative review, editorial, letter)
El Sayyad FF, El-Tal M, Salah A, ElKholify H, El-Husseiny M, Saleh MF. A randomized clinical trial of adjunctive intraoperative 5-fu in bilateral primary open angle glaucoma (poag): 5-year results. Meeting abstract
El Sayyad FF, Helal MH, El-Kholify H, Khalil M, El Maghraby A. Non-Penetrating Deep Sclerectomy versus Trabeculectomy in Bilateral Primary Open-Angle Glaucoma (POAG). Meeting abstract
El Sayyad FF, Helal M, El-Hamzawey H, El-Maghraby MA. Superior Mitomycin (MMC) Filter Combined with Temporal Clear Corneal Phacoemulsification (TCC Phaco) and Foldable IOL. Meeting abstract
El Sayyad F, Belmekki M, Helal M, Khalil M, El-Hamzawey H, Hisham M. Simultaneous subconjunctival and subscleral mitomycin-C application in trabeculectomy. Ophthalmology. 2000;107(2):298-301. discussion 302. [pmid: 10690829]. Other (specify):Not a comparison of interest
El Sayyad F, Elsharif Z, Helal M, Balajonda MNG, EI-Maghraby A. Fornix-Based vs. Limbal-Based Tenon’s Flap in Bilateral Trabeculectomy in Primary Open-Angle Glaucoma (POAG),. Meeting abstract
El Sayyad F, Helal MM, Elsherif Z, EI-Maghraby A. Single Plate Molteno Implant Combined with Mitomycin C (MMC) Trabeculectomy in Difficult Glaucomas. Meeting abstract
El Sayyad F, Helal M, El Sherif Z, El-Maghraby MA. Trabeculectomy With Adjunctive Intraoperative 5-Fluorouracil (5-FU) in Primary Open-Angle Glaucoma (POAG). Meeting abstract
El Sayyad F, Helal M, El-Kholify H, Khalil M, El-Maghraby A. Nonpenetrating deep sclerectomy versus trabeculectomy in bilateral primary open-angle glaucoma. Cheng 2009
el Sayyad F, Helal M, el-Maghraby A, Khalil M, el-Hamzawey H. One-site versus 2-site phacotrabeculectomy: a randomized study. J Cataract Refract Surg. 99;25(1):77-82. It is not a RCT and has less than 100 patients
El Sayyad F, Helal M, El-Maghraby MA, Elsherif Z. Glaucoma Drainage Implant Versus Trabeculectomy With Adjunctive Intraoperative Mitomycin-C (MMC) in High-Risk Glaucoma Patients. Meeting abstract
El Sayyad F, Helal M, Elsherif Z, El-Maghraby A. FORNIX-BASED VERSUS LIMBAL-BASED TENON’S FLAP IN BILATERAL TRABECULECTOMY. Meeting abstract
El Sayyad F, Helal M, Elsherif Z, El-Maghraby A. Molteno implant versus trabeculectomy with adjunctive intraoperative mitomycin-C in high-risk glaucoma patients. J. GLAUCOMA. 95;4(2):80-85. OAG can’t be analyzed separately
Eldaly MA. Pneumatic trabecular bypass (PTB): pilot study. Systematic review
Elena PP, Rouland JF, Morel-Mandrino P, Polzer H. THERAPEUTIC EQUIVALENCE OF A TIMOLOL 0.1% HYDROGEL (T-GEL 0.1%) QD AND AQUEOUS TIMOLOL 0.5% BID IN REDUCING THE IOP OF GLAUCOMATOUS PATIENTS. Meeting abstract
Eliezer RN, Coen R, Umbelino CC, Pinheiro RK, Mandia C, Kasarara N, Almeida GVd, Malta RFS, Malta RFS. Use of Amniotic Membrane in Trabeculectomy for the Treatment of Glaucoma - A Pilot Study. Meeting abstract
Ellis PP. Urinary calculi with methazolamide therapy. Doc Ophthalmol. 73;34(1):137-42. It is a case series
Ellis PP, Price PK, Kelmenson R, Rendi MA. Effectiveness of generic acetazolamide. Arch Ophthalmol. 82;100(12):1920-22. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Elman J, Caprioli J, Rosanelli EG Jr, Shields R, Mead A, Sears M, Petillo J. Celiprolol versus timolol and placebo: a two week double-blind comparison. J Ocul Pharmacol. 87;3(1):5-10. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Elsas T, Johnsen H, Brevik TA. The immediate pressure response to primary laser trabeculoplasty--a comparison of one- and two-stage treatment. Acta Ophthalmol (Copenh). 89;67(6):664-8. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Elsas T, Johnsen H, Stang O, Fygd O. Pressure increase following primary laser trabeculoplasty. Effect on the visual field. Acta Ophthalmologica. 94;72(3):297-302. It is not a RCT and has less than 100 patients
El-Sayyad FF, Helal MH, Khalil MM, El-Maghraby MA. Phacotrabeculectomy versus two-stage operation: a matched study. Ophthalmic Surg Lasers. 99;30(4):260-5. It is combined cataract/glaucoma surgery study published before April 2000
El-Sayyad F, El-Maghraby A, Amayam A, Helal M. Fornix-Based Versus Limbal-Based Conjunctival Flap in Trabeculectomy with 5-Fluorouracil (5-FU). Meeting abstract
Emarah AM, El-Helw MA. Anterior Lens Capsule Versus Mitomycin-C as an Adjunct to Trabeculectomy in Combined Phacotrabeculectomy. J Glaucoma. 2010. OAG can’t be analyzed separately
Emarah MH, El-Metwalli NR, Emarah AM, El-Serogy HM, Zaki NS. Initial filtration surgery vs medical therapy for managing chronic simple glaucoma. Meeting abstract
Emmerich KH. Latanoprost-monotherapy in comparison with adjunction of timolol and dorzolamide in patients with glaucoma or ocular hypertension. Meeting abstract
Emmerich KHA. Comparison of Latanoprost Monotherapy to Dorzolamide Combined with Timolol in Glaucoma and Ocular Hypertension Patients. Meeting abstract
Emmerich KH. Comparison of latanoprost monotherapy to dorzolamide combined with timolol in patients with glaucoma and ocular hypertension. A 3-month randomised study. KQ 3 RCT
Englert JA, Cox TA, Allingham RR, Shields MB. Argon vs diode laser trabeculoplasty. Am J Ophthalmol. 97;124(5):627-31. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Englund GW. Fatal pancytopenia and acetazolamide therapy. JAMA. 69;210(12):2282. It is a case series
Epstein DL, Krug JH Jr, Hertzmark E, Remis LL, Edelstein DJ. A long-term clinical trial of timolol therapy versus no treatment in the management of glaucoma suspects. Maier, 2005
Epstein DL, Krug JH Jr, Hertzmark E, Remis LL, Edelstein DJ. Early treatment study of elevated intraocular pressure (2). J Glaucoma. 93;2(Suppl A):3-4. Data not abstractable
Epstein R, Brown SV, Dennis RF, Konowal-Allen A. Combination of systemic acetazolamide and topical dorzolamide. Ophthalmology. 98;105(9):1581-2. No original data (e.g., systematic review, narrative review, editorial, letter)
Erdogan H, Toker I, Arici MK, Aygen A, Topalkara A. A short-term study of the additive effect of latanoprost 0.005% and brimonidine 0.2%. Jpn J Ophthalmol. 2003;47(5):473-8. [pmid: 12967863]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Erdogan H, Toker MI, Arici MK, Topalkara A. Effect of latanoprost 0.005% and brimonidine 0.2% on intraocular pressure after phacoemulsification and intraocular lens implantation surgery. Jpn J Ophthalmol. 2004;48(6):600-1. [pmid: 15592790]. Does not address any key questions
Ergin A, Ornek K, Gullu R, Bulcun E, Ekici M, Ekici A. Effects of timolol and latanoprost on respiratory and cardiovascular status in elderly patients with glaucoma. J Ocul Pharmacol Ther. 2009;25(5):463-6. [pmid: 19552600]. It is not a RCT and has less than 100 patients
Erichev VP. Comparative evaluation of the hypotensive effectiveness of beta blockers. Foreign language
Erichev VP, Maichuk IuF. Experience with the use of timolol maleate in the therapy of open-angle glaucoma. Foreign language
Erichev VP, Maichuk IuF. Pilaren in the therapy of open-angle glaucoma. Foreign language
Erichev VP, Abdulkadyrova MD, Kalinina OM, Shmyreva VF, Polutornov AL, Egorov EA, Shmeleva IA. Clinical evaluation of the hypotensive effectiveness of Betoptic preparation. Foreign language
Erichev VP, Salminen L, Maichuk IuF. Ocular hypotensive effect of low doses of timolol. Foreign language
Erkin EF, Celik P, Kayikcioglu O, Deveci HM, Sakar A. Effects of latanoprost and betaxolol on cardiovascular and respiratory status of newly diagnosed glaucoma patients. Unique comparators
Ermakova VN. A clinico-pharmacological study of an ophthalmic drug form of proxodolol. Foreign language
Ermakova VN. Results of the use of Thymoptik (timolol) in the treatment of primary glaucoma. Foreign language
Ermakova VN, Iuzhakov SD, Mashkovskii MD, Kolomoitseva EM. Proxodolol, a new domestic preparation for lowering intraocular pressure in glaucoma. Foreign language
Ermakova VN, Malinina SL, Abdulkadyrova MZh. Comparative evaluation of the tolerability of proxofelin and clofelin and their effects on the eye in patients with glaucoma. Foreign language
Ershkovich IG. Trabeculectomy in open-angle glaucoma. Foreign language
Eschstruth P, Schmidt J. External trabeculecomy (ETE): an alternative? A retrospective comparison with goniotrepanation. Foreign language
Eschstruth P, Schmidt J. External trabeculecomy (ETE): An alternative? A retrospective comparison with goniotrepanation. Externe trabekulektomie (ETE): Eine alternative? Eine retrospektive studie zur goniotrepanation. Duplicate
Estudio ultrabiomecroscopico en ablacion trabecular con laser y su relacion con la apariencia de la ampolla conjuntival y la presion intraocular. Foreign language.
Estudo do efeito da trabeculoplastia na redugPo de medicamentos hipotensores oculares utilizados em pacientes glaucomatosos. 2003. Foreign language.
Evans DW, Bartlett J, Houde B, Than T. Effect of Latanoprost Therapy on Contrast Sensitivity in Glaucoma Patients. Meeting abstract
Eyawo O, Nachega J, Lefebvre P, Meyer D, Rachlis B, Lee CW, Kelly S, Mills E. Efficacy and safety of prostaglandin analogues in patients with predominantly primary open-angle glaucoma or ocular hypertension: a meta-analysis. Systematic review
Facio AC, Reis AS, Vidal KS, de Moraes CG, Suzuki R, Hatanaka M, Susanna R. A comparison of bimatoprost 0.03% versus the fixed-combination of latanoprost 0.005% and timolol 0.5% in adult patients with elevated intraocular pressure: an eight-week, randomized, open-label trial. J Ocul Pharmacol Ther. 2009;25(5):447-51. [pmid: 19860553]. Other (specify):not FDA approved
Fama F, Santamaria S. Comparison of the ocular effects of three beta-blockers: Timolol, carteolol, and betaxolol. ANN. OPHTHALMOL. GLAUCOMA. 96;28(5):317-320. Other (specify):Mean age less than 50
Fang A, Xu M, Li Y, Ye L. Microtrebeculectomy in glaucoma. Foreign language
Fanous S, Brouillette G. Combined trabeculectomy and cataract extraction: modified technique. Can J Ophthalmol. 83;18(6):274-7. It is combined cataract/glaucoma surgery study published before April 2000
Faridi UA, Saleh TA, Ewings P, Venkateswaran M, Cadman DH, Samarasinghe RA, Vodden J, Claridge KG. Comparative study of three prostaglandin analogues in the treatment of newly diagnosed cases of ocular hypertension, open-angle and normal tension glaucoma. Medical KQ 3 only
Faulkner W. Miotic effect of alphagan P. J Cataract Refract Surg. 2003;29(3):423. [pmid: 12662989]. It is a case series
Fechtner RD, Airaksinen PJ, Getson AJ, Lines CR, Adamsons IA. Efficacy and tolerability of the dorzolamide 2%/timolol 0.5% combination (COSOPT(trademark)) versus latanoprost 0.005% (XALATAN(trademark)) in the treatment of ocular hypertension or glaucoma: Results from two randomized clinical trials. Medical KQ 3 or KQ 3 and KQ 6 only
Fechtner RD, Airaksinen PJ, Getson AJ, Lines CR, Adamsons IA. Efficacy and tolerability of the dorzolamide 2%/timolol 0.5% combination (COSOPT) versus 0.005% (XALATAN) in the treatment of ocular hypertension or glaucoma: results from two randomized clinical trials. Medical KQ 3 only
Fechtner RD, Godfrey DG, Budenz D, Stewart JA, Stewart WC, Jasek MC. Prevalence of ocular surface complaints in patients with glaucoma using topical intraocular pressure-lowering medications. Cornea. 2010;29(6):618-21. [pmid: 20386433]. Data not abstractable
Fechtner RD, Harasymowycz P, Nixon DR, Vold SD, Zaman F, Williams JM, Hollander DA. Twelve-week, randomized, multicenter study comparing a fixed combination of brimonidine-timolol with timolol as therapy adjunctive to latanoprost. Clin Ophthalmol. status =Glaucoma Division, University of Medicine and Dentistry New Jersey, Newark, NJ, USA;. 2011;5:945-53. [pmid: 21792284]. OAG can’t be analyzed separately
Feghali JG, Klussmann KG, Viti AJ. Effect of the Tightness of Scleral Flap Closure on the Outcome of Trabeculectomy and Its Complications. Meeting abstract
Feghali JG, Kaufman PL. Decreased intraocular pressure in the hypertensive human eye with betaxolol, a beta 1-adrenergic antagonist. Medical KQ 3 or KQ 3 and KQ 6 only
Feghali JG, Kaufman PL, Radius RL, Mandell AI. A comparison of betaxolol and timolol in open angle glaucoma and ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Feibel RM. High incidence of topical allergic reactions to 1% apraclonidine. Arch Ophthalmol. 95;113(12):1579-80. No original data (e.g., systematic review, narrative review, editorial, letter)
Feibel RM. Monocular drug trial. Ophthalmology. 2010;117(5):1048. author reply 1048. [pmid: 20438967]. No original data (e.g., systematic review, narrative review, editorial, letter)
Feiler-Ofry V, Godel V, Lazar M. Nail pigmentation following timolol maleate therapy. Ophthalmologica. 81;182(3):153-6. It is a case series
Feldman RM. A Comparison of Fixed Combination of Latanoprost and Timolol with Fixed Combination of Dorzolamide and Timolol (COSOPT) in Patients With Elevated Intraocular Pressure: A Three-month Masked Evaluator, Phase IIIb, Multicenter Study in the United States (XALCOM vs. COSOPT). Meeting abstract
Feldman RM, Prager TC, Baker L, Chuang AZ. Additivity Study Group. Additivity of Brinzolamide vs. Brimonidine 0.15% to Travoprost 0.004%. Meeting abstract
Feldman RM, Stewart RH, Stewart WC, Jia G, Gergich K, Smugar SS, Galet VA. 24-Hour Diurnal IO P Lowering Efficacy of 2% Dorzolamide/0.5% Timolol Maleate Combination phthalmic Solution in Open Angle Glaucoma or Ocular Hypertension. Meeting abstract
Feldman RM, Stewart RH, Stewart WC, Jia G, Gergich K, Smugar SS, Galet VA. 24-hour Diurnal IOP Lowering Efficacy of 2% Dorzolamide/0.5% Timolol Maleate Combination Ophthalmic Solution in Open Angle Glaucoma or Ocular Hypertension. Meeting abstract
Feldman RM, Stewart RH, Stewart WC, Jia G, Smugar SS, Galet VA. 24-hour control of intraocular pressure with 2% dorzolamide/0.5% timolol fixed-combination ophthalmic solution in open-angle glaucoma. Unique comparators
Feldman RM, Tanna AP, Gross RL, Chuang AZ, Baker L, Reynolds A, Prager TC. Comparison of the ocular hypotensive efficacy of adjunctive brimonidine 0.15% or brinzolamide 1% in combination with travoprost 0.004%. Medical KQ 3 only
Feldman Robert M. Actualizaci£n sobre la combinaci£n de latanoprost y timolol, en proporci£n fija, para el tratamiento de glaucoma de bngulo abierto y la hipertensi£n ocular. Foreign language
Fellenbaum PS. Six-month randomized clinical trial comparing intraocular pressure-lowering efficacy of bimatoprost and latanoprost in patients with ocular hypertension or glaucoma. Am J Ophthalmol. 2003;136(2):392. author reply 392–3. [pmid: 12888081]. No original data (e.g., systematic review, narrative review, editorial, letter)
Fellman R, Budenz D. Malignant glaucoma. J Glaucoma. 99;8(2):149-53. No original data (e.g., systematic review, narrative review, editorial, letter)
Fellman RL. Travoprost Study Group. TRAVOPROST IS SUPERIOR TO TIMOLOL IN LOWERING IOP IN PATIENTS WITH OPEN-ANGLE GLAUCOMA OR OCULAR HYPERTENSION. Meeting abstract
Fellman RL, Starita RJ, Spaeth GL, Poryzees EM. ALT: argon laser trabeculoplasty following failed trabeculectomy. J Ophthalmic Nurs Technol. 86;5(2):65-8. [pmid: 3635636]. It is not a RCT and has less than 100 patients
Fellman RL, Sullivan EK, Ratliff M, Silver LH, Whitson JT, Turner FD, Weiner AL, Davis AA. Comparison of travoprost 0.0015% and 0.004% with timolol 0.5% in patients with elevated intraocular pressure: a 6-month, masked, multicenter trial. Medical KQ 3 or KQ 3 and KQ 6 only
Feltgen N, Mueller H, Ott B, Frenz M, Funk J. Endoscopically controlled erbium: YAG goniopuncture versus trabeculectomy: effect on intraocular pressure in combination with cataract surgery. Graefes Arch Clin Exp Ophthalmol. 2003;241(2):94-100. [pmid: 12605262]. Other (specify):comparison of 2 case series
Feng J-H, Song W-L, Zhao C-Y. Mitomycin C and sodium hyaluronate in tabeculectomy. Foreign language
Feng Y. Trabeculectomy combined with mitomycin C and removed suture in glaucoma. Foreign language
Feng Z. Remote results of trabeculectomy (author’s transl). Foreign language
Fenton RM, Rubin BI, de Smet MD, Whitcup SM, Nussenblatt RB. A PROSPECTIVE STUDY OF 5-FU TRABECULECTOMY VS SINGLE PLATE MOLTENO IMPLANT IN PATIENTS WITH PANUVEITIS COMPLICATED BY GLAUCOMA REFRACTORY TO PRIOR THERAPY. Meeting abstract
Ferguson JG Jr, Macdonald R Jr. Trabeculectomy in blacks: a two-year follow-up. Ophthalmic Surg. 77;8(6):41-3. It is not a RCT and has less than 100 patients
Fernandez S, Pardinas N, Laliena JL, Pablo L, Diaz S, Perez S, Honrubia FM. Long-term tensional results after trabeculectomy. A comparative study among types of glaucoma and previous medical treatment. Arch Soc Esp Oftalmol. 2009;84(7):345-51. [pmid: 19658052]. Other (specify):only patients without surgical failure, It is a case series
Fernandez-Barrientos Y, Garcia-Feijoo J, Martinez-de-la-Casa JM, Pablo LE, Fernandez-Perez C, Garcia Sanchez J. Fluorophotometric study of the effect of the glaukos trabecular microbypass stent on aqueous humor dynamics. Invest Ophthalmol Vis Sci. 2010;51(7):3327-32. [pmid: 20207977]. Other (specify):unique comparator, Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Fernandez-Vozmediano JM, Blasi NA, Romero-Cabrera MA, Carrascosa-Cerquero A. Allergic contact dermatitis to timolol. Contact Dermatitis. 86;14(4):252. It is a case series
Ferri M, Parmeggiani F, Gasparrini E, Gavioli I, Peruz G, Maciga C, Costagliola C. Topical administration of apraclonidine 0.1% and brimonidine 0.2% in patients affected by primary open-angle glaucoma: Effects on ocular perfusion pressure and visual field parameters. Somministrazione topica di apraclonidina 0.1% e brimonidina 0.2% in pazienti affetti da glaucoma primario ad angolo aperto: Effetti sulla pressione di perfusione oculare e sugli indici perimetrici. Foreign language
Ferry AP, Lichtig M. Gouty arthritis as a complication of acetazolamide (Diamox) therapy for glaucoma. Can J Ophthalmol. 69;4(2):145-7. It is a case series
Feuerhake C, Buchholz P, Kimmich F. Efficacy, tolerability and safety of the fixed combination of bimatoprost 0.03% and timolol 0.5% in a broad patient population: multicenter, open-label observational study. Curr Med Res Opin. 2009;25(4):1037-43. [pmid: 19290780]. Other (specify):No control group
Figueiredo Carlos Rubens de, de Figueiredo Bruno Pimentel. Fluxo sangnÆneo ocular em hipotensores oculares t£picos: estudo prospectivo. Foreign language
Figueiredo Carlos Rubens de, Suzuki J·nior EmÆlio Rintaro, Ribeiro Breno Barreto, Figueiredo Bruno Pimentel de, Batista Wagner Duarte, Agostini Netto JoPo. Efeito do Bimatoprost, Latanoprost, Travoprost e Unoprostona na pressPo intra-ocular e no fluxo sangnÆneo ocular. Foreign language
Figueroa AndreÆna, Chocr£n Isaac. Evoluci£n postoperatoria de la cirugÆa filtrante en el Hospital Universitario de Caracas. Foreign language
Figurska M, Rekas M. Effect of local abnormalities and systemic disorders on phacotrabeculectomy and the post-operative period. Foreign language
Fiore PM, Jacobs IH, Goldberg DB. Drug-induced pemphigoid. A spectrum of diseases. Arch Ophthalmol. 87;105(12):1660-3. It is a case series
Fiscella RG. Persistency with glaucoma medication. Am J Ophthalmol. 2004;138(6):1093-4. author reply 1094. [pmid: 15629333]. No original data (e.g., systematic review, narrative review, editorial, letter)
Five-year follow-up of the Fluorouracil Filtering Surgery Study. The Fluorouracil Filtering Surgery Study Group. Wormald 2009
Flach AJ. Efficacy of apraclonidine ophthalmic solution (iopidine) in presumed silicon oil-induced glaucoma and primary open-angle glaucoma. Surv Ophthalmol. 95;40(1):84-5. It is not a RCT and has less than 100 patients
Flad M, Paetzold J, Krapp E, Denk PO, Vonthein R, Schiefer U. Follow-up of Visual Field Defects with Fundus-oriented Perimetry (FOP) - a Comparative Pilot Study in Glaucoma Patients with and without Topical Brimonidine Therapy. Meeting abstract
Flamm C, Wiegand W. Intraocular pressure after cyclophotocoagulation with the diode laser. Ophthalmologe. 2004;101(3):263-7. [pmid: 15007607]. It is a case series
Flamm C, Wiegand W. Intraocular pressure after cyclophotocoagulation with the diode laser. Tensionsverlauf nach Zyklophotokoagulation mit dem Diodenlaser. Ophthalmologe. 2004;101(3):263-267. [pmid: 15007607]. It is a case series
Flammer J, Drance SM. Effect of acetazolamide on the differential threshold. Arch Ophthalmol. 83;101(9):1378-80. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Flammer J, Drance SM. Reversibility of a glaucomatous visual field defect after acetazolamide therapy. Can J Ophthalmol. 83;18(3):139-41. It is not a RCT and has less than 100 patients
Flammer J, Collignon-Brach J, Demailly P, Graves SA. A long-term study of the visual fields in patients treated with betaxolol and timolol. Foreign language
Flammer J, Robert Y, Gloor B. Influence of pindolol and timolol treatment on the visual fields of glaucoma patients. J Ocul Pharmacol. 86;2(4):305-11. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Fledelius HC. Central vein thrombosis and topical dipivalyl epinephrine. Acta Ophthalmol (Copenh). 90;68(4):491-2. Does not address any key questions
Florez A, Roson E, Conde A, Gonzalez B, Garcia-Doval I, de la Torre C, Cruces M. Toxic epidermal necrolysis secondary to timolol, dorzolamide, and latanoprost eyedrops. J Am Acad Dermatol. 2005;53(5):909-11. [pmid: 16243161]. It is a case series
Fluorouracil filtering surgery study one-year follow-up. Am J Ophthalmol. 90;109(5):613-6. No original data (e.g., systematic review, narrative review, editorial, letter). No original data (e.g., systematic review, narrative review, editorial, letter)
Flury H, Tournoux A, Martenet AC. Tolerance and pharmacologic effectiveness of antiglaucoma eyedrops. Klin Monbl Augenheilkd. 86;188(6):573-5. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Fogagnolo P, Rossetti L, Marchini G, Marraffa M, Rolando M, Ciancaglini M, Calabria G, Mastropasqua L, Orzalesi N. The effect of pneumatic trabeculoplasty on intraocular pressure: the results of a 6-month, open-label, multicenter study. Eur J Ophthalmol. 2008;18(6):922-8. [pmid: 18988163]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Follmann P, Turi E. Glaucoma and the dry eye syndrome. Klin Monbl Augenheilkd. 80;176(1):147-52. Data not abstractable
Fong DS, Frederick AR Jr, Richter CU, Jakobiec FA. Adrenochrome deposit. Arch Ophthalmol. 93;111(8):1142-3. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Fontana H, Nouri-Mahdavi K, Lumba J, Ralli M, Caprioli J. Trabeculectomy with mitomycin C: outcomes and risk factors for failure in phakic open-angle glaucoma. Ophthalmology. 2006;113(6):930-6. [pmid: 16647135]. It is a case series
Fontana L, Viswanathan AC, Poinooswamy D, Hitchings RA, Scullica L. Surgery for normal tension glaucoma. Target intraocular pressure and visual field progression. Acta Ophthalmol Scand Suppl. 97(224):43-4. Does not address any key questions
Francis BAA. Multi-Site Evaluation of a Fixed Combination Therapy of Dorzolamide-Timolol (Cosopt®) Compared with Concomitant Administration of a Topical Beta-Blocker and Dorzolamide. Meeting abstract
Francis BA, Du LT, Berke S, Ehrenhaus M, Minckler DS. Comparing the fixed combination dorzolamide-timolol (Cosopt) to concomitant administration of 2% dorzolamide (Trusopt) and 0.5% timolol -- a randomized controlled trial and a replacement study. Medical KQ 3 or KQ 3 and KQ 6 only
Francis BA. Kawji, Vo NT, Dustin L, Chopra V. Endoscopic Cyclophotocoagulation (ECP) in the Management of Uncontrolled Glaucoma With Prior Aqueous Tube Shunt. J Glaucoma. 2010. It is not a RCT and has less than 100 patients
Francis BA, Minckler D, Dustin L, Kawji S, Yeh J, Sit A, Mosaed S, Johnstone M. Combined cataract extraction and trabeculotomy by the internal approach for coexisting cataract and open-angle glaucoma: initial results. J Cataract Refract Surg. 2008;34(7):1096-103. [pmid: 18571075]. Does not address any key questions
Francois J, Goes F, Stockmans L. Acute glaucoma after pilocarpine instillation. Foreign language
Francois J, Goes F, Stockmans L. Acute glaucoma secondary to instillation of pilocarpine. Foreign language
Francois J, Goes F, Zagorski Z. Comparative ultrasonographic study of the effect of pilocarpine 2% and Ocusert P 20 on the eye components. Am J Ophthalmol. 78;86(2):233-8. Other (specify):Mean age below 50
Franks WA, Renard JP, Cunliffe IA, Rojanapongpun P. A 6-week, double-masked, paralle-group study of the efficacy and safety of travoprost 0.004% compared with latanoprost 0:005%/timolol 0.5% in patients with primary open-angle glaucoma or ocular hypertension. Clin Ther. 2006;28(3):332-339. [pmid: 16750448]. Other (specify):uses not FDA approved drug
Franks WA, Renard JP, Cunliffe IA, Rojanapongpun P. A 6-week, double-masked, parallel-group study of the efficacy and safety of travoprost 0.004% compared with latanoprost 0:005%/timolol 0.5% in patients with primary open-angle glaucoma or ocular hypertension. Clin Ther. 2006;28(3):332-9. [pmid: 16750448]. Other (specify):not approved combi
Fraser S. Trabeculectomy and antimetabolites. Br J Ophthalmol. 2004;88(7):855-6. [pmid: 15205223]. No original data (e.g., systematic review, narrative review, editorial, letter)
Fraunfelder FT, Fraunfelder FW. Short-term use of carbonic anhydrase inhibitors and hematologic side effects. Arch Ophthalmol. 92;110(4):446-7. No original data (e.g., systematic review, narrative review, editorial, letter)
Fraunfelder FT. Ocular beta-blockers and systemic effects. Arch Intern Med. 86;146(6):1073-4. No original data (e.g., systematic review, narrative review, editorial, letter)
Fraunfelder FT, Shell JW, Herbst SF. Effect of pilocarpine ocular therapeutic systems on diurnal control of intraocular pressure. Ann Ophthalmol. 76;8(9):1031-9. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
French DD, Margo CE. Glaucoma medications and mortality: a retrospective cohort study. Ann Epidemiol. (12; status =V.A. Center of Excellence on Implementing Evidence Based Practice, Regenstrief Institute Inc., Department of General Internal Medicine and Geriatrics, Indiana University School of Medicine, Indianapolis, USA. Dustin.French2@va.gov). 2010;20:917-23. [pmid: 21074106]. OAG can’t be analyzed separately
Frenkel RE, Noecker RJ, Craven ER. Evaluation of circadian control of intraocular pressure after a single drop of bimatoprost 0.03% or travoprost 0.004%. Curr Med Res Opin. 2008;24(4):919-23. [pmid: 18267054]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Freudenthal J, Yan D. Comparison of Efficacy and Tolerability in an InvestigatorMasked Switch From Cosopt to Combigan in the Treatment of Primary Open-Angle Glaucoma. Meeting abstract
Freyler H, Novack GD, Menapace R, Skorpik C, Mordaunt J, Batoosingh AL. Comparison of the effectiveness and safety of levobunolol and timolol in ocular hypertension and chronic open-angle glaucoma. Klin Monbl Augenheilkd. 88;193(3):257-60. It is not a RCT and has less than 100 patients
Frezzotti P, Ciappetta R, Nuti A, Traversi C, Frezzotti R. 2% IBOPAMINE EYE DROPS IN THE TREATMENT OF TRANSIENT OCULAR HYPOTONY AFTER TRABECULECTOMY IN PRIMARY OPEN-ANGLE GLAUCOMA AND CHRONIC ANGLE-CLOSURE GLAUCOMA. Meeting abstract
Frezzotti P, Mittica V, Martone G, Motolese I, Lomurno L, Peruzzi S, Motolese E. Longterm follow-up of diode laser transscleral cyclophotocoagulation in the treatment of refractory glaucoma. Acta Ophthalmol. 2010;88(1):150-155. [pmid: 19432863]. OAG can’t be analyzed separately
Friederich RL. The pilocarpine Ocusert: a new drug delivery system. Ann Ophthalmol. 74;6(12):1279-84. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Friedland BR, Mallonee J, Anderson DR. Short-term dose response characteristics of acetazolamide in man. Arch Ophthalmol. 77 ; 95(10):1809-12. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Friedman DS, Okeke CO, Jampel HD, Ying GS, Plyler RJ, Jiang Y, Quigley HA. Risk factors for poor adherence to eyedrops in electronically monitored patients with glaucoma. Systematic review
Fristrom B. A 6-month, randomized, double-masked comparison of latanoprost with timolol in patients with open angle glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Fristrom B, Nilsson SE. A double masked comparison of the intraocular pressure reducing effect of latanoprost 0005% and 0001% administered once daily in open angle glaucoma and ocular hypertension. Unique comparators
Fristrom B, Nilsson SE. Interaction of PhXA41, a new prostaglandin analogue, with pilocarpine. A study on patients with elevated intraocular pressure. Arch Ophthalmol. 93 ;111(5):662-5. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Fristrom B, Uusitalo H. A randomized, 36-month, post-marketing efficacy and tolerability study in Sweden and Finland of latanoprost versus non-prostaglandin therapy in patients with glaucoma or ocular hypertension. Acta Ophthalmol. 2010;88(1):37-43. [pmid: 19900212]. Other (specify):Control group poorly described
Fuchsjager-Mayrl G, Georgopoulos M, Hommer A, Weigert G, Pemp B, Vass C, Garhofer G, Schmetterer L. Effect of dorzolamide and timolol on ocular pressure: blood flow relationship in patients with primary open-angle glaucoma and ocular hypertension. Invest Ophthalmol Vis Sci. 2010;51(3):1289-96. [pmid: 19850848]. Does not address any key questions
Fuchsjager-Mayrl G, Rainer G, Georgopoulos M, Buehl W, Vass C, Kircher K, Schmetterer L. Dorzolamide increases ocular blood flow in patients with open angle glaucoma and ocular hypertension. Meeting abstract
Fukuchi T, Suda K, Nakatsue T, Hara H, Abe H. Midterm results and the problems of nonpenetrating lamellar trabeculectomy with mitomycin C for Japanese glaucoma patients. Jpn J Ophthalmol. 2007;51(1):34-40. [pmid: 17295138]. It is not a RCT and has less than 100 patients
Fukuchi T, Ueda J, Yaoeda K, Suda K, Seki M, Abe H. Comparison of fornix- and limbus-based conjunctival flaps in mitomycin C trabeculectomy with laser suture lysis in Japanese glaucoma patients. Jpn J Ophthalmol. 2006;50(4):338-44. [pmid: 16897218]. It is not a RCT and has less than 100 patients
Fukuchi T, Ueda J, Yaoeda K, Suda K, Seki M, Abe H. The outcome of mitomycin C trabeculectomy and laser suture lysis depends on postoperative management. Jpn J Ophthalmol. 2006;50(5):455-9. [pmid: 17013699]. Does not address any key questions
Funk J, Frank A. Long-term reduction of intraocular pressure by goniotrepanation or laser trabeculoplasty. Duplicate 8421
Funk J, Frank A. Long term IOP reduction after goniotrephination or lasertrabeculoplasty. LANGFRISTIGE AUGENDRUCKSENKUNG DURCH GONIOTREPANATION ODER LASERTRABEKULOPLASTIK. Foreign language
Funnell CL, Clowes M, Anand N. Combined cataract and glaucoma surgery with mitomycin C: phacoemulsification-trabeculectomy compared to phacoemulsification-deep sclerectomy. Br J Ophthalmol. 2005;89(6):694-8. [pmid: 15923504]. OAG can’t be analyzed separately
G£mez Toledo patricio. La microcirculaci£n ocular estudiada con eco Doppler color en pacientes con glaucoma y los efectos de dorzolamida timolol en el flujo. Foreign language
Gaasterland DE, Ederer F, et al. The Advanced Glaucoma Intervention Study (AGIS): 7. The relationship between control of intraocular pressure and visual field deterioration. Am J Ophthalmol. 2000;130(4):429-440. [pmid: 11024415]. OAG can’t be analyzed separately
Gafencu O, Carstocea B, Ionita M. Prostaglandin esters--new directions in the treatment of glaucoma. Foreign language
Gagliano C, Ortisi E, Pulvirenti L, Reibaldi M, Scollo D, Amato R, Avitabile T, Longo A. Ocular Hypotensive Effect of Oral Palmitoyl-ethanolamide: A Clinical Trial. Invest Ophthalmol Vis Sci. 2011:6096-100. [pmid: 21705689]. Other (specify):drug not available in US
Galassi F, Giambene B. Deep sclerectomy with SkGel implant: 5-year results. J Glaucoma. 2008;17(1):52-6. [pmid: 18303386]. Does not address any key questions
Gale AE. The safety of topical beta-blockers in glaucoma treatment. Med J Aust. 96 ;165(3):175. It is a case series
Gallardo Vallejo Guadalupe, Montor Pacheco Angqlica MarÆa. Control postoperatorio de la presi£n intraocular en cirugÆa combinada de catarata y glaucoma con tqcnica habitual vs esclerotomÆa. Foreign language
Gallego-Pinazo R, Lopez-Sanchez E, Marin-Montiel J. Postoperative outcomes after combined glaucoma surgery. Comparison of express miniature implant with standard trabeculectomy. Arch Soc Esp Oftalmol. 2009;84(6):293-7. [pmid: 19568989]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Gallenga PE, Mastropasqua L, Carpineto P, Ciancaglini M, Zuppardi E. Delayed postoperative use of 5-fluorouracil in primary open angle glaucoma. Acta Ophthalmol Scand Suppl. 97(224):45-6. Data not abstractable
Galloway GD, Eke T, Broadway DC. Periocular cutaneous pigmentary changes associated with bimatoprost use. Arch Ophthalmol. 2005;123(11):1609-10. [pmid: 16286629]. It is a case series
GalvPo Neto Paulo, Figueiredo Carlos Rubens de, Suzuki J·nior EmÆlio Rintaro, Figueiredo Bruno Pimentel de, Batista Wagner Duarte. Efeito dos beta-bloqueadores na pressPo intraocular e fluxo sangnÆneo ocular pulsbtil. Foreign language
GalvPo-Neto Paulo, Rocha J·nior Fabiano Saulo, Ribeiro Breno Barreto, Silva FelÆcio Arist teles da, Figueiredo Carlos Rubens, Batista Wagner Duarte. Volume da gota dos anblogos das prostaglandinas. Foreign language
Gamero G, Robison M, Harmon H, Goldsmith R, Fechtner R, Zimmerman T. THE DURATION OF ACTION OF DORZOLAMIDE 2% WITH CONCOMITANT USE OF A TOPICAL BETA ADRENERGIC ANTAGONIST. Meeting abstract
Gamm EG. Cause of the appearance of diacarb side effects. Foreign language
Gandol SA, Cimino L, Chetta A. INCIDENCE OF BRONCHIAL HYPER REACTIVITY IN GLAUCOMATOUS SUBJECTS UPON LONGTERM USE OF TOPICAL BETA BLOCKERS. Meeting abstract
Gandolfi SA, Quaranta L, Ungaro N, Cimino L, Sangermani C, Tardini M, Bettelli S. Deep Sclerectomy vs Trabeculectomy in Open Angle Glaucoma. 7-Year Prospective Randomised Clinical Trial. Meeting abstract
Gandolfi SA, Sangermani C, Cimino L, Ungaro N, Tardini M, Viswanathan A, Hitchings R. IS THERE A NON IOP-RELATED EFFECT OF BRIMONIDINE ON VISUAL FIELD PROGRESSIOIN IN HUMAN GLAUCOMA?. Meeting abstract
Gandolfi SA, Cimino L. Deep sclerectomy without absorbable implants and with unsutured scleral flap: pospective, randomized 2-year clinical trial vs trabeculectomy with releasable sutures. Meeting abstract
Gandolfi SA, Cimino L. Effect of 0.03% Bimatoprost on Patients Non-responders to 0.005% Latanoprost: A Cross-over Study. Meeting abstract
Gandolfi SA, Cimino L. Effect of bimatoprost on patients with primary open-angle glaucoma or ocular hypertension who are nonresponders to latanoprost. Medical KQ 3 only
Gandolfi SA, Vecchi M. 5-fluorouracil in combined trabeculectomy and clear-cornea phacoemulsification with posterior chamber intraocular lens implantation. A one-year randomized, controlled clinical trial. Ophthalmology. 97 ;104(2):181-6. It is combined cataract/glaucoma surgery study published before April 2000
Gandolfi SA, Vecchi M. Serial administration of adrenergic antagonist and agonist (“pulsatile therapy”) reduces the incidence of long-term drift to timolol in humans. Invest Ophthalmol Vis Sci. 96 ;37(4):684-8. Data not abstractable
Gandolfi SA. Improvement of visual field indices after surgical reduction of intraocular pressure. Ophthalmic Surg. 95 ;26(2):121-6. It is not a RCT and has less than 100 patients
Gandolfi SA, Cimino L, Vecchi M. Improvement of spatial contrast sensitivity threshold after surgical reduction of intraocular pressure in unilateral high-tension glaucoma. Acta Ophthalmol Scand Suppl. 97(224):40. It is not a RCT and has less than 100 patients
Gandolfi SA, David R. Brimonidine Additive Study Group. ADDITIVE EFFECT OF BRIMONIDINE 0.2% BID OR PILOCARPINE 2.0% TID IN PATIENTS UNCONTROLLED ON BETA-BLOCKER MONOTHERAPY. Meeting abstract
Gandolfi SA, Rossetti L, Cimino L, Mora P, Tardini M, Orzalesi N. Replacing maximum-tolerated medications with latanoprost versus adding latanoprost to maximum-tolerated medications: a two-center randomized prospective trial. Excluded drug
Gandolfi S, Paredes T, Goldberg I, Coote M, Wells A, Volksone L, Pillai MR, Stalmans I, Denis P. Comparison of a travoprost BAK-free formulation preserved with polyquaternium-1 with BAK-preserved travoprost in ocular hypertension or open-angle glaucoma. Eur J Ophthalmol. 2011. Other (specify):Does not report a mean age and 54.7% under age 65
Gandolfi S, Simmons ST, Sturm R, Chen K, VanDenburgh AM. Three-month comparison of bimatoprost and latanoprost in patients with glaucoma and ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Gandolfi S, Traverso CF, Bron A, Sellem E, Kaplan-Messas A, Belkin M. Short-term results of a miniature draining implant for glaucoma in combined surgery with phacoemulsification. Acta Ophthalmol Scand Suppl. 2002;236:66. [pmid: 12390153]. It is not a RCT and has less than 100 patients
Gao W, Chui W, Liu SY, Chen XH, Zhang GR, et al. A clinical comparative study of human amniotic membrane with mitomycin C applied in glaucoma trabeculectomy. Foreign language
Garadi R, Silver L, Landry T, Turner FD. Travoprost Study Group. TRAVOPROST: A NEW ONCE-DAILY DOSED PROSTAGLANDIN FOR THE REDUCTION OF ELEVATED INTRAOCULAR PRESSURE. Meeting abstract
GarcÆa Gonzblez Frank, Sede±o Cruz Ibis, Alema±y Gonzblez Jaime, Peralta Fernbndez Jorge Orlando. Terapia combinada con timolol/dorzolamida versus timolol/pilocarpina en el glaucoma primario de bngulo abierto. Foreign language
Garcia Sanchez J. Efficacy and side effects of latanoprost monotherapy compared to adding dorzolamide to timolol in patients with glaucoma and ocular hypertension--a three-month randomised study. Spanish Latanoprost Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
Garcia F, Blanco J, Juste S, Garces MM, Alonso L, Marcos ML, Carretero P, Perez R. Contact dermatitis due to levobunolol in eyedrops. Contact Dermatitis. 97 ;36(4):230. It is a case series
Garcia-Feijoo J, Martinez-de-la-Casa JM, Castillo A, Mendez C, Fernandez-Vidal A, Garcia-Sanchez J. Circadian IOP-lowering efficacy of travoprost 0.004% ophthalmic solution compared to latanoprost 0.005%. Curr Med Res Opin. 2006;22(9):1689-97. [pmid: 16968572]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Garcia-Feijoo J, Saenz-Frances F, Martinez-de-la-Casa JM, Mendez-Hernandez C, Fernandez-Vidal A, Calvo-Gonzalez C, Garcia-Sanchez J. Comparison of ocular hypotensive actions of fixed combinations of brimonidine/timolol and dorzolamide/timolol. Medical KQ 3 only
Garcia-Perez JL, Puerto-Hernandez B, Rebolleda Fernandez G, Munoz-Negrete FJ, Gonzalez-Gordaliza C. Evaluation of the effect of bimatoprost/timolol fixed combination on ocular blood flow in patients with ocular hypertension using colour Doppler imaging. Preliminary study. Foreign language
Garcia-Sanchez J. Xalacom Study Group. Efficacy and Safety of the Fixed Combination Latanoprost/Timolol versus the Unfixed Combination Brimonidine/Timolol in Patients with Elevated Intraocular Pressure: A 6-month, Masked-evaluator Study. Meeting abstract
Garcia-Sanchez J, Rouland JF, Spiegel D, Pajic B, Cunliffe I, Traverso C, Landry J. A comparison of the fixed combination of latanoprost and timolol with the unfixed combination of brimonidine and timolol in patients with elevated intraocular pressure. A six month, evaluator masked, multicentre study in Europe. Non-FDA-approved drug combination
Gareis O, Wagner P, Lang GK. Results after combined phacoemulsification and trabeculectomy by scleral tunnel incision and goniotrepanation alone. Klin Monbl Augenheilkd. 97 ;211(6):359-62. It is not a RCT and has less than 100 patients
Garrett MA, Harris A, Kagemann L, Cantor LB, Garzozi HJ, Marino A. SUBSTITUTION OF COSOPT TREATMENT FOR TIMOLOL TREATMENT HASTENS ARTERIOVENOUS PASSAGE IN GLAUCOMA PATIENTS. Meeting abstract
Garrison L, Roth A, Rundle H, Christensen RE. A clinical comparison of three carbonic anhydrase inhibitors. Trans Pac Coast Otoophthalmol Soc Annu Meet. 67 ;51:137-45. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Gartaganis SP, Katsimpris JM, Feretis D, Koliopoulos JX. Intraocular pressure variations after Neodymium:YAG iridotomy using topical 2% dorzolamide. Annals of Ophthalmology-Glaucoma. 2000;32(3):240-244. No subjects with open-angle glaucoma
Garty N, Lusky M, Zalish M, Rachmie R, Greenbaum A, Desatnik H, Neumann R, Howes JF, Melamed S. PILOCARPINE IN SUBMICRON EMULSION FORMULATION FOR TREATMENT OF OCULAR HYPERTENSION: A PHASE II CLINICAL TRIAL. Meeting abstract
Garty N, Melamed S, Ticho U, Zalish M, Howes JF, Rachmiel R, Greenbaum A, Neumann R. ADAPROLOL: A SITE ACTIVE â-BLOCKER FOR THE TREATMENT OF GLAUCOMA; A TWO WEEK CLINICAL TRIAL. Meeting abstract
Garudadri CS, Rao HL, Senthil S. Three-year follow-up of the tube versus trabeculectomy study. Am J Ophthalmol. 2010;149(4):685-6. author reply 686–7. [pmid: 20346785]. No original data (e.g., systematic review, narrative review, editorial, letter)
Garzozi H, Harris A, Kagemann L, Jonescu-Cuypers CP, Rotenstreich Y, Siesky B, Cantor LB, McCranor L, McNulty L. Comparison of dorzolamide and latanoprost in normal-tension glaucoma: effects on IOP and retinal hemodynamics. Meeting abstract
Gasper JR, Stewart JA, Leland T, Stewart WC. EFFICACY AND SAFETY OF BETIMOL™ (TIMOLOL HEMIHYDRATE SOLUTION) GIVEN ONCE DAILY VERSUS TIMOPTIC-XE™ GIVEN ONCE DAILY IN THE TREATMENT OF ELEVATED INTRAOCULAR PRESSURE. Meeting abstract
Gayton JL, Van der Karr MA, Sanders V. Combined cataract and glaucoma procedures using temporal cataract surgery. J Cataract Refract Surg. 96 ;22(10):1485-91. It is combined cataract/glaucoma surgery study published before April 2000
Gayton JL, Van Der Karr M, Sanders V. Combined cataract and glaucoma surgery: trabeculectomy versus endoscopic laser cycloablation. J Cataract Refract Surg. 99 ;25(9):1214-9. It is combined cataract/glaucoma surgery study published before April 2000
Gdih GA, Yuen D, Yan P, Sheng L, Jin YP, Buys YM. Meta-analysis of 1-versus 2-Site Phacotrabeculectomy. Systematic review
Gebhardt DO. Self-administration of eye drops. a patient’s view. Am J Ophthalmol. 2003;136(4):778. author reply 778. [pmid: 14516846]. No original data (e.g., systematic review, narrative review, editorial, letter)
Gedde SJ, Herndon LW, Brandt JD, Budenz DL, Feuer WJ, Schiffman JC. Surgical complications in the Tube Versus Trabeculectomy Study during the first year of follow-up. Am J Ophthalmol. 2007;143(1):23-31. [pmid: 17054896]. Data not abstractable
Gedde SJ, Schiffman JC, Feuer WJ, Herndon LW, Brandt JD, Budenz DL. Three-year follow-up of the tube versus trabeculectomy study. Am J Ophthalmol. 2009;148(5):670-84. [pmid: 19674729]. Data not abstractable
Gedde SJ, Schiffman JC, Feuer WJ, Herndon LW, Brandt JD, Budenz DL. Treatment Outcomes in the Tube versus Trabeculectomy (TVT) Study after Three Years of Follow-Up. Meeting abstract
Gedde SJ, Schiffman JC, Feuer WJ, Herndon LW, Brandt JD, Budenz DL. Treatment outcomes in the tube versus trabeculectomy study after one year of follow-up. Am J Ophthalmol. 2007;143(1):9-22. [pmid: 17083910]. OAG can’t be analyzed separately
Geijssen HC, Greve EL. Prevention of hypotony after trabeculectomies with mitomycin. Doc Ophthalmol. 93 ;85(1):45-9. It is not a RCT and has less than 100 patients
Gelfand YA, Wolpert M. Effects of topical indomethacin pretreatment on argon laser trabeculoplasty: a randomised, double-masked study on black South Africans. The British journal of ophthalmology. 85 ;69(9):668-72. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Genead MA, Fishman GA, Walia S. Efficacy of sustained topical dorzolamide therapy for cystic macular lesions in patients with X-linked retinoschisis. Systematic review
George MK, Emerson JW, Cheema SA, McGlynn R, Ford BA, Martone JF, Shields MB, Wand M. Evaluation of a modified protocol for selective laser trabeculoplasty. J Glaucoma. 2008;17(3):197-202. [pmid: 18414105]. Other (specify):Study design does not match KQ
Georgiadis N, Boboridis K, Halvatzis N, Ziakas N, Moschou V. Low-dose tissue plasminogen activator in the management of anterior chamber fibrin formation. J Cataract Refract Surg. 2003;29(4):729-32. [pmid: 12686240]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Georgopoulos GT, Papaconstantinou DS, Patsea LE, Andreanos DG, Vergados J, Chalkiadakis J, Theodossiadis GP. Laser iridotomy versus low dose pilocarpine treatment in patients with pigmentary glaucoma. Meeting abstract
Georgopoulos GT, Chalkiadakis J, Livir-Rallatos G, Theodossiadis PG, Theodossiadis GP. Combined clear cornea phacoemulsification and trabecular aspiration in the treatment of pseudoexfoliative glaucoma associated with cataract. Graefes Arch Clin Exp Ophthalmol. 2000;238(10):816-21. [pmid: 11127567]. It is combined cataract/glaucoma surgery study published before April 2000
Georgopoulos GT, Livir-Rallatos G, Papaconstantinou DS, Patsea EE, Chalkiadakis J, Theodossiadis GP. A COMPARATIVE STUDY OF COMBINED CLEAR CORNEA PHACOEMULSIFICATION AND TRABECULAR ASPIRATION VS PHACOEMULSIFICATION ALONE IN THE TREATMENT OF PSEUDOEXFOLIATIVE GLAUCOMA ASSOCIATED WITH CATARACT. Meeting abstract
Georgopoulos GT, Papaconstantinou DS, Chalkiadakis I, Patsea ES, Maragos A, Iliakis E, Andreanos DG, Moschos M. Long Term Results of Trabecular Aspiration in the Treatment of Pseudoexfoliative Glaucoma. Meeting abstract
Gerber SL, Cantor LB, Sponsel WE. A comparison of postoperative complications from pressure-ridge Molteno implants versus Molteno implants with suture ligation. Ophthalmic Surg Lasers. 97 ;28(11):905-10. OAG can’t be analyzed separately
Gerkowicz K, Toczolowski J. Cataract cryoextraction combined with trabeculectomy. Foreign language
Gerstenberger A, Marquardt R. Goblet cell density modified by pilocarpine. Fortschr Ophthalmol. 86 ;83(1):46-50. Does not address any key questions
Geyer O, Lazar M, Novack GD, Lue JC, Duzman E. Levobunolol compared with timolol for the control of elevated intraocular pressure. Medical KQ 3 or KQ 3 and KQ 6 only
Geyer O, Lazar M, Novack GD, Shen D, Eto CY. Levobunolol compared with timolol: a four-year study. Medical KQ 3 or KQ 3 and KQ 6 only
Geyer O, Loewenstein A, Lazar M. Glaucoma masked by systemic medications. Arch Intern Med. 91 ;151(6):1236. It is a case series
Geyer O, Neudorfer M, Lazar M. Recurrent choroidal detachment following timolol therapy in previously filtered eye. Choroidal detachment post filtering surgery. Acta Ophthalmol (Copenh). 92 ;70(5):702-3. It is a case series
Geyer O, Rothkoff L, Lazar M. Efficacy of adding dipivefrin to a beta-blocker. Ophthalmology. 90 ;97(10):1245-6. Does not address any key questions
Geyer O, Rothkoff L, Lazar M. Timolol-pilocarpine combined vs timolol and pilocarpine given separately (I). Meeting abstract
Geyer O, Rothkoff L, Lazar M. Timolol-pilocarpine combined vs timolol and pilocarpine given separately. Am J Ophthalmol. 90 ;109(1):111. No original data (e.g., systematic review, narrative review, editorial, letter)
Gharagozloo NZ, Brubaker RF. Effect of apraclonidine in long-term timolol users. Ophthalmology. 91 ;98(10):1543-6. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Gharagozloo NZ, Will N, Brubaker RF. EFFECT OF APRACLONIDINE IN CHRONIC TIMOLOL USERS. Meeting abstract
Ghauri RR, Liu E, Feldman RM, Chang AZ, Arevelo BH. COMPARING THE EFFICACY OF PREDNISOLONE ACETATE TO LOTEPREDNOL ETABONATE AFTER PRIMARY TRABECULECTOMY. Meeting abstract
Ghiaroni Almir, Daher Leila, Jateni Valqria, Villani EugWnia. Faco-trabeculectomia com LIOs dobrbveis: resultados a longo prazo. Foreign language
Gianoli F, Mermoud A. Cataract-glaucoma combined surgery: comparison between phacoemulsification combined with deep sclerectomy, or trabeculectomy. Duplicate
Gianoli F, Mermoud A. Combined surgery: Comparison between phacoemulsification associated with deep sclerectomy or with trabeculectomy. Chirurgie combinee cataracte-glaucome: Comparaison entre phacoemulsification associee a une sclerectomie profonde, ou a une trabeculectomie. Foreign language
Gianoli F, Schnyder CC, Bovey E, Mermoud A. Combined surgery for cataract and glaucoma: phacoemulsification and deep sclerectomy compared with phacoemulsification and trabeculectomy. J Cataract Refract Surg. 99 ;25(3):340-6. It is not a RCT and has less than 100 patients
Gilles WE, West RH, Cebon L. A trial of Timoptol (timolol maleate) in a clinical situation. Aust J Ophthalmol. 80 ;8(2):173-5. Data not abstractable
Gillies MC, Brooks AM, Young S, Gillies B, Simpson JM, Goldberg I. A randomized phase II trial of interferon-alpha2b versus 5-fluorouracil after trabeculectomy. Aust N Z J Ophthalmol. 99 ;27(1):37-44. It is combined cataract/glaucoma surgery study published before April 2000
Gillies MC, McAllister IL, Zhu M, Wong W, Louis D, Arnold JJ, Wong TY. Pretreatment with intravitreal triamcinolone before laser for diabetic macular edema: 6-month results of a randomized, placebo-controlled trial. Investigative ophthalmology & visual science. 2010;51(5):2322-8. [pmid: 20019369]. No subjects with open-angle glaucoma
Gillies WE, Brooks AM. A clinical trial of MK-507, Trusopt, for raised intraocular pressure--the Australian experience. Medical KQ 3 or KQ 3 and KQ 6 only
Gillies WE, Brooks AM. A trial of dorzolamide for glaucoma. Ophthalmic Surg Lasers. 98 ;29(9):728-32. Data not abstractable
Gillies WE, West RH. Timolol maleate and intra-ocular pressure in low-tension glaucoma. Aust J Ophthalmol. 82 ;10(3):183-5. OAG can’t be analyzed separately
Gillies WE, West RH. Timolol maleate and intraocular pressure in low-tension glaucoma. Trans Ophthalmol Soc N Z. 81 ;33:33-5. Does not address any key questions
Gillies WE, West RH, Cebon L. Timoptol--three years on. A study of timolol maleate drops over a longer period. Aust J Ophthalmol. 83 ;11(3):155-7. OAG can’t be analyzed separately
Gilmour DF, Manners TD, Devonport H, Varga Z, Solebo AL, Miles J. Viscocanalostomy versus trabeculectomy for primary open angle glaucoma: 4-year prospective randomized clinical trial. Chai 2010
Gimbel HV. Small Incision Trabeculectomy Combined With Phacoemulsification and Intraocular Lens Implantation. Meeting abstract
Gimbel HV, Meyer D, DeBroff BM, Roux CW, Ferensowicz M. Intraocular pressure response to combined phacoemulsification and trabeculotomy ab externo versus phacoemulsification alone in primary open-angle glaucoma. J Cataract Refract Surg. 95 ;21(6):653-60. It is combined cataract/glaucoma surgery study published before April 2000
Gimbel HV, Penno EE, Ferensowicz M. Combined cataract surgery, intraocular lens implantation, and viscocanalostomy. J Cataract Refract Surg. 99 ;25(10):1370-5. It is combined cataract/glaucoma surgery study published before April 2000
Girma T, Courtright P, Mengistu F, Tamirat T, Birhanu Z. A placebo controlled double blind clinical trial of mitomycin C in primary trabeculectomy in Ethiopian patients. Ethiop Med J. 2006;44(3):253-6. [pmid: 17447391]. Data not abstractable
Giuffrida S, Longo A, Amico V, Cro MG, Uva MG. Efficacy of a New Formulation of Timolol 05% in Sodium Hyaluronate Vehicle Administered Once Daily. Meeting abstract
Giul’alieva DT, Kasimova MD. Results of sinusotrabeculectomy in glaucoma. Foreign language
Glaucoma e catarata: resultados da facoemulsificagåo combinada a trabeculectomia e mitomicina-C. 2000. Foreign language
Glaucoma laser trial. Ophthalmology. 91 ;98(6):841-3. [pmid: 6472820]. Does not address any key questions (see below for questions) No original data (e.g., systematic review, narrative review, editorial, letter), Does not address any key questions
Gliushko DG, Kornienko VV, Sobko EG. The late results of sinusotrabeculectomy in initial open-angle glaucoma. Foreign language
Gloor B, Tholen H. On the problematic nature of laser trabeculoplasty in the course of primary open-angle glaucoma. LASERS LIGHT OPHTHALMOL. 91 4(1):1-6. It is not a RCT and has less than 100 patients
Gloor B, Niederer W, Daicker B. Trabeculectomy: surgical technique, results, indications (author’s transl). Klin Monbl Augenheilkd. 77 ;170(2):241-8. It is a case series
Glover BK, Lee D, Shin DH, Kim C, Abreu MM, Hughes BA. THE EFFECT OF ADJUNCTIVE TRABECULECTOMY ON MOLTENO DRAINAGE TUBE IMPLANTATION IN RECALCITRANT GLAUCOMA CASES. Meeting abstract
Godfrey DA, Peplinski LS, Stewart JA, Stewart WC. A comfort comparison of travoprost BAK-free 0.004% versus latanoprost 0.005% in patients with primary open-angle glaucoma or ocular hypertension. Clin Ophthalmol. 2009;3:189-94. [pmid: 19668564]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Goela A, Damji KF, Daneshvar H, Gilberg SM. Delayed, recurrent hypotonous maculopathy following aqueous suppressant therapy in pseudophakia. Can J Ophthalmol. 99 ;34(7):395-7. It is a case series
Goethals M, Missotten L. Long term trial of timolol in different forms of glaucoma. Bull Soc Belge Ophtalmol. 77 ;179:95-101. Does not address any key questions
Goethals M. Ten-year follow-up of timolol-treated open-angle glaucoma. Surv Ophthalmol. 89 ;33(Suppl):463-4. discussion 471–2. It is not a RCT and has less than 100 patients
Goldberg I. 5-Fluorouracil and filtering surgery. Aust N Z J Ophthalmol. 91 ; 19(3):173. No original data (e.g., systematic review, narrative review, editorial, letter)
Goldberg I, Ritch R, Mietz H, Krieglstein GK. Postoperative application of mitomycin C improves the complete success rate of primary trabeculectomy: a prospective, randomized trial. Graefes Arch Clin Exp Ophthalmol. 2006;244:1429-1436. [pmid: 16598468]. Graefes Arch Clin Exp Ophthalmol. 2007;245(8):1241. author reply 1243. [pmid: 17342505]. No original data (e.g., systematic review, narrative review, editorial, letter)
Goldberg I, Ritch R, Mietz H, Krieglstein GK. Postoperative application of mitomycin C improves the complete success rate of primary trabeculectomy: A prospective, randomized trial. Graefes Arch Clin Exp Ophthalmol. 2006;244:1429-1436. [3]. [pmid: 16598468]. Graefe’s Arch. Clin. Exp. Ophthalmol. 2007;245(8):1241. No original data (e.g., systematic review, narrative review, editorial, letter)
Goldberg I. Comparison of tropical travoprost eye drops given once daily and timolol 0.5% given twice daily in patients with open-angle glaucoma or ocular hypertension. J Glaucoma. 2001;10:414-22. [pmid: 11711841]. J Glaucoma. 2002;11(3):275. [pmid: 12140407]. No original data (e.g., systematic review, narrative review, editorial, letter)
Goldberg I. Pilocarpine-Ocuserts(registered trademark): An extended clinical trial. AUST. J OPHTHALMOL. 78 ;6(2):83-85. It is not a RCT and has less than 100 patients
Goldberg I, Ashburn FS Jr, Kass MA, Becker B. Efficacy and patient acceptance of pilocarpine gel. Am J Ophthalmol. 79 ;88(5):843-6. Other (specify):pilocarpine
Goldberg I, Ashburn FS, Kass MA, Becker B. New broad spectrum anti-glaucoma drop. Med J Aust. 79 ;1(9):396. No original data (e.g., systematic review, narrative review, editorial, letter)
Goldberg I, Crowston JG, Jasek MC, Stewart JA, Stewart WC. Intraocular Pressure-lowering Efficacy of Brinzolamide When Added to Travoprost/Timolol Fixed Combination as Adjunctive Therapy. J Glaucoma. 2010. Data not abstractable
Goldberg I, Crowston JG, Jasek MC, Stewart JA, Stewart WC. Intraocular Pressure-lowering Efficacy of Brinzolamide When Added to Travoprost/Timolol Fixed Combination as Adjunctive Therapy. J Glaucoma. 2010. Other (specify):Combination not included
Goldberg I, Cunha-Vaz J, Jakobsen JE, Nordmann JP, Trost E, Sullivan EK. Comparison of topical travoprost eye drops given once daily and timolol 0.5% given twice daily in patients with open-angle glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Goldberg I, Li XY, Selaru P, Paggiarino D. A 5-year, randomized, open-label safety study of latanoprost and usual care in patients with open-angle glaucoma or ocular hypertension. Unique comparators
Goldenberg-Cohen N, Bahar I, Ostashinski M, Lusky M, Weinberger D, Gaton DD. Cyclocryotherapy versus transscleral diode laser cyclophotocoagulation for uncontrolled intraocular pressure. Ophthalmic Surg Lasers Imaging. 2005;36(4):272-9. [pmid: 16156142]. Data not abstractable
Goldenfeld M, Krupin T, Ruderman JM, Wong PC, Rosenberg LF, Ritch R, Liebmann JM, Gieser DK. 5-Fluorouracil in initial trabeculectomy. A prospective, randomized, multicenter study. Wormald 2009
Goldenfeld M, Wong P, Ruderman J, Rosenberg L, Krupin T, Geiser D, Liebmann J, Ritch R. 5-FLUOROURACIL (5-FU) IN PRIMARY TRABECULECTOMY: A PROSPECTIVE, RANDOMIZED STUDY. Meeting abstract
Goni FJ. 12-week study comparing the fixed combination of brimonidine and timolol with concomitant use of the individual components in patients with glaucoma and ocular hypertension. Unique comparators
Gonzalez JR, Baiza-Duran L, Quintana-Hau J, Tornero-Montano R, Castaneda-Hernandez G, Ortiz M, Alarcon-Oceguera F, Beltran-Loustaunau M, Cortez-Gastelum M, Garciduenas-Mejia J, Gomez-Bastar P, Jimenez-Roman J, Korder-Ortega V, Paczka-Zapata J, Torres-Segura M, Velasco-Gallegos G. Comparison of the stability, efficacy, and adverse effect profile of the innovator 0.005% latanoprost ophthalmic solution and a novel cyclodextrin-containing formulation. Unique comparators
Gonzblez Bouchon J, Varas CA, Gonzblez MI, Gonzblez GM. TrabeculoesclerectomÆa profunda no perforante con mitocina C, sin implante: evaluaci£n prospectiva de 69 casos. Foreign language
Gonzblez Bouchon Josq D, Mariana Gonzblez G, Gonzblez Isabel M, Alejandra Varas C, Montecino M Isabel. TrabeculoesclerectomÆa profunda no perforante versus trabeculectomÆa en glaucoma cr£nico de bngulo abierto. Foreign language
Gonzblez Bouchon Josq Domingo, Gonzblez Gblvez Mariana, Gonzblez Mathiesen Isabel, Barra Pantoja Carmen, Carrasco Zunino Francisca, Cazenave Paulette, Grant Valeria, Barra Rosa, Pradenas Ivonne, Moroni Magaly. Citostbticos en la cirugÆa del glaucoma de mal pron£stico, distintas dosis de 5 fluorouracilo, mitomicina C: estudio en 100 casos. Foreign language
Gos R. Timolol in the treatment of glaucoma (author’s transl). Foreign language
Gosiengfiao DH, Latina MA, Tumbocon JA, Frenkel RE. A Crossover Study to Evaluate the Effect of Topical Dorzolamide and Brimonidine on Ocular Blood Flow in Patients with Primary Open Angle Glaucoma Using the Heidelberg Retinal Flowmeter. Meeting abstract
Goulas MT, Shin DH, Kim C, Eliassi-Rad Schulz L, Juzych MS, Glover BK, Cha SC. COMPARISON OF LONG-TERM OUTCOME OF SELECTIVE LASER TRABECULOPLASTY VS ARGON LASER TRABECULOPLASTY IN CHRONIC OPEN ANGLE GLAUCOMA PATIENTS WITH AND WITHOUT PREVIOUS ALT. Meeting abstract
Goulet RJ 3rd, Phan AD, Cantor LB, WuDunn D. Efficacy of the Ahmed S2 glaucoma valve compared with the Baerveldt 250-mm2 glaucoma implant. Ophthalmology. 2008;115(7):1141-7. [pmid: 18164068]. OAG can’t be analyzed separately
Gouws P. Combination products in clinical practice: Canadian experience. Eur J Ophthalmol. 2007;17(SUPPL 5):S15-17. Does not address any key questions
Goyal S, Beltran-Agullo L, Rashid S, Shah SP, Nath R, Obi A, Lim KS. Effect of primary selective laser trabeculoplasty on tonographic outflow facility: a randomised clinical trial. The British journal of ophthalmology. 2010;94(11):1443-7. [pmid: 20472748]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Goyal S, Beltran-Agullo L, Rashid S, Shah SP, Nath R, Obi A, Lim KS. Effect of primary selective laser trabeculoplasty on tonographic outflow facility: a randomised clinical trial. Systematic review
Goyal S, Beltran-Agullo L, Rashid S, Shah SP, Nath R, Obi A, Lim KS. Effect of primary selective laser trabeculoplasty on tonographic outflow facility: a randomised clinical trial. Br J Ophthalmol. 2010;94(11):1443-7. [pmid: 20472748].
Goyal S, Beltran-Agullo L, Rashid S, Shah SP, Nath R, Obi A, Lim KS. Effect of primary selective laser trabeculoplasty on tonographic outflow facility: a randomised clinical trial. Br J Ophthalmol. (11; status =Department of Ophthalmology, St Thomas’ Hospital, London, UK. shenglim@gmail.com). 2010;94:1443-7. [pmid: 20472748]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Gracner T, Naji M, Hudovernik M, Gracner B, Pahor D. Predictive factors of successful selective laser trabeculoplasty in open-angle glaucoma. Klin Monbl Augenheilkd. 2007;224(12):922-6. [pmid: 18260055]. It is a case series
Gramer E, Gramer G, Buscher A. EFFICACY OF MONO- AND COMBINATION THERAPY WITH BRIMONIDINE 0.2% AND FREQUENCY OF CARDIAC DISEASE AND FAMILY HISTORY OF GLAUCOMA IN THE GLAUCOMAS. A PROSPECTIVE STUDY. Meeting abstract
Granstrom KO. Side-effects with the Diamox therapy of glaucoma. Foreign language
Granstrom PA, Norell S. Visual ability and drug regimen: relation to compliance with glaucoma therapy. Acta Ophthalmol (Copenh). 83 ; 61(2):206-19. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Granstrom PA. Progression of visual field defects in glaucoma. Relation to compliance with pilocarpine therapy. Arch Ophthalmol. 85 ; 103(4):529-31. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Grayson Dk, Chi T, Liebmann JM, Ritch R. SUPERIOR VERSUS INFERIOR ANGLE TREATMENT IN ARGON LASER TRABECULOPLASTY. Meeting abstract
Grayson DK, Ritch R, Camras C, Lustgarten JS, Podos SM. Influence of treatment protocol on the long-term efficacy of argon laser trabeculoplasty. Journal of Glaucoma. 93 ;2(1):7-12. Data not abstractable
Grayson D, Chi T, Liebmann J, Ritch R. Initial argon laser trabeculoplasty to the inferior vs superior half of trabecular meshwork. Arch Ophthalmol. 94 ; 112(4):446-7. Does not address any key questions
Greenfield DS, Liebmann JM, Jee J, Ritch R. Late-onset bleb leaks after glaucoma filtering surgery. Arch Ophthalmol. 98 ; 116(4):443-7. Does not address any key questions
Greff L, Johnson-Pratt L, Skobieranda F, Polis A, Delucca P, Kolodny A, Fletcher C, Cassel D. Comparison of ocular hypotensive effect of cosopt vs concomitant alphagan and timolol. Meeting abstract
Grehn F, Hollo G, Khaw P, Overton B, Wilson R, Vogel R, Smith Z. Factors affecting the outcome of trabeculectomy: an analysis based on combined data from two phase III studies of an antibody to transforming growth factor beta2, CAT-152. Ophthalmology. 2007;114(10):1831-8. [pmid: 17719641]. Does not address any key questions
Grieshaber MC, Pienaar A, Olivier J, Stegmann R. Canaloplasty for primary open-angle glaucoma: long-term outcome. Br J Ophthalmol. 2010;94(11):1478-82. [pmid: 20962352]. It is not a RCT and has less than 100 patients
Grieshaber MC, Pienaar A, Olivier J, Stegmann R. Canaloplasty for primary open-angle glaucoma: long-term outcome. Br J Ophthalmol. (11; status =Department of Ophthalmology, Medical University of Southern Africa, MEDUNSA, Pretoria, South Africa. mgrieshaber@uhbs.ch). 2010;94:1478-82. [pmid: 20962352]. It is not a RCT and has less than 100 patients
Grieshaber MC, Pienaar A, Olivier J, Stegmann R. Comparing two tensioning suture sizes for 360 degrees viscocanalostomy (canaloplasty): a randomised controlled trial. Eye (Lond). 2010;24(7):1220-6. Does not include treatment for open-angle glaucoma (medical, surgical or combined; See addendum for list of interventions). [pmid: 20094068]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Grignolo FM, Gallo R, Tonini L, Rabbione MM, Fea AM. Advanced flap trabeculectomy. Acta Ophthalmol Scand Suppl. 2002;236:60-1. [pmid: 12390149]. It is not a RCT and has less than 100 patients
Grinich NP, Van Buskirk EM, Samples JR. Three-year efficacy of argon laser trabeculoplasty. Ophthalmology. 87 ; 94(7):858-61. Data not abstractable
Gross RL, Peace JH, Smith SE, Walters TR, Dubiner HB, Weiss MJ, Ochsner KI. Duration of IOP reduction with travoprost BAK-free solution. J Glaucoma. 2008;17(3):217-22. [pmid: 18414108]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Gross RL, Pinyero A, Orengo-Nania S. Clinical experience with apraclonidine 0.5%. J Glaucoma. 97 ; 6(5):298-302. Other (specify):Apraclonidine
Gross R, Piltz J, Shin DH, Kass MA, Gordon MO. The Contralateral Effect of Topical Beta-blockers on Intraocular Pressure in theOcular Hypertension Treatment Study. Meeting abstract
Gross Ronald L. Glaucoma: Therapy - New advances in medical management. Foreign language
Grueb M, Rohrbach JM, Bartz-Schmidt KU, Schlote T. Transscleral diode laser cyclophotocoagulation as primary and secondary surgical treatment in primary open-angle and pseudoexfoliatve glaucoma. Graefe’s Arch Clin Exp Ophthalmol. 2006;244(10):1293-1299. It is not a RCT and has less than 100 patients
Gudmundsdottir E, Stefansson E, Bjarnadottir G, Sigurjonsdottir JF, Gudmundsdottir G, Masson M, Loftsson T. Methazolamide 1% in cyclodextrin solution lowers IOP in human ocular hypertension. Invest Ophthalmol Vis Sci. 2000;41(11):3552-4. [pmid: 11006251]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Guedes RA, Guedes VM. Nonpenetrating deep sclerectomy in Brazil: a 3-year retrospective study. Foreign language
Guedes RA, Guedes VM, Chaoubah A. Does phacoemulsification affect the long-term success of non-penetrating deep sclerectomy. Ophthalmic Surg Lasers Imaging. 2010;41(2):228-35. [pmid: 20307042]. Other (specify):study design does not match KQ (3)
Guedes Ricardo Augusto Paletta, Guedes Vanessa Maria Paletta. Resultados press£ricos da esclerectomia profunda nPo penetrante no tratamento do glaucoma primbrio de Gngulo aberto. Foreign language
Guggenbach M, Mojon DS, Bohnke M. Evaluation of phacotrabeculectomy versus trabeculectomy alone. Ophthalmologica. 99 ; 213(6):367-70. It is combined cataract/glaucoma surgery study published before April 2000
Guglielminetti E, Barabino S, Monaco M, Mantero S, Rolando M. HLA-DR expression in conjunctival cells after latanoprost. J Ocul Pharmacol Ther. 2002;18(1):1-9. [pmid: 11858610]. Does not address any key questions
Gulkilik G, Kocabora S, Engin G, Taskapili M, Yilmazli C, Kucuksahin H. Sodium hyaluronate in trabeculectomy: effect on early complications. Clin Experiment Ophthalmol. 2006;34(5):421-4. [pmid: 16872336]. Data not abstractable
Gunawardena KA, Crame N, Mertz B, Shams N. Safety of unoprostone isopropyl 0.15% ophthalmic solution in patients with mild to moderate asthma. Ophthalmologica. 2003;217(2):129-36. [pmid: 12592052]. No subjects with open-angle glaucoma
Gunning FP, Greve EL, Bron AM, Bosc JM, Royer JG, George JL, Lesure P, Sirbat D. Two topical carbonic anhydrase inhibitors sezolamide and dorzolamide in Gelrite vehicle: a multiple-dose efficacy study. Graefes Arch Clin Exp Ophthalmol. 93 ; 231(7):384-8. Does not address any key questions
Guo W-Y, Zhu Y-F, Jin X-H, Meng F-R, Song Y-L, Qian S-H, Sun X-H. Non-penetrating trabecular surgery with T-Flux implant in primary open-angle glaucoma. Foreign language
Gupta N, Weinreb RN. Diode laser transscleral cyclophotocoagulation. J Glaucoma. 97 ; 6(6):426-9. No original data (e.g., systematic review, narrative review, editorial, letter)
Gyasi M, Amoaku W, Debrah O, Awini E, Abugri P. Outcome of trabeculectomies without adjunctive antimetabolites. Ghana Med J. 2006;40(2):39-44. [pmid: 17299564]. It is a case series
Ha S-P, Fan W-Y, Yang Q-L. A comparative study between biotic amniotic membrane and mitomycin C applied in refractory glaucoma trabeculectomy. Foreign language
Halberg GP, Kelly SE, Morrone M. Drug delivery systems for topical ophthalmic medication. Ann Ophthalmol. 75 ; 7(9):1199-1204. 1207. 9. It is not a RCT and has less than 100 patients
Hall JA, WuDunn D, Cantor LB, Palanca-Capistrano AM, Hoop J, Morgan L. Long Term Outcomes of Intraoperative 5-Fluorouracil versus Intraoperative Mitomycin C in Primary Trabeculectomy Surgery. Meeting abstract
Halper LK, Johnson-Pratt L, Dobbins T, Hartenbaum D. A comparison of the efficacy and tolerability of 0.5% timolol maleate ophthalmic gel-forming solution QD and 0.5% levobunolol hydrochloride BID in patients with ocular hypertension or open-angle glaucoma. J Ocul Pharmacol Ther. 2002;18(2):105-13. [pmid: 12002664]. Data not abstractable
Halpern MT, Covert DW, Robin AL. Projected impact of travoprost versus both timolol and latanoprost on visual field deficit progression and costs among black glaucoma subjects. Trans Am Ophthalmol Soc. 2002;100:109-17. discussion 117–8. [pmid: 12545683]. Does not address any key questions
Hamacher T, Spiegel D. Safety and effectiveness of latanoprost (Xalatan) versus fixed combination of dorzolamide and timolol (Cosopt) in patients with open-angel glaucoma. Meeting abstract
Hamacher T, Airaksinen J, Saarela V, Liinamaa MJ, Richter U, Ropo A. Efficacy and safety levels of preserved and preservative-free tafluprost are equivalent in patients with glaucoma or ocular hypertension: results from a pharmacodynamics analysis. Acta Ophthalmol Suppl (Oxf ). 2008;242:14-9. [pmid: 18752510]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Hamacher T, Schinzel M, Scholzel-Klatt A, Neff HM, Maier H, Schlaffer G, Beausencourt E, Jutte M, Scholz R, Lorger C, Stewart WC. Short term efficacy and safety in glaucoma patients changed to the latanoprost 0.005%/timolol maleate 0.5% fixed combination from monotherapies and adjunctive therapies. Br J Ophthalmol. 2004;88(10):1295-8. [pmid: 15377554]. It is a case series
Hamard P, Plaza L, Kopel J, Quesnot S, Hamard H. Deep nonpenetrating sclerectomy and open angle glaucoma. Intermediate results from the first operated patients. J Fr Ophtalmol. 99 ;22(1):25-31. It is not a RCT and has less than 100 patients
Hamard P, Plaza L, Kopel J, Quesnot S, Hamard H. Non penetrating deep sclerectomy and open-angle glaucoma: Mid-term results: Sclerectomie profonde non perforante (SPNP) et glaucome a angle ouvert: Resultats a moyen terme des premiers patients operes. Foreign language
Haneda M, Shirato S, Maruyama K, Ohno Y. Comparison of the additive effects of nipradilol and carteolol to latanoprost in open-angle glaucoma. Jpn J Ophthalmol. 2006;50(1):33-7. [pmid: 16453185]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Hansen AC. Compliance with topical pilocarpine treatment. Am J Ophthalmol. 86 ;102(4):547. No original data (e.g., systematic review, narrative review, editorial, letter)
Hara T. Increased iris pigmentation after use of latanoprost in Japanese brown eyes. Foreign language
Harasymowycz PJ, Papamatheakis DG, Ennis M, Brady M, Gordon KD. Relationship between travoprost and central corneal thickness in ocular hypertension and open-angle glaucoma. Cornea. 2007;26(1):34-41. [pmid: 17198011]. It is a case series
Harasymowycz P, Hutnik CM, Nicolela M, Stewart WC. Latanoprost versus timolol gel-forming solution once daily in primary open-angle glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Harbick KH, Sidoti PA, Budenz DL, Venkatraman A, Bruther M, Grayson DK, Ko A, Yi GN. Outcomes of inferonasal Baerveldt glaucoma drainage implant surgery. J Glaucoma. 2006;15(1):7-12. [pmid: 16378010]. It is a case series
Harju M. Intraocular pressure and progression in exfoliative eyes with ocular hypertension or glaucoma. Acta Ophthalmol Scand. 2000;78(6):699-702. [pmid: 11167237]. Does not address any key questions
Harkonen M. Bradycardia of an elderly patient caused by Timolol therapy in ocular hypertension. Foreign language
Harris A, Arend O, Chung HS, Kagemann L, Cantor L, Martin B. A comparative study of betaxolol and dorzolamide effect on ocular circulation in normal-tension glaucoma patients. Ophthalmology. 2000;107(3):430-4. [pmid: 10711877]. It is not a RCT and has less than 100 patients
Harris A, Arend O, Kagemann L, Garrett M, Chung HS, Martin B. Dorzolamide, visual function and ocular hemodynamics in normal-tension glaucoma. J Ocul Pharmacol Ther. 99 ;15(3):189-97. Data not abstractable
Harris A, Caldemeyer KS, Mansberger SL, Martin BJ. (alpha)-Adrenergic agonists’ effects on ocular hemodynamics. J. GLAUCOMA. 95 ;4(SUPPL 1):S19-23. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Harris A, Jonescu-Cuypers CP, Kagemann L, Nowacki EA, Garzozi H, Cole C, Martin B. Effect of dorzolamide timolol combination versus timolol 0.5% on ocular bloodflow in patients with primary open-angle glaucoma. Am J Ophthalmol. 2001;132(4):490-5. [pmid: 11589868]. It is not a RCT and has less than 100 patients
Harris A, Migliardi R, Rechtman E, Cole CN, Yee AB, Garzozi HJ. Comparative analysis of the effects of dorzolamide and latanoprost on ocular hemodynamics in normal tension glaucoma patients. Eur J Ophthalmol. 2003;13(1):24-31. [pmid: 12635671]. Data not abstractable
Harris A, Siesky B, Shoshani Y, Januleviciene I. Predictors for visual field progression. Acta Ophthalmol. 2010;88(5):504-5. [pmid: 20653571]. No original data (e.g., systematic review, narrative review, editorial, letter)
Harris LS, Galin MA. Dose response analysis of pilocarpine-induced ocular hypotension. Arch Ophthalmol. 70 ;84(5):605-8. It is not a RCT and has less than 100 patients
Harris LS, Galin MA. Effect of ocular pigmentation on hypotensive response to pilocarpine. Am J Ophthalmol. 71 ;72(5):923-5. Does not address any key questions
Harris LS, Kahanowicz Y. Pump infusion of pilocarpine. Ophthalmologica. 75 ;171(2):157-64. It is not a RCT and has less than 100 patients
Harris LS, Greenstein SH, Bloom AF. Respiratory difficulties with betaxolol. Am J Ophthalmol. 86 ;102(2):274-5. [pmid: 686131]. It is not a RCT and has less than 100 patients
Hartenbaum D. The efficacy of dorzolamide, a topical carbonic anhydrase inhibitor, in combination with timolol in the treatment of patients with open-angle glaucoma and ocular hypertension. Clin Ther. 96 ;18(3):460-5. Data not abstractable
Hartenbaum D, Maloney S, Vaccarelli L, Liss C, Wilson H, Gormley GJ. Comparison of dorzolamide and pilocarpine as adjunctive therapy in patients with open-angle glaucoma and ocular hypertension. Excluded drugs
Hasegawa E, Matsuo N, Sarada K, Miyagawa K. Timolol ophthalmic solution for the treatment of glaucoma (author’s transl). Foreign language
Hashimot M, Okinami S, Ohkuma M. Trabeculectomy: A follow up study. Duplicate
Hashimoto M, Okinami S, Ohkuma M. Trabeculectomy: a follow up study (author’s transl). Foreign language
Hashimoto Y, Aragane Y, Kawada A. Allergic contact dermatitis due to levobunolol in an ophthalmic preparation. J Dermatol. 2006;33(7):507-9. [pmid: 16848829]. It is a case series
Haskjold E. Acetazolamide in new formulation forms. A randomized cross-over comparison of Glaupax retard capsules and Diamox Sustex. Foreign language
Haskjold E. New acetazolamide formulation. A randomized cross-over comparison of Glaupax retard capsules and Diamox Sustets. Foreign language
Hass I, Drance SM. Comparison between pilocarpine and timolol on diurnal pressures in open-angle glaucoma. Arch Ophthalmol. 80 ;98(3):480-1. [pmid: 4300000]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Hatanaka M, Reis A, Sano ME, Susanna R. Additive intraocular pressure reduction effect of fixed combination of maleate timolol 0.5%/dorzolamide 2% (Cosopt) on monotherapy with latanoprost (Xalatan) in patients with elevated intraocular pressure: a prospective, 4-week, open-label, randomized, controlled clinical trial. Journal of glaucoma. 2010;19(5):331-5. [pmid: 19730119]. Data not abstractable
Hatanaka M, Grigera DE, Barbosa WL, Jordao M, Susanna R Jr. An eight-week, multicentric, randomized, interventional, open-label, phase 4, parallel comparison of the efficacy and tolerability of the fixed combination of timolol maleate 0.5%/brimonidine tartrate 0.2% versus fixed combination of timolol maleate 0.5%/dorzolamide 2% in patients with elevated intraocular pressure. Medical KQ 3 or KQ 3 and KQ 6 only
Hatanaka M, Reis A, Sano ME, Susanna R Jr. Additive intraocular pressure reduction effect of fixed combination of maleate timolol 0.5%/dorzolamide 2% (Cosopt) on monotherapy with latanoprost (Xalatan) in patients with elevated intraocular pressure: a prospective, 4-week, open-label, randomized, controlled clinical trial. Medical KQ 3 only
Hattat N, Caldag M, Surel Z. A double-blind comparison study of local timolol and pindolol in the treatment of primary open angle glaucoma. Foreign language
Haverkamp F, Wuensch S, Fuchs M, Stewart WC. Intraocular pressure, safety and quality of life in glaucoma patients switching to latanoprost from adjunctive and monotherapy treatments. Eur J Ophthalmol. 2004;14(5):407-15. [pmid: 15506603]. OAG can’t be analyzed separately
HAYES and Inc. Selective laser trabeculoplasty (SLT) using the Selecta 7000 (Lumenis Inc.) for treatment of primary open-angle glaucoma and ocular hypertension (Structured abstract). Meeting abstract
Hayes LP, Stewart CJ, Kim I, Mohr JA. Timolol side effects and inadvertent overdosing. J Am Geriatr Soc. 89 ;37(3):261-2. It is a case series
Hayreh SS, Podhajsky P, Zimmerman MB. Beta-blocker eyedrops and nocturnal arterial hypotension. Am J Ophthalmol. 99 ; 128(3):301-9. It is a case series
Hazelton JR, Whitson JT, Henry C, Terry S, Hughes B, Lee DA. Comparison of the Intraocular Pressure Effect and Safety of Dorzolamide 2% Versus Brimonidine 0.2%, Each Given Three Times Daily for Six Weeks in Patients With Primary Open-Angle Glaucoma or Ocular Hypertension. Meeting abstract
Hedman K, Alm A. A pooled-data analysis of three randomized, double-masked, six-month clinical studies comparing the intraocular pressure reducing effect of latanoprost and timolol. Eur J Ophthalmol. 2000;10(2):95-104. [pmid: 10887918]. No original data (e.g., systematic review, narrative review, editorial, letter)
Hedman K, Larsson LI. The effect of latanoprost compared with timolol in African-American, Asian, Caucasian, and Mexican open-angle glaucoma or ocular hypertensive patients. Surv Ophthalmol. 2002;47(Suppl 1):S77-89. [pmid: 12204703]. No original data (e.g., systematic review, narrative review, editorial, letter)
Hedman K, Alm A, Gross RL. Pooled-data analysis of three randomized, double-masked, six-month studies comparing intraocular pressure-reducing effects of latanoprost and timolol in patients with ocular hypertension. Medical KQ 3 only
Hedman K, Asenblad NG, Alm A, Watson PG, Mandahl A. Intraocular Pressure of Latanoprost and Timolol in the Phase III Clinical Trials in Scandinavia, UK, and USA. Meeting abstract
Hedman K, Watson PG, Alm A. The effect of latanoprost on intraocular pressure during 2 years of treatment. Surv Ophthalmol. 2002;47(4 SUPPL 1):S65-76. [pmid: 12204702]. Other (specify):No control group
Heier JS, Steinert RF, Frederick AR Jr. Cystoid macular edema associated with latanoprost use. Arch Ophthalmol. 98 ;116(5):680-2. [pmid: 7369902]. It is a case series
Heijl A. One- and two-session laser trabeculoplasty. A randomized, prospective study. Acta ophthalmologica. 84 ;62(5):715-24. It is not a RCT and has less than 100 patients
Heijl A, Leske MC, Bengtsson B, Hyman L, Bengtsson B, Hussein M. Reduction of intraocular pressure and glaucoma progression: results from the Early Manifest Glaucoma Trial. EMGT-Maier
Heijl A, Peters D, Leske MC, Bengtsson B. Effects of Argon Laser Trabeculoplasty in the Early Manifest Glaucoma Trial. Am J Ophthalmol. 2011. Other (specify):not RCT and doesn’t do harms
Heijl A, Strahlman E, Sverrisson T, Brinchman-Hansen O, Puustjarvi T, Tipping R. A comparison of dorzolamide and timolol in patients with pseudoexfoliation and glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Heilmann K. A report on Ocusert (author’s transl). Klin Monbl Augenheilkd. 75 ;167(4):534-42. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Heilmann K. A report on ocusert (author’s transl). Klin Monbl Augenheilkd. 77 ;170(1):109-19. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Heilmann K. A report on Ocusert: OCUSERT, EIN NEUARTIGES MEDIKAMENTENTRAGERSYSTEM FUR DIE GLAUKOMBEHANDLUNG. 3. MITTEILUNG. Duplicate
Heilmann K, Sinz U. A report on Ocusert (author’s transl). Klin Monbl Augenheilkd. 74 ;165(3):519-24. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Heilmann K, Sinz U. A report on Ocusert. I: OCUSERT, EIN NEUARTIGES MEDIKAMENTENTRAGERSYSTEM FUR DIE GLAUKOMBEHANDLUNG. I. MITTEILUNG. Foreign language
Heimann K, Kyrieleis E. Retinal detachment from miotic therapy. Foreign language
Heinrich P. Miotics and retinal detachment (author’s transl). Foreign language
Heinz C, Koch JM, Zurek-Imhoff B, Heiligenhaus A. Prevalence of uveitic secondary glaucoma and success of nonsurgical treatment in adults and children in a tertiary referral center. Ocul Immunol Inflamm. 2009;17(4):243-8. [pmid: 19657977]. No subjects with open-angle glaucoma, It is a case series
Helal MH, El Sayyad FF, El-Hamzawey H. Manual Small-Incision Mini Nuc Technique for Extracapsular Cataract Extraction (MNT ECCE) and Trabeculectomy Versus Phacotrabeculectomy. Meeting abstract
Helton J, Storrs FJ. Pilocarpine allergic contact and photocontact dermatitis. Contact Dermatitis. 91 ;25(2):133-4. It is a case series
Henderer JD, Heeg MC, Myers JS, Moster MR, Schmidt CR, Katz LJ, Spaeth GL. LONG-TERM EFFECTS OF DIGITAL OCULAR COMPRESSION IN THE LATE POST-OPERATIVE PERIOD. Meeting abstract
Henderer J, Heeg M, Moster M, Myers J, Schmidt C Jr, Katz LJ, Spaeth G, Steinmann W. A RANDOMIZED TRIAL OF THE LONG-TERM EFFECTS OF DIGITAL OCULAR COMPRESSION [N THE LATE POST-OPERATIVE PERIOD. Meeting abstract
Henderson HW, Ezra E, Murdoch IE. Early postoperative trabeculectomy leakage: incidence, time course, severity, and impact on surgical outcome. Br J Ophthalmol. 2004;88(5):626-9. [pmid: 15090412]. Does not address any key questions
Hennig J. A comparative trial between pilocarpine drops and ocusert-pilocarpine. Klin Monbl Augenheilkd. 76 ;169(1):112-5. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Hennis HL, Stewart WC. The use of 5-fluorouracil in patients following combined trabeculectomy and cataract extraction. Ophthalmic Surg. 91 ; 22(8):451-4. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Henry JC, Kessler TL, Mallick S, Wells DT, Hua S, Landry TA, Bergamini MVW, Krueger DS. Travoprost/Timolol Study Group. Comparison of the Safety and IOP-Lowering Efficacy of Travoprost 0.004%/Timolol 0.5% Fixed Combination to the Concomitant Administration of Xalatan® and Timolol 0.5%. Meeting abstract
Hepsen IF, Ozkaya E. 24-h IOP control with latanoprost, travoprost, and bimatoprost in subjects with exfoliation syndrome and ocular hypertension. Eye (Lond). 2007;21(4):453-8. [pmid: 16543930]. Data not abstractable
Herbort CP, Mermoud A, Schnyder C, Pittet N. Anti-inflammatory effect of topical diclofenac after argon laser trabeculoplasty: Preliminary results of a placebo controlled study. Duplicate
Herde J. On the relevance of the long-time follow-up of the cyclocryotherapy. Ophthalmologe. 99 ;96(9):600-4. It is a case series
Herde J. Relevance of long-term follow-up of cyclocryocoagulation. Ophthalmologe. 99 ;96(11):772-6. It is a case series
Hermann MM, Bron AM, Creuzot-Garcher CP, Diestelhorst M. Measurement of Adherence to Brimonidine Therapy for Glaucoma Using Electronic Monitoring. Unique comparators
Herndon LW, Asrani SG, Williams GH, Challa P, Lee PP. Paradoxical intraocular pressure elevation after combined therapy with latanoprost and bimatoprost. Arch Ophthalmol. 2002;120(6):847-9. [pmid: 12049597]. It is a case series
Herndon LW, Gedde SJ, Brandt JD, Budenz DL, Schiffman JC, Feuer WJ. the Tube Versus Trabeculectomy Study Group. Surgical Complications in the Tube Versus Trabeculectomy (TVT) Study during the First Year of Follow-Up. Meeting abstract
Herrera Hernbndez Norma. Terapqutica en el glaucoma cr£nico de bngulo abierto. Foreign language
Herretes Samantha, Stangogiannis Crisante, Behrens Ashley. +Queratitis difusa lamellar?: desafortunadamente un diagn£stico errado. Foreign language
Hesse RJ, Swan JL 2nd. Aphakic cystoid macular edema secondary to betaxolol therapy. Ophthalmic Surg. 88 ;19(8):562-4. It is a case series
Hesse RJ. Risk of sudden visual loss after filtration surgery in end-stage glaucoma. Am J Ophthalmol. 2006;141(5):983. author reply 983–4. [pmid: 16678536]. No original data (e.g., systematic review, narrative review, editorial, letter)
Heuring AH, Hutz WW, Eckhardt HB. Combined phacoemulsification and goniotrephination in primary open-angle glaucoma and pseudoexfoliation glaucoma - a retrospective analysis. Foreign language
Heuring AH, Hutz WW, Eckhardt HB. Combined phacoemulsification and goniotrephination in primary open-angle glaucoma and pseudoexfoliation glaucoma - A retrospective analysis. Kombinierte Katarakt-Glaukom-Operation bei primarem chronischen offenwinkelglaukom und Pseudoexfoliationsglaukom - Eine retrospektive analyse. Foreign language
Heuring AH, Hutz WW, Hoffmann PC, Eckhardt HB. Combined phacoemulsification and goniotrepanation in primary chronic open angle glaucoma and classical pseudoexfoliation glaucoma. Ophthalmologe. 99 ;96(5):312-8. It is a case series
Hickey-Dwyer M, Campbell SH, Harding S. Doubled-masked three-period crossover investigation of metipranolol in control of raised intraocular pressure. Medical KQ 3 or KQ 3 and KQ 6 only
Higginbotham EJ. AGN 192024 Study Group. 1. 1 -year comparison of the new prostamide AGN 192024 with timolol for the management of glaucoma and ocular hypertension. Meeting abstract
Higginbotham EJ, Goldberg I, Schuman JS, Gross RL, Vandenburgh AM, Whitcup SM. One-year comparison of bimatoprost with timolol in patients with glaucoma or ocular hypertension. Meeting abstract
Higginbotham EJ, Feldman R, Stiles M, Dubiner H. Latanoprost and timolol combination therapy vs monotherapy: one-year randomized trial. Medical KQ 3 or KQ 3 and KQ 6 only
Higginbotham EJ, Gordon MO, Beiser JA, Drake MV, Bennett GR, Wilson MR, Kass MA. The Ocular Hypertension Treatment Study: topical medication delays or prevents primary open-angle glaucoma in African American individuals. Medical KQ 3 only
Higginbotham EJ, Kass MA, Lippa EA, Batenhorst RL, Panebianco DL, Wilensky JT. MK-927: a topical carbonic anhydrase inhibitor. Dose response and duration of action. Arch Ophthalmol. 90 ;108(1):65-8. Does not address any key questions
Higginbotham EJ, Olander KW, Kim EE, Grunden JW, Kwok KK, Tressler CS. Fixed combination of latanoprost and timolol vs individual components for primary open-angle glaucoma or ocular hypertension: a randomized, double-masked study. Arch Ophthalmol. 2010;128(2):165-72. [pmid: 20142538]. Other (specify):not FDA approved
Higginbotham EJ, Olander KW, Kim EE, Grunden JW, Kwok KK, Tressler CS. Fixed combination of latanoprost and timolol vs individual components for primary open-angle glaucoma or ocular hypertension: a randomized, double-masked study. Systematic review
Higginbotham EJ, Schuman JS, Goldberg I, Gross RL, van Denburgh AM, Chen K, et al. One year, randomizing study comparing bimatoprost and timolol in glaucoma and ocular hypertenstion. Archives of Ophthalmology. 2002;120:1286-93. [pmid: 12365906]. OAG can’t be analyzed separately
Higginbotham EJ, Schuman JS, Goldberg I, Gross RL, VanDenburgh AM, Chen K, Whitcup SM. One-year, randomized study comparing bimatoprost and timolol in glaucoma and ocular hypertension. Arch Ophthalmol. 2002;120(10):1286-93. [pmid: 12365906]. OAG can’t be analyzed separately
Higginbotham EJ, Stevens RK, Musch DC, Karp KO, Lichter PR, Bergstrom TJ, Skuta GL. Bleb-related endophthalmitis after trabeculectomy with mitomycin C. Ophthalmology. 96 ;103(4):650-6. OAG can’t be analyzed separately
Higgins RA. Two years’ experience with laser trabeculoplasty. Aust N Z J Ophthalmol. 85 ;13(3):237-41. OAG can’t be analyzed separately
Hillery M, Blake J. Pilocarpine sine miosis in primary open angle glaucoma. [abstract]. Abstract only
Hillman D, Mundorf T, Dirks M, Noecker RJ, Earl M. Comparison of Brimonidine Purite 0.15% vs. Timolol in Patients with Glaucoma or Ocular Hypertension. Meeting abstract
Hillman JS. Management of acute glaucoma with pilocarpine-soaked hydrophilic lens. Br J Ophthalmol. 74 ;58(7):674-9. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Hinkle DM, Zurakowski D, Ayyala RS. A comparison of the polypropylene plate Ahmed glaucoma valve to the silicone plate Ahmed glaucoma flexible valve. Eur J Ophthalmol. 2007;17(5):696-701. [pmid: 17932842]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Hirsch R, Remky H. Trabeculectomy. Long-term results of 247 cases (2-101/2-years-old). Bull Soc Belge Ophtalmol. 84 ;209:19-36. It is a case series
Hitchings RA, Smith RJ. Experience with pilocarpine Ocuserts. Trans Ophthalmol Soc U K. 77 ;97(1):202-5. It is not a RCT and has less than 100 patients
Hitchings RA. Beta-blockers in the treatment of chronic simple glaucoma. Br Med J (Clin Res Ed). 82 ;285(6335):84-5. No original data (e.g., systematic review, narrative review, editorial, letter)
Ho JD, Hu CC, Lin HC. Antiglaucoma medications during pregnancy and the risk of low birth weight: a population-based study. Br J Ophthalmol. 2009;93(10):1283-6. [pmid: 19520696]. Does not address any key questions
Hodapp E, Kolker AE, Kass MA, Goldberg I, Becker B, Gordon M. The effect of topical clonidine on intraocular pressure. Arch Ophthalmol. 81 ;99(7):1208-11. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Hodes B. Ocular hypertensive response to therapy. Arch Ophthalmol. 79 ;97(8):1544-5. It is a case series
Hodge W, Damji KF, Bovell A, Buhrmann RR. Highly Successful SLT is Independent of Glaucoma Type, Previous Surgery, Medical Therapy, or Glaucoma Risk Factors. Meeting abstract
Hoffmann E, Schwenn O, Karallus M, Krummenauer F, Grehn F, Pfeiffer N. Long-term results of cataract surgery combined with trabeculotomy. Graefes Arch Clin Exp Ophthalmol. 2002;240(1):2-6. [pmid: 11954776]. Does not address any key questions
Hollo G, Kothy P. Intraocular pressure reduction with travoprost/timolol fixed combination, with and without adjunctive brinzolamide, in glaucoma. Curr Med Res Opin. 2008;24(6):1755-61. [pmid: 18479590]. Does not address any key questions
Hollo G. Argon and low energy, pulsed Nd:YAG laser trabeculoplasty. A prospective, comparative clinical and morphological study. Acta Ophthalmol Scand. 96 ;74(2):126-31. It is not a RCT and has less than 100 patients
Hollo G, Chiselita D, Petkova N, Cvenkel B, Liehneova I, Izgi B, Berta A, Szaflik J, Turacli E, Stewart WC. The efficacy and safety of timolol maleate versus brinzolamide each given twice daily added to travoprost in patients with ocular hypertension or primary open-angle glaucoma. Medical KQ 3 only
Hollo G, Konstas AGP, Tsironi S, Irkec M, Durukan I, Goldenfield M, Melamed S. Diurnal IOP Control With Bimatoprost vs Latanoprost in Exfoliative Glaucoma: A Crossover Observer-Masked Three-Center Study. Meeting abstract
Hollo G, Thelen U, Teus MA, Quaranta L, Ferkova S, Babic N, Misiuk-Hojlo M, Mikropoulos DG, Kaluzny BJ, Kozobolis V, Januleviciene I, Kothy P, Camara C, Russo A, Krzyzanowska-Berkowska P, Cieslinska I, Stewart JA, Kristoffersen MS, Nelson LA, Stewart WC. Long-Term Outcomes of Prostaglandin Analog Versus Timolol Maleate in Ocular Hypertensive or Primary Open-Angle Glaucoma Patients in Europe. J Ocul Pharmacol Ther. 2011. Does not address any key questions
Hollo G, Vargha P, Kothy P. Influence of switching to travoprost on intraocular pressure of uncontrolled chronic open-angle glaucoma patients compliant to previously-used topical medication. Curr Med Res Opin. 2005;21(12):1943-8. [pmid: 16368044]. Other (specify):Study design does not match KQ
Holmes KT, Sharpe ED, Day DC, Dubiner H, Stewart WC. EFFICACY AND SAFETY OF TIMOLOL HEMIHYDRATE 05% SOLUTION ONCE DAILY VERSUS TIMOLOL MALEATE GEL 0.5% ONCE DAILY ADDED TO LATANOPROST 0.005%. Meeting abstract
Holmes WR. Ocusert in Christchurch. Trans Ophthalmol Soc N Z. 77 ; 29:111-2. It is a case series
Holmin C. Signs of activity and progression in chronic glaucoma. Acta Ophthalmol Suppl. 82 ;153:1-40. No original data (e.g., systematic review, narrative review, editorial, letter)
Holmwood P, Chase D, Ruderman I, Rosenberg L, Krupin T. EFFECT OF APRACLONIDINE DOSAGE ON ARGON LASER TRABECULOPLASTY (ALT) INDUCED INCREASE IN INTRAOCULAR PRESSURE (IOP). Meeting abstract
Hommer A. A double-masked, randomized, parallel comparison of a fixed combination of bimatoprost 0.03%/timolol 0.5% with non-fixed combination use in patients with glaucoma or ocular hypertension. Eur J Ophthalmol. 2007;17(1):53-62. [pmid: 17294383]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Hommer AB, Mertz B, Schwenninger C, Yannoulis N, Kapik B. The Unoprostone Study Group. Efficacy and safety of unoprostone, dorzolamide, and brimonidine in adjunctive therapy to timolol in patients with primary open-angle glaucoma and ocular hypertension. Meeting abstract
Hommer A, Kapik B, Shams N. Unoprostone as adjunctive therapy to timolol: a double masked randomised study versus brimonidine and dorzolamide. Excluded drug
Hommer A, Nowak A, Huber SV. A multidose, double-masked, parallel active treatment controlled multicenter study of 025% timolol in Gelrite once daily versus 0.25% timolol solution twice. Duplicate
Hommer A, Nowak A, Huber-Spitzy V. Multicenter double-blind study with 025% timolol in Gelrite (TG) once daily vs. 0.25% timolol solution (TS) twice daily. German Study Group. Ophthalmologe. 95 ; 92(4):546-9. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Hommer A, Nowak A, Huber-Spitzy V. A multidose, double-masked, parallel active treatment controlled multicenter study of 025% timolol in Gelrite once daily versus 0.25% timolol solution twice. MULTIZENTRISCHE DOPPELBLINDSTUDIE MIT 0,25% TIMOLOL IN GELRITE (TG) 1MAL TAGLICH VS. 0,25% TIMOLOL-LOSUNG (TS) 2MAL TAGLICH. Duplicate
Hommer A, Thygesen J, Ferreras A, Wickstrom J, Friis MM, Buchholz P, Walt JG. A European perspective on costs and cost effectiveness of ophthalmic combinations in the treatment of open-angle glaucoma (Structured abstract). Duplicate
Hommer A, Wickstrom J, Friis MM, Steeds C, Thygesen J, Ferreras A, Gouws P, Buchholz P. A cost-effectiveness analysis of fixed-combination therapies in patients with open-angle glaucoma: a European perspective (Structured abstract). Current Medical Research and Opinion. 2008;24(4):1057-1063. [pmid: 18315942]. No original data (e.g., systematic review, narrative review, editorial, letter)
Hong S, Park K, Ha SJ, Yeom HY, Seong GJ, Hong YJ. Long-term intraocular pressure control of trabeculectomy and triple procedure in primary open angle glaucoma and chronic primary angle closure glaucoma. Ophthalmologica. 2007;221(6):395-401. [pmid: 17947826]. It is a case series
Hong S, Seong GJ, Hong YJ. Long-term intraocular pressure fluctuation and progressive visual field deterioration in patients with glaucoma and low intraocular pressures after a triple procedure. Arch Ophthalmol. 2007;125(8):1010-3. [pmid: 17698746]. Other (specify):Study design does not match KQ
Honjo M, Tanihara H, Negi A, Hangai M, Taniguchi T, Honda Y, Mizoguchi T, Matsumura M, Nagata M. Trabeculotomy ab externo, cataract extraction, and intraocular lens implantation: preliminary report. J Cataract Refract Surg. 96 ;22(5):601-6. It is combined cataract/glaucoma surgery study published before April 2000
Honrubia FM, Ferrer EJ, Lecinena J, Torron C, Gomez ML. Long term follow-up of the argon laser trabeculoplasty in eyes treated 180 degrees and 360 degrees of the trabeculum. Int Ophthalmol. 92; 16(4–5):375-9. Other (specify):Study design does not match KQ
Honrubia FM, Larsson LI, Spiegel D. A comparison of the effects on intraocular pressure of latanoprost 0.005% and the fixed combination of dorzolamide 2% and timolol 0.5% in patients with open-angle glaucoma. Medical KQ 3 only
Honrubia F, Garcia-Sanchez J, Polo V, de la Casa JM, Soto J. Conjunctival hyperaemia with the use of latanoprost versus other prostaglandin analogues in patients with ocular hypertension or glaucoma: a meta-analysis of randomised clinical trials. Systematic review
Hooi ST, Hooi SH. Trabeculectomy outcomes in a Malaysian general hospital. Med J Malaysia. 2003;58(4):565-78. [pmid: 15190633]. OAG can’t be analyzed separately
Hopkins JJ, Apel A, Trope GE, Rootman DS. Early intraocular pressure after phacoemulsification combined with trabeculectomy. Ophthalmic Surg Lasers. 98 ; 29(4):273-9. It is combined cataract/glaucoma surgery study published before April 2000
Horven I. Timolol Eyedrops. Foreign language
Hoste AM. Reduction of IOP with latanoprost. Ophthalmology. 97 ; 104(6):895-7. No original data (e.g., systematic review, narrative review, editorial, letter)
Hostyn P, Le Rebeller MJ, Trinquand C. Fixed combination of carteolol and pilocarpine eye-drops: A double-blind randomized cross-over trial versus carteolol alone on intra-ocular pressure. Duplicate
Hostyn P, Le Rebeller MJ, Trinquand C. Fixed combination of carteolol and pilocarpine eye-drops: a double-blind randomized cross-over trial versus carteolol alone on intra-ocular pressure. The Study Group. Eur J Ophthalmol. 96 ;6(1):17-20. Other (specify):Study design does not match KQ
Hotchkiss ML, Robin AL, Pollack IP, Quigley HA. Nonsteroidal anti-inflammatory agents after argon laser trabeculoplasty. A trial with flurbiprofen and indomethacin. Ophthalmology. 84 ;91(8):969-76. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Hovding G, Aasved H. Timolol/pilocarpine combination eye drops in open angle glaucoma and in ocular hypertension. A controlled randomized study. Acta Ophthalmol (Copenh). 87 ;65(5):594-601. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Hovding G. Fixed-ratio timolol and pilocarpine combination in the management of open-angle glaucoma: Scandinavian multicenter study. CHIBRET INT. J OPHTHALMOL. 90 ;7(1):63-67. Other (specify):not FDA approved
Hu C. Long-term effect of domestic timolol on patients with primary open-angle glaucoma. Foreign language
Hu CY, Matsuo H, Tomita G, Suzuki Y, Araie M, Shirato S, Tanaka S. Clinical characteristics and leakage of functioning blebs after trabeculectomy with mitomycin-C in primary glaucoma patients. Ophthalmology. 2003;110(2):345-52. [pmid: 12578779]. Does not address any key questions
Huang MC, Netland PA, Coleman AL, Siegner SW, Moster MR, Hill RA. Intermediate-term clinical experience with the Ahmed Glaucoma Valve implant. Am J Ophthalmol. 99 ;127(1):27-33. [pmid: 3966516]. OAG can’t be analyzed separately
Huang P, Zhong Z, Wu L, Liu W. Increased iridial pigmentation in Chinese eyes after use of travoprost 0.004%. J Glaucoma. 2009;18(2):153-6. [pmid: 19225354]. It is not a RCT and has less than 100 patients
Huang Y, Wang N-L, Wang B-W, Li L-J. The long term curative effect of the nonpenetrating trabecular surgery. Foreign language
Huber K, Wolter P, Plange N, Remky A, Arend O. A randomised trial to evaluate hemodynamic effects of timolol, latanoprost and dorzolamide in patients with newly diagnosed open angle glaucoma. Meeting abstract
Jeanette Huertas A, Patricio Anuch J, Adrianzen Barreto Rosa. Estudio comparativo entre trabeculectomÆa y sinusotrabeculectomÆa en el glaucoma primario de angulo abierto. Foreign language
Hughes BA, Bacharach J, Craven ER, Kaback MB, Mallick S, Landry TA, Bergamini MV. A three-month, multicenter, double-masked study of the safety and efficacy of travoprost 0.004%/timolol 0.5% ophthalmic solution compared to travoprost 0.004% ophthalmic solution and timolol 0.5% dosed concomitantly in subjects with open angle glaucoma or ocular hypertension. Non-FDA-approved drug combination
Hughes BA, Juzych MS, Pettigrew SC, Sullivan EK, Landry TA, Robertson SM. A Comparison of Travoprost 0.004%/Timolol 0.5% Ophthalmic Solution and the Concomitant Administration of TRAVATAN® and Timolol 0.5%. Meeting abstract
Hugkulstone CE. Argon laser trabeculoplasty with standard and long duration. Acta Ophthalmol (Copenh). 90 ;68(5):579-81. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Hugkulstone CE. Primary glaucoma triple procedure. Ophthalmology. 97 ;104(8):1208-9. Data not abstractable
Hugkulstone CE. Standard and long duration repeat argon laser trabeculoplasty. Acta Ophthalmol (Copenh). 90 ; 68(5):575-8. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Hugkulstone CE. The effects of different energy levels in argon laser trabeculoplasty. Acta Ophthalmol (Copenh). 89 ;67(3):271-4. Data not abstractable
Hugkulstone CE. Two-year follow-up of intra-ocular pressure control with long duration argon laser trabeculoplasty. Rolim de Moura 2009
Hugkulstone CE, Smith LF, Vernon SA. Trabeculectomy in diabetic patients with glaucoma. Eye (Lond). 93 ;7(Pt 4):502-6. It is not a RCT and has less than 100 patients
Hugues FC, Le Jeunne C, Munera Y, Dufier JL. Evaluation of the systemic effects of timolol maleate in eye drops. J Fr Ophtalmol. 85 ;8(5):389-94. It is not a RCT and has less than 100 patients
Hung PT, Hsieh JW, Chiou GC. Ocular hypotensive effects of N-demethylated carbachol on open angle glaucoma. Arch Ophthalmol. 82 ;100(2):262-4. Does not address any key questions
Hung SO. Role of sodium hyaluronate (Healonid) in triangular flap trabeculectomy. Br J Ophthalmol. 85 ;69(1):46-50. Other (specify):Not an intervention of interest
Huo Q, Shen Q, Zhang DM, Zhang RT. Effect of pricking blood at Neiyingxiang (EX-HN 9) on the intraocular pressure of patients with primary open angle glaucoma. Foreign language
Hurvitz LM. 5-FU-supplemented phacoemulsification, posterior chamber intraocular lens implantation, and trabeculectomy. Ophthalmic Surg. 93 ;24(10):674-80. It is combined cataract/glaucoma surgery study published before April 2000
Husain R, Aung T, Gazzard G, Foster PJ, Devereux JG, Chew PT, Oen FT, Khaw PT, Seah SK. Effect of trabeculectomy on lens opacities in an East Asian population. Arch Ophthalmol. 2006;124(6):787-92. [pmid: 16769831]. It is a case series
Hustead JD. Central corneal thickness. Arch Ophthalmol. 98 ;116(9):1263. No original data (e.g., systematic review, narrative review, editorial, letter)
Hutzelmann JE, Polis AB, Michael AJ, Adamsons IA. A comparison of the efficacy and tolerability of dorzolamide and acetazolamide as adjunctive therapy to timolol. Duplicate
Hutzelmann JE, Polis AB, Michael AJ, Adamsons IA. A comparison of the efficacy and tolerability of dorzolamide and acetazolamide as adjunctive therapy to timolol. Oral to Topical CAI Study Group. Acta Ophthalmol Scand. 98 ;76(6):717-22. Data not abstractable
Hutzelmann J, Owens S, Shedden A, Adamsons I, Vargas E. Comparison of the safety and efficacy of the fixed combination of dorzolamide/timolol and the concomitant administration of dorzolamide and timolol: A clinical equivalence study. Duplicate
Hutzelmann J, Owens S, Shedden A, Adamsons I, Vargas E. Comparison of the safety and efficacy of the fixed combination of dorzolamide/timolol and the concomitant administration of dorzolamide and timolol: a clinical equivalence study. International Clinical Equivalence Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
Hutzelmann J, Owens S, Shedden A, Adamsons I. A STUDY COMPARING THE SAFETY AND EFFICACY OF THE FIXED COMBINATION OF DORZOLAMIDEiTIMOLOL TO THE CONCOMITANT ADMINISTRATION OF TIMOLOL AND DORZOLAMIDE. Meeting abstract
Hutzelmann J, Snyder E, Tipping R, Adamsons I. COMPARISON OF THE IOP LOWERING EFFECT OF 2.0% DORZOLAMIDE T.I.D. (TRUSOPT*) IN PATIENTS WITH LIGHT AND DARK IRIDES. Meeting abstract
Huygens M, Vercruysse K, Goethals M, Missotten L. Trabeculectomy: a retrospective long-term follow-up study. Bull Soc Belge Ophtalmol. 90 ;238:125-35. Data not abstractable
Hypotensive efficacy in primary open-angle glaucoma and ocular hypertension: latanoprost in monotherapy vs timolol and dorzolamide in association. Acta Ophthalmol Scand Suppl. 2000;(232):49-50. [pmid: 11235535]. No original data (e.g., systematic review, narrative review, editorial, letter) Data not abstractable, No original data (e.g., systematic review, narrative review, editorial, letter)
Iakovlev AA, Lenkevich MM. Use of pilocarpine in a polyvinyl alcohol film for the treatment of glaucoma patients. Foreign language
Iester M, Perdicchi A, Venturino G, Rolando M, Traverso CE, Leonardi E, Calabria G. Short-term effects of bimatoprost in glaucoma patients from an outpatient clinic. J Ocul Pharmacol Ther. 2004;20(5):393-400. [pmid: 15650514]. It is not a RCT and has less than 100 patients
Ignat F, Damian C, Manescu R, Perovic I. Neuroprotective effect of Betoptic S-considerations after 18 months of treatment. Foreign language
Ikeda Y, Mori K, Ishibashi T, Naruse S, Kobayashi L, Hozono Y, Ikushima T, Imai K, Nakajima N, Kinoshita S. Non-Response to â-Blocker Topical Application in Normal-Tension-Glaucoma. Meeting abstract
Ikeda Y, Mori K, Ishibashi T, Naruse S, Nakajima N, Kinoshita S. Effects of switching from topical beta-blockers to latanoprost on intraocular pressure in patients with normal-tension glaucoma. J Ocul Pharmacol Ther. 2008;24(2):230-4. [pmid: 18341431]. Does not address any key questions
Imamoto N, Kim J, Chang F, Kim C. COMPARISON BETWEEN TIMOPTIC-XE QD AND TIMOLOL SOLUTION BID ON IOP AT THE 23RD HOUR. Meeting abstract
Inaba Z. Long-term results of trabeculectomy in the Japanese: an analysis by life-table method. Foreign language
Inaba Z. Long-term results of trabeculectomy in the Japanese: an analysis by life-table method. Jpn J Ophthalmol. 82 ; 26(4):361-73. Does not address any key questions
Inal A, Bayraktar S, Inal B, Bayraktar Z, Yilmaz OF. Intraocular pressure control after clear corneal phacoemulsification in eyes with previous trabeculectomy: a controlled study. Acta Ophthalmol Scand. 2005;83(5):554-60. [pmid: 16187992]. It is not a RCT and has less than 100 patients
Inatani M, Iwao K, Inoue T, Awai M, Muto T, Koga T, Ogata-Iwao M, Hara R, Futa R, Tanihara H. Long-term relationship between intraocular pressure and visual field loss in primary open-angle glaucoma. J Glaucoma. 2008;17(4):275-9. [pmid: 18552612]. Data not abstractable
Inatani M, Tanihara H, Muto T, Honjo M, Okazaki K, Kido N, Honda Y. Transient intraocular pressure elevation after trabeculotomy and its occurrence with phacoemulsification and intraocular lens implantation. Jpn J Ophthalmol. 2001;45(3):288-92. [pmid: 11369380]. Does not address any key questions
Incidence of a latanoprost-induced increase in iris pigmentation in Japanese eyes. Jpn J Ophthalmol. 2006;50(2):96-9. [pmid: 16604382]. It is a case series gives an estimate of likelihood of pigmentation It is a case series
Indar AR, Poinoosawmy D, Hitchings RA. Effect of medical treatment or surgery on intraocular pressure and ocular blood flow in normal tension glaucoma. Meeting abstract
Ingram CJ, Brubaker RF. Effect of brinzolamide and dorzolamide on aqueous humor flow in human eyes. Am J Ophthalmol. 99 ;128(3):292-6. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Inoue K, Ezure T, Wakakura M, Inoue J, Tomita G. The effect of once-daily levobunolol on intraocular pressure in normal-tension glaucoma. Jpn J Ophthalmol. 2005;49(1):58-9. [pmid: 15692777]. It is not a RCT and has less than 100 patients
Inoue K, Okugawa K, Kato S, Inoue Y, Tomita G, Oshika T, Amano S. Ocular factors relevant to anti-glaucomatous eyedrop-related keratoepitheliopathy. J Glaucoma. 2003;12(6):480-5. [pmid: 14646683]. Other (specify):Unoprostone, nipradilol, dipifrevin and outcomes not given separately
Inoue K, Wada SA, Wakakura M, Inoue J, Tomita G. Switching from dorzolamide to brinzolamide: effect on intraocular pressure and patient comfort. Jpn J Ophthalmol. 2006;50(1):68-9. [pmid: 16453193]. It is not a RCT and has less than 100 patients
Inoue K, Wakakura M, Inoue J, Matsuo H, Hara T, Tomita G. Adverse reaction after use of latanoprost in Japanese glaucoma patients. Foreign language
Inoue K, Wakakura M, Inouye J, Tomita G. Effect of levobunolol switched from timolol gel-forming solution. Foreign language
Irak I, Moster MR, Fontanarosa J. Intermediate-term results of Baerveldt tube shunt surgery with mitomycin C use. Ophthalmic Surg Lasers Imaging. 2004;35(3):189-96. [pmid: 15185786]. OAG can’t be analyzed separately
Isasi-Saseta MB, Urcelay-Segura JL, Zamora-Barrios J, Ortega-Usobiaga J, Moreno Garcia-Rubio B, Cortes-Valdes C. Trabeculectomy and phacoemulsification. One site vs. two site approach. A comparative study. Foreign language
Ishida K, Netland PA. Ahmed Glaucoma Valve implantation in African American and white patients. Arch Ophthalmol. 2006;124(6):800-6. [pmid: 16769833]. OAG can’t be analyzed separately
Ishida K, Netland PA, Costa VP, Shiroma L, Khan B, Ahmed II. Comparison of polypropylene and silicone Ahmed Glaucoma Valves. Ophthalmology. 2006;113(8):1320-6. [pmid: 16877071]. OAG can’t be analyzed separately
Ishikawa M, Yoshitomi T. Effects of brinzolamide vs timolol as an adjunctive medication to latanoprost on circadian intraocular pressure control in primary open-angle glaucoma Japanese patients. Clin Ophthalmol. 2009;3(1):493-500. [pmid: 19750124]. Does not address any key questions
Ishikawa S, Nakamura Y, Nakamura Y, Sakai H, Sawaguchi S, Terashima K, Kanno M, Yamashita H. Efficacy and safety of combination therapy with latanoprost after a change in therapeutic regimen from timolol to brinzolamide in Japanese adult patients with primary open-angle glaucoma and ocular hypertension: open, non-randomized 12-week study. Clin Ophthalmol. 2008;2(4):703-8. [pmid: 19668419]. It is not a RCT and has less than 100 patients
Ishikawa T, Okisaka S, Hiwatari S, Taketani P, Sugimachi Y. Pilocarpine, carbachol and carteolol on open-angle glaucoma and ocular hypertension (author’s transl). Foreign language
Iwakiri R, Kobayashi H, Kobayashi K, Okinami S. Addition of topical bunazosin to latanoprost in multiple medical treatment for glaucoma. Foreign language
Iwao K, Inatani M, Tanihara H. Success rates of trabeculotomy for steroid-induced glaucoma: a comparative, multicenter, retrospective cohort study. Am J Ophthalmol. (6; status =Department of Ophthalmology and Visual Science, Kumamoto University Graduate School of Medical Sciences, 1-1-1 Honjo, Kumamoto, Japan.). 2011;151:1047-1056. e1. [pmid: 21396622]. No subjects with open-angle glaucoma
Jacobi PC, Dietlein TS, Krieglstein GK. Cataract surgery in pseudoexfoliation glaucoma: A combination with trabeculectomy, aspiration of the trabeculum or bilateral procedure. Meeting abstract
Jacobi PC, Dietlein TS, Krieglstein GK. Comparative study of trabecular aspiration vs trabeculectomy in glaucoma triple procedure to treat pseudoexfoliation glaucoma. Arch Ophthalmol. 99 ; 117(10):1311-8. It is combined cataract/glaucoma surgery study published before April 2000
Jacobi PC, Dietlein TS, Krieglstein GK. The risk profile of trabecular aspiration versus trabeculectomy in glaucoma triple procedure. Graefes Arch Clin Exp Ophthalmol. 2000;238(7):545-51. [pmid: 10955654]. It is combined cataract/glaucoma surgery study published before April 2000
Jaenen N, Baudouin C, Pouliquen P, Manni G, Figueiredo A, Zeyen T. Ocular symptoms and signs with preserved and preservative-free glaucoma medications. Eur J Ophthalmol. 2007;17(3):341-9. [pmid: 17534814]. Data not abstractable
Jain S. Betaxolol-associated anterior uveitis. Eye (Lond). 94 ;8(Pt 6):708-9. It is not a RCT and has less than 100 patients
Jampel HD, Bacharach J, Sheu WP, Wohl LG, Solish AM, Christie W. Randomized clinical trial of latanoprost and unoprostone in patients with elevated intraocular pressure. Am J Ophthalmol. 2002;134(6):863-71. [pmid: 12470755]. Other (specify):unoprostone
Januleviciene I, Ehrlich R, Siesky B, Nedzelskiene I, Harris A. Visual function, optic nerve structure, and ocular blood flow parameters after 1 year of glaucoma treatment with fixed combinations. Non-FDA-approved drug combination
Januleviciene I, Ehrlich R, Siesky B, Nedzelskiene I, Harris A. Visual function, optic nerve structure, and ocular blood flow parameters after 1 year of glaucoma treatment ith fixed combinations. Duplicate
Januleviciene I, Harris A, Kagemann L, Siesky B, McCranor L. A comparison of the effects of dorzolamide/timolol fixed combination versus latanoprost on intraocular pressure and pulsatile ocular blood flow in primary open-angle glaucoma patients. Medical KQ 3 only
Januszewski T, Nowakowska-Maziarz M, Kliszczewski D. Simultaneous cataract and glaucoma surgery. Selection of trabeculectomy site. Foreign language
Janz NK, Musch DC, Gillespie BW, Wren PA, Niziol LM. Evaluating clinical change and visual function concerns in drivers and nondrivers with glaucoma. Invest Ophthalmol Vis Sci. 2009;50(4):1718-25. [pmid: 19060263]. Does not address any key questions
Jappe U, Uter W, Menezes de Padua CA, Herbst RA, Schnuch A. Allergic contact dermatitis due to beta-blockers in eye drops: a retrospective analysis of multicentre surveillance data 1993–2004. Acta Derm Venereol. 2006;86(6):509-14. [pmid: 17106597]. Data not abstractable
Jardim AS, Ferreira LG, Mendes H, Coutinho D. Pilocarpine in ophthalmology. A PILOCARPINA EM OFTALMOLOGIA. Foreign language
Javitt J, Goldberg I. Comparison of the clinical success rates and quality of life effects of brimonidine tartrate 0.2% and Betaxolol 0.25% Suspension in patients with open-angle glaucoma and ocular hypertension. Duplicate
Javitt J, Goldberg I. Comparison of the clinical success rates and quality of life effects of brimonidine tartrate 0.2% and betaxolol 0.25% suspension in patients with open-angle glaucoma and ocular hypertension. Brimonidine Outcomes Study Group II. Medical KQ 3 only
Javitt JC. Clinical Effectiveness Quality of Life Associated with Brimonidine versus Betaxalol as Monotherapy for Glaucoma and Ocular Hypertension (OHT). Meeting abstract
Javitt JC, Gaasterland DE, Street DA. Treatment trials of glaucoma suspects. Ophthalmology. 91 ; 98(10):1483-5. No original data (e.g., systematic review, narrative review, editorial, letter)
Javitt JC, Schiffman RM, Atlas W, Baum KJ, Cookem DL, DuBiner HB, Katz JL, Kupin T, Memmen JE, Mundorf TK, Nelson E, Offenberg H, Schenker HI, Sharpe E, Stevenson D, Stewart WC, Tanchel N, Whitaker R. Clinical success and quality of life with brimonidine 0.2% or Timolol 0.5% used twice daily in glaucoma or ocular hypertension: A randomized clinical trial. Duplicate
Javitt J. THE CLINICAL SUCCESS RATE AND QUALITY OF LIFE ASSESSMENT OF BRIMONIDINE TARTRATE 0.2% COMPARED WITH TIMOLOL 0.5%, ADMINISTERED TWICE DAILY IN PATIENTS WITH PREVIOUSLY UNTREATED OPEN-ANGLE GLAUCOMA OR OCULAR HYPERTENSION. Meeting abstract
Jay JL, Allan D. The benefit of early trabeculectomy versus conventional management in primary open angle glaucoma relative to severity of disease. Eye (Lond). 89 ;3(Pt 5):528-35. Does not address any key questions
Jay JL, Murray SB. Early trabeculectomy versus conventional management in primary open angle glaucoma. Br J Ophthalmol. 88 ; 72(12):881-9. Data not abstractable
Jay JL. Earlier trabeculectomy. Trans Ophthalmol Soc U K. 83 ; 103(Pt 1):35-8. Other (specify): Not interested in studies comparing the ordering of interventions
Jayamanne DG, Kostakis A, Phelan PS. The outcome of 2.3 mm incision combined phacoemulsification, trabeculectomy and lens implantation of non-foldable intraocular lenses. Eye (Lond). 97 ;11(Pt 1):91-4. It is combined cataract/glaucoma surgery study published before April 2000
Jayaprakasam A, Ghazi-Nouri S. Periorbital fat atrophy - an unfamiliar side effect of prostaglandin analogues. Orbit. (6; status =Ophthalmology Department, Broomfield Hospital, Court Road, Chelmsford, Essex. anuradhajayaprakasam@hotmail.com). 2010;29:357-9. [pmid: 21158579]. It is a case series
Jerndal T, Lundstrom M. 330 trabeculectomies. A long time study 3–51/2 years). Acta Ophthalmol (Copenh). 80 ;58(6):947-56. OAG can’t be analyzed separately
Jerndal T, Lundstrom M. 330 trabeculectomies--a follow-up study through 1/2–3 years. Acta Ophthalmol (Copenh). 77 ; 55(1):52-62. OAG can’t be analyzed separately
Jiang B, Jiang YQ. Long-term follow-up of mitomycin C in trabeculectomy. Foreign language
Jiang Y-L, Yuan Z-L, Zhang W-Z, Zhang W-W, Li Y. The clinical study on the change of corneal endothelial cells after viscocanalotomy and trabeculectomy. Foreign language
John KD, Kloss G, Lubcke P. Occurrence of bronchial obstruction in asthma patients immediately following administration of timolol-containing eyedrops. Prax Klin Pneumol. 85; 39(8):281-3. It is a case series
Johnson DH, Epstein DL, Allen RC, Boys-Smith J, Campbell D, Rosenquist R, Van Buskirk EM. A one-year multicenter clinical trial of pilocarpine gel. Am J Ophthalmol. 84; 97(6):723-9. It is not a RCT and has less than 100 patients
Johnson DH, Yoshikawa K, Brubaker RF, Hodge DO. The effect of long-term medical therapy on the outcome of filtration surgery. Am J Ophthalmol. 94;117(2):139-48. OAG can’t be analyzed separately
Johnson LN. Medical vs surgical therapy in preventing visual field loss. Ophthalmology. 2003;110(2):250-1. [pmid: 12578761]. No original data (e.g., systematic review, narrative review, editorial, letter)
Johnson TV, Fan S, Zhan G, Camras CB, Toris CB. Efficacy and mechanisms of intraocular pressure reduction with latanoprost and timolol in participants with ocular hypertension: a comparison of 1 and 6 weeks of treatment. J Glaucoma. 2010;19(6):356-64. [pmid: 20179619]. It is not a RCT and has less than 100 patients, Data not abstractable
Johnson TV, Toris CB, Fan S, Camras CB. Effects of central corneal thickness on the efficacy of topical ocular hypotensive medications. J Glaucoma. 2008;17(2):89-99. [pmid: 18344753]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Jonas JB. Systemic carbonic anhydrase inhibitors have been used to reduce intraocular pressure in glaucoma patients unresponsive to other anti glaucomatous medical treatments. J Glaucoma. 2001;10(5):441. [pmid: 11711848]. No original data (e.g., systematic review, narrative review, editorial, letter)
Jonasson F. Dangerous antihypertensive treatment. Br Med J. 79; 2(6199):1218. It is a case series
Jones FL Jr, Ekberg NL. Exacerbation of asthma by timolol. N Engl J Med. 79;301(5):270. It is a case series
Jones R 3rd, Triana MI, Zaslow K, Sponsel WE. Uniocular drug trial. Ophthalmology. 2005;112(6):1170. author reply 1170–1. [pmid: 15936449]. No original data (e.g., systematic review, narrative review, editorial, letter)
Jonescu-Cuypers CP, Roessler G, Hellmich M, Diestelhorst M. Comparing Efficacy of Xalacom™ and Cosopt™ on Intraocular Pressure and Optic Nerve Head Perfusion in Glaucoma Patients: A Randomized Cross-Over Trial. Meeting abstract
Jonescu-Cuypers CP, Jacobi PC, Konen W, Krieglstein GK. Primary viscocanalostomy versus trabeculectomy in caucasian patients with open-angel glaucoma: a prospective randomised trial. Meeting abstract
Jonescu-Cuypers C, Jacobi P, Konen W, Krieglstein G. Primary viscocanalostomy versus trabeculectomy in white patients with open-angle glaucoma: A randomized clinical trial. Ophthalmology. 2001;108(2):254-8. [pmid: 11158795]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Jothi R, Ismail AM, Senthamarai R, Pal S. A comparative study on the efficacy, safety, and cost-effectiveness of bimatoprost/timolol and dorzolamide/timolol combinations in glaucoma patients. Medical KQ 3 or KQ 3 and KQ 6 only
Jothi R, Ismail AM, Senthamarai R, Pal S. A comparative study on the efficacy, safety, and cost-effectiveness of bimatoprost/timolol and dorzolamide/timolol combinations in glaucoma patients. Indian J Pharmacol. (6; status =RVS College of Pharmaceutical Sciences, Sulur, Coimbatore–641 402, Tamilnadu, India.). 2010;42:362-5. [pmid: 21189906]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Joyce PW, Mills KB. A COMPARISON OF EQUIVALENT DOSAGE FORMS OF ACETAZOLAMIDE IN PRIMARY OPEN ANGLE GLAUCOMA. Meeting abstract
Joyce PW, Mills KB. Comparison of the effect of acetazolamide tablets and sustets on diurnal intraocular pressure in patients with chronic simple glaucoma. Br J Ophthalmol. 90;74(7):413-6. It is not a RCT and has less than 100 patients
Joyce PW, Raj PS. Topical beta blockers and serum lipoproteins. Br J Ophthalmol. 91;75(8):510-1. No original data (e.g., systematic review, narrative review, editorial, letter)
Joyce PW. Taste disturbance with acetazolamide. Lancet. 90; 336(8728):1446. No original data (e.g., systematic review, narrative review, editorial, letter)
Joyce PW, Mills KB, Richardson T, Mawer GE. Equivalence of conventional and sustained release oral dosage formulations of acetazolamide in primary open angle glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Juhas T. Argon laser trabeculoplasty--long-term results. Foreign language
Jurowski P, Gos R. Effectiveness of the combined surgical treatment for glaucoma and cataract. Foreign language
Juzych MS, Chopra V, Banitt MR, Hughes BA, Kim C, Goulas MT, Shin DH. Comparison of long-term outcomes of selective laser trabeculoplasty versus argon laser trabeculoplasty in open-angle glaucoma. Ophthalmology. 2004;111(10):1853-9. [pmid: 15465546]. It is a case series
Juzych MS, Chopra V, Shin DH, Goulas MT, Shobit R, Hughes BA, Kim C. Comparison of Long-term Outcome Between SLT and ALT in Chronic Open-Angle Glaucoma Patients. Meeting abstract
Kaback M, Geanon J, Katz G, Ripkin D, Przydryga J. Ocular hypotensive efficacy of travoprost in patients unsuccessfully treated with latanoprost. Curr Med Res Opin. 2004;20(9):1341-5. [pmid: 15383181]. It is a case series
Kaback M, Scoper SV, Arzeno G, James JE, Hua SY, Salem C, Dickerson JE, Landry TA, Bergamini MV. Intraocular pressure-lowering efficacy of brinzolamide 1%/timolol 0.5% fixed combination compared with brinzolamide 1% and timolol 0.5%. Ophthalmology. 2008;115(10):1728-34. 1734.e1. 2. [pmid: 18538406]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Kabiru J, Bowman R, Wood M, Mafwiri M. Audit of trabeculectomy at a tertiary referral hospital in East Africa. J Glaucoma. 2005;14(6):432-4. [pmid: 16276273]. It is a case series
Kabuni M, Maertens K, Missotten L. The effect of high-percent pilocarpine in the pigmented eye. Foreign language
Kaburaki T, Koshino T, Kawashima H, Numaga J, Tomidokoro A, Shirato S, Araie M. Initial trabeculectomy with mitomycin C in eyes with uveitic glaucoma with inactive uveitis. Eye (Lond). 2009;23(7):1509-17. [pmid: 19521438]. It is not a RCT and has less than 100 patients
Kahana A, Marcet MM, Albert DM, Thliveris AT. Drug-induced cicatrising granulomatous conjunctivitis. Br J Ophthalmol. 2007;91(5):691-2. [pmid: 17446509]. It is a case series
Kahook MY, Noecker RJ. Fibrin glue-assisted glaucoma drainage device surgery. Br J Ophthalmol. 2006;90(12):1486-9. [pmid: 16916877]. It is not a RCT and has less than 100 patients
Kahook MY. Bleb morphology and vascularity after trabeculectomy with intravitreal ranibizumab: a pilot study. Am J Ophthalmol. 2010;150(3):399-403. e1. [pmid: 20570237]. Does not address any key questions
Kahook MY, Lathrop KL, Noecker RJ. One-site versus two-site endoscopic cyclophotocoagulation. J Glaucoma. 2007;16(6):527-30. [pmid: 17873713]. It is not a RCT and has less than 100 patients
Kaiser HJ, Flammer J, Stumpfig D, Hendrickson P. Longterm visual field follow-up of glaucoma patients treated with beta-blockers. Vass-2007
Kaiser PK, Pineda R, Albert DM, Shore JW. ‘Black cornea’ after long-term epinephrine use. Arch Ophthalmol. 92;110(9):1273-5. It is a case series
Kaiserman I, Fendyur A, Vinker S. Topical beta blockers in asthmatic patients-is it safe. Curr Eye Res. 2009;34(7):517-22. [pmid: 19899964]. Does not address any key questions
Kaiya T, Yuguchi T, Sawaguchi S, Iwata K. NON-PENETRATING LAMELLAR TRABECULAECTOMY WITH MMC APPLICATION FOR OPEN ANGLE GLAUCOMA. Meeting abstract
Kalavala M, Statham BN. Allergic contact dermatitis from timolol and dorzolamide eye drops. Contact Dermatitis. 2006;54(6):345. [pmid: 16787459]. It is a case series
Kalenak J, Ripkin D, Medendorp S. A RANDOMIZED CONTROLLED TRIAL OF THE MOLTENO IMPLANT WITH AND WITHOUT MITOMYCIN-C. Meeting abstract
Kalra BR, Sood NN, Agarwal HC. Hypersecretion glaucoma. Indian J Ophthalmol. 84;32(2):109-11. No subjects with open-angle glaucoma
Kaluzny JJ, Szaflik J, Czechowicz-Janicka K, Kaluzny J, Orzalkiewicz A, Zaleska A, Krajewska M, Stewart JA, Leech JN, Stewart WC. Timolo 0.5%/dorzolamide 2% fixed combination versus timolol 0.5%/pilocarpine 2% fixed combination in primary open-angle glaucoma or ocular hypertensive patients. Acta Ophthalmol Scand. 2003;81(4):349-354. [pmid: 12859261]. Does not address any key questions
Kaluzny JJ, Szaflik J, Czechowicz-Janicka K, Kaluzny J, Orzalkiewicz A, Zaleska A, Krajewska M, Stewart JA, Leech JN, Stewart WC. Timolol 0.5%/dorzolamide 2% fixed combination versus timolol 0.5%/pilocarpine 2% fixed combination in primary open-angle glaucoma or ocular hypertensive patients. Acta Ophthalmol Scand. 2003;81(4):349-54. [pmid: 12859261]. Other (specify):pilocarpine
Kaluzny JJ, Szaflik J, Czechowicz-Janicka K, Kaluzny J, Orzalkiewicz A, Zaleska-Zmijewska A, Krajewska M, Stewart JA, Leech JN, Stewart WC. Timolol 0.5%/dorzolamide 2% fixed combination versus timolol 0.5%/pilocarpine 2% fixed combination in primary open-angle glaucoma or ocular hypertensive patients. Foreign language
Kaluzny J, Sobecki R, Czechowicz-Janicka K, Kecik D, Kaluzny BJ, Stewart JA, Stewart WC. Efficacy and safety of latanoprost versus pilocarpine/timolol maleate fixed combination in patients with primary open-angle glaucoma or ocular hypertension. Acta Ophthalmol. 2008;86(8):860-5. [pmid: 18721251]. Other (specify):pilocarpine
Kamal D, Garway-Heath D, Ruben S, O’Sullivan F, Bunce C, Viswanathan A, Franks W, Hitchings R. Results of the betaxolol versus placebo treatment trial in ocular hypertension. Vass-2007
Kammer JA, Katzman B, Ackerman SL, Hollander DA. Efficacy and tolerability of bimatoprost versus travoprost in patients previously on latanoprost: a 3-month, randomised, masked-evaluator, multicentre study. The British journal of ophthalmology. 2010;94(1):74-9. [pmid: 19726422]. OAG can’t be analyzed separately
Kammer JA, Katzman B, Ackerman SL, Hollander DA. Efficacy and tolerability of bimatoprost versus travoprost in patients previously on latanoprost: a 3-month, randomised, masked-evaluator, multicentre study. Medical KQ 3 only
Kampik A. European Study Group. A COMPARISON OF THE EFFICACY AND SAFETY OF LATANOPROST (XALATAN®) WITH BRIMONIDINE (ALPHAGAN®) IN PATIENTS WITH OPEN ANGLE GLAUCOMA AND OCULAR HYPERTENSION. Meeting abstract
Kampik A, Arias-Puente A, O’Brart DP, Vuori ML. Intraocular pressure-lowering effects of latanoprost and brimonidine therapy in patients with open-angle glaucoma or ocular hypertension: a randomized observer-masked multicenter study. Medical KQ 3 or KQ 3 and KQ 6 only
Kandarakis A, Soumplis V, Karampelas M, Panos C, Kyriakos N, Baxevanakis A, Karagiannis D. Efficacy of brimonidine in preventing intraocular pressure spikes following phacoemulsification in glaucoma patients. Eur J Ophthalmol. (6; status =1st Ophthalmology Department, Ophthalmiatrion Eye Hospital of Athens, Sina 2, Athens, Greece. artemiskandarakis@yahoo.gr). 2010;20:994-9. [pmid: 20544673]. Does not address any key questions
Kang RX. The intraocular pressure depressive effect of puerarin. Zhonghua Yan Ke Za Zhi. 93; 29(6):336-9. Does not address any key questions
Kanner EM, Netland PA, Sarkisian SR Jr, Du H. Ex-PRESS miniature glaucoma device implanted under a scleral flap alone or combined with phacoemulsification cataract surgery. J Glaucoma. 2009;18(6):488-91. [pmid: 19223790]. OAG can’t be analyzed separately
Kano K, Kuwayama Y, Mizunoya H. Clinical results of fornix-based trabeculectomy with a scleral tunnel. Foreign language
Kanzaki T, Kato N, Kabasawa Y, Mizuno N, Yuguchi M, Majima A. Contact dermatitis due to the beta-blocker befunolol. Contact Dermatitis. 88;19(5):388. It is a case series
Kaplan-Messas A, Cohen Y, Blumenthal EZ, Avni I. Trabeculectomy and photo-trabeculectomy with and without peripheral iridectomy. Duplicate
Kardasis CT, Shin DH, Kim C, Lee C, Juzych MS, Hughes BA. TOPICAL VERAPAMIL IN GLAUCOMA FILTERING SURGERY. Meeting abstract
Karlik JS, Baker KS, Dutt RM. COMPARISON OF LATANOPROST VERSES APRACLONIDINE AS PRETREATMENT IN EYES UNDERGOING ARGON LASER TRABECULOPLASTY. Meeting abstract
Karlik JS, Barber JC, Humphreys A, Dutt RM. THE COMPARISON OF LATANOPROST VERSES APRACLONIDINE AS PRETREATMENT IN EYES UNDERGOING ARGON LASER TRABECULOPLASTY. Meeting abstract
Karray H, Demailly P. Comparative study of long-term tonometry results of 2 surgical technics combining extraction of the crystalline lens and trabeculectomy. Bull Soc Ophtalmol Fr. 88; 88(1):59-62. 65. It is combined cataract/glaucoma surgery study published before April 2000
Kashintseva LT, Krivitskii AK. The therapeutic efficacy of Arutimol in open-angle glaucoma. Foreign language
Kashintseva LT, Teliushchenko VD. Late observations on the effectiveness of a new antiglaucoma operation--“concealed” sinusotrabeculotomy--in initial exfoliative glaucoma. Foreign language
Kashintseva LT, Mel’nik LS, Salenko SV. A comparative assessment of the effectiveness of sinusotrabeculotomy in different stages of open-angle glaucoma. Foreign language
Kashiwagi K, Tsumura T, Tsukahara S. Long-term effects of latanoprost monotherapy on intraocular pressure in Japanese glaucoma patients. J Glaucoma. 2008;17(8):662-6. [pmid: 19092463]. It is not a RCT and has less than 100 patients
Kashkouli MB, Parvaresh MM, Mirzajani H, Astaraki A, Falavarjani KG, Ahadian A. Intraoperative mitomycin C use during filtration surgery and lacrimal drainage system obstruction. Am J Ophthalmol. 2009;147(3):453-457. e1. [pmid: 19019341]. It is not a RCT and has less than 100 patients
Kashkouli MB, Rezaee R, Nilforoushan N, Salimi S, Foroutan A, Naseripour M. Topical antiglaucoma medications and lacrimal drainage system obstruction. Ophthal Plast Reconstr Surg. 2008;24(3):172-5. OAG can’t be analyzed separately
Kass MA. Five-year follow-up study of timolol in patients at moderate risk of developing open-angle glaucoma. CHIBRET INT. J OPHTHALMOL. 90;7(1):5-8. Other (specify):Duplicate for RefId 9468
Kass MA. The ocular hypertension treatment study. J GLAUCOMA. 94;3(2):97-100. No original data (e.g., systematic review, narrative review, editorial, letter)
Kass MA. Timolol treatment prevents or delays glaucomatous visual field loss in individuals with ocular hypertension: a five-year, randomized, double-masked, clinical trial. Trans Am Ophthalmol Soc. 89; 87:598-618. Other (specify):Duplicate for RefId 9468
Kass MA. Topical carbonic anhydrase inhibitors. Am J Ophthalmol. 89;107(3):280-2. No original data (e.g., systematic review, narrative review, editorial, letter)
Kass MA, Gordon MO, Gao F, Heuer DK, Higginbotham EJ, Johnson CA, Keltner JK, Miller JP, Parrish RK, Wilson MR. Delaying treatment of ocular hypertension: the ocular hypertension treatment study. Arch Ophthalmol. 2010;128(3):276-87. [pmid: 20212196]. Other (specify):Study design does not match KQ
Kass MA, Gordon MO, Hoff MR, Parkinson JM, Kolker AE, Hart WM. Topical timolol administration reduces the incidence of glaucomatous damage in ocular hypertensive individuals. A randomized, double-masked, long-term clinical trial (1). Maier, 2005
Kass MA, Gordon MO, Hoff MR, Parkinson JM, Kolker AE, Hart WM Jr, Becker B. Topical timolol administration reduces the incidence of glaucomatous damage in ocular hypertensive individuals. A randomized, double-masked, long-term clinical trial (1). J Glaucoma. 93; 2(Suppl A):1-2. Data not abstractable
Kass MA, Gordon MO, Hoff MR, Parkinson JM, Kolker AE, Hart WM Jr, Becker B. Topical timolol administration reduces the incidence of glaucomatous damage in ocular hypertensive individuals. A randomized, double-masked, long-term clinical trial. Arch Ophthalmol. 89; 107(11):1590-8. Other (specify):Duplicate for RefId 9468
Kass MA, Heuer DK, Higginbotham EJ, Johnson CA, Keltner JL, Miller JP, Parrish RK 2nd, Wilson MR, Gordon MO. The Ocular Hypertension Treatment Study: a randomized trial determines that topical ocular hypotensive medication delays or prevents the onset of primary open-angle glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Kass MA, Kolker AE, Gordon M, Goldberg I, Gieser DK, Krupin T, Becker B. Acetazolamide and urolithiasis. Ophthalmology. 81; 88(3):261-5. OAG can’t be analyzed separately
Kass MA, Korey M, Gordon M, Becker B. Timolol and acetazolamide. A study of concurrent administration. Unique comparators
Kass MA, Mandell AI, Goldberg I. Dipivefrin and epinephrine treatment treatment of elevated intraocular pressure. A comparative study. ARCH OPHTHALMOL. 79;97(10):1865-1866. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Kass MA, Meltzer DW, Gordon M, Cooper D, Goldberg J. Compliance with topical pilocarpine treatment. Am J Ophthalmol. 86; 101(5):515-23. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Katz LJ, Cohen JS, Batoosingh AL, Felix C, Shu V, Schiffman RM. Twelve-month, randomized, controlled trial of bimatoprost 0.01%, 0.0125%, and 0.03% in patients with glaucoma or ocular hypertension. American journal of ophthalmology. 2010;149(4):661-671. e1. [pmid: 20346780]. OAG can’t be analyzed separately
Katz IM. Efficacy and safety of long-term maintenance treatment with timolol ophthalmic solution in chronic open-angle glaucoma (author’s transl). Foreign language
Katz IM. 5-FU trabeculectomy. Ophthalmology. 92;99(1):3. Does not address any key questions
Katz JL, Spaeth GL, Steinmann WC, Fahmy IA, Ali MA, Gross RL. TOPICAL TRIFLURIDINE USE FOLLOWING FILTERING SURGERY: A RANDOMIZED PROSPECTIVE TRIAL. Meeting abstract
Katz LJ. Brimonidine Outcomes Study Group. CLINICAL SUCCESS RATE AND QUALITY OF LIFE OF BRIMONIDINE 0.2% BID VERSUS TIMOLOL 0.5% BID IN NAIVE GLAUCOMA PATIENTS. Meeting abstract
Katz LJ. Brimonidine tartrate 0.2% Twice daily vs timolol 0.5% Twice daily: 1-year results in glaucoma patients. Medical KQ 3 or KQ 3 and KQ 6 only
Katz LJ. Brimonidine tartrate 0.2% twice daily vs timolol 0.5% twice daily: 1-year results in glaucoma patients. Brimonidine Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
Katz LJ. Twelve-month evaluation of brimonidine-purite versus brimonidine in patients with glaucoma or ocular hypertension. Unique comparators
Katz LJ, Cantor LB, Spaeth GL. Complications of surgery in glaucoma. Early and late bacterial endophthalmitis following glaucoma filtering surgery. Ophthalmology. 85;92(7):959-63. It is not a RCT and has less than 100 patients
Katz LJ, Cohen JS, Batoosingh AL, Felix C, Shu V, Schiffman RM. Twelve-month, randomized, controlled trial of bimatoprost 0.01%, 0.0125%, and 0.03% in patients with glaucoma or ocular hypertension. Unique comparators
Katz L, Lewis R, Battosingh A, Liu CC. Bimatoprost/timolol Fixed Combination: A One-Year Double-Masked, Randomized Parallel Comparison to Its Individual Components in Patients With Glaucoma or Ocular Hypertension. Meeting abstract
Kaufman HS. Timolol-induced vasomotor rhinitis: a new iatrogenic syndrome. Arch Ophthalmol. 86;104(7):967. 970. Other (specify):case report of harm
Kaufman PL. The prostaglandin wars. Am J Ophthalmol. 2003;136(4):727-8. [pmid: 14516814]. No original data (e.g., systematic review, narrative review, editorial, letter)
Kaur J, Singh G. A prospective comparison between trabeculectomy, Scheie’s sclerostomy under scleral flap operation and thermal (Sub Scleral Scheie’s) procedure. Indian J Ophthalmol. 88;36(4):158-61. OAG can’t be analyzed separately
Kazakova EL. Laser trabeculoplasty and the status of the crystalline lens in open-angle glaucoma. Foreign language
Kazakova EL, Akopian VS. Effect of laser therapy on visual function in primary open-angle glaucoma. Foreign language
Keates EU, Stone R. The effect of d-timolol on intraocular pressure in patients with ocular hypertension. Am J Ophthalmol. 84; 98(1):73-8. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Keates EU. Evaluation of timolol maleate combination therapy in chronic open-angle glaucoma. Am J Ophthalmol. 79;88(3 Pt 2):565-71. Does not address any key questions
Keates EU, Friedland BR, Stewart RH, Mandell AI. Carteolol hydrochloride: controlled evaluations of its ocular hypotensive efficacy relative to its vehicle, and, in combination with pilocarpine, relative to timolol. J Glaucoma. 94;3(4):315-22. Other (specify):pilocarpine
Kee CW, Youn DH. The influence of miotics on the visual field. Korean J Ophthalmol. 87;1(1):52-8. It is not a RCT and has less than 100 patients
Keisu M, Wiholm BE, Ost A, Mortimer O. Acetazolamide-associated aplastic anaemia. J Intern Med. 90;228(6):627-32. It is a case series
Kendall K, Mundorf T, Nardin G, Zimmerman TJ, Hesse R, Lavin P. Tolerability of timolol and betaxolol in patients with chronic open-angle glaucoma. Clin Ther. 87;9(6):651-5. Data not abstractable
Kendrick R, Kollarits CR, Khan N. The results of ab interno laser thermal sclerostomy combined with cataract surgery versus trabeculectomy combined with cataract surgery 6 to 12 months postoperatively. Ophthalmic Surg Lasers. 96; 27(7):583-6. It is combined cataract/glaucoma surgery study published before April 2000
Kent AR, Dubiner HB, Whitaker R, Mundorf TK, Stewart JA, Cate EA, Stewart WC. The efficacy and safety of diclofenac 0.1% versus prednisolone acetate 1% following trabeculectomy with adjunctive mitomycin-C. Ophthalmic Surg Lasers. 98;29(7):562-9. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Kent AR, Vroman DT, Thomas TJ, Hebert RL, Crosson CE. Interaction of pilocarpine with latanoprost in patients with glaucoma and ocular hypertension. J Glaucoma. 99;8(4):257-62. It is not a RCT and has less than 100 patients
Kerstetter JR, Brubaker RF, Wilson SE, Kullerstrand LJ. Prostaglandin F2 alpha-1-isopropylester lowers intraocular pressure without decreasing aqueous humor flow. Am J Ophthalmol. 88; 105(1):30-4. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Kessler C, Bishop K. FIXED DRUG COMBINATION FOR GLAUCOMA TREATMENT. Meeting abstract
Kessler C, Christ T. Incidence of uveitis in glaucoma patients using metipranolol. J. GLAUCOMA. 93;2(3):166-170. OAG can’t be analyzed separately
Khalili MA, Diestelhorst M, Krieglstein GK. Long-term follow-up of 700 trabeculectomies. Klin Monbl Augenheilkd. 2000;217(1):1-8. discussion 9. [pmid: 10949810]. It is a case series
Khalili MA, Diestelhorst M, Krieglstein GK. Long-term follow-up of 700 trabeculectomies. Langzeituntersuchung von 700 trabekulektomien. Foreign language
Khan AM, Jilani FA. Comparative results of limbal based versus fornix based conjunctival flaps for trabeculectomy. Indian J Ophthalmol. 92;40(2):41-3. Data not abstractable
Khatana A, Craven ER, Mundorf TK, Liu CC, Batoosingh A. A Randomized, Controlled Comparison of Conjunctival Hyperemia in Patients Treated with Bimatoprost 0.01% or Vehicle Who Were Previously Controlled on Latanoprost. Meeting abstract
Khaw PT, Grehn FJ, Overton BM. A Multicentre, Double-Masked, Randomised, Placebo-Control Study to Evaluate the Efficacy, Safety, and Tolerability of Subconjunctival Injections of 100 μG CAT-152 Human Anti-Tgfß2 Monoclonal Antibody as an Agent to Modulate Wound Healing Following First Time Trabeculectomy (Study 0102). Meeting abstract
Khaw P, Grehn F, Hollo G, Overton B, Wilson R, Vogel R, Smith Z. A phase III study of subconjunctival human anti-transforming growth factor beta(2) monoclonal antibody (CAT-152) to prevent scarring after first-time trabeculectomy. Ophthalmology. 2007;114(10):1822-30. [pmid: 17908591]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Khouri AS, Willman M, Fechtner RD, Zimmerman TJ. 5-Fluorouracil in primary combined glaucoma surgery. Ophthalmology. 97; 104(10):1527-8. No original data (e.g., systematic review, narrative review, editorial, letter)
Khurana AK, Chawla U, Passi N, Jyoti Archana, Yogesh. A comparative study of combined small-incision cataract surgery with sutureless trabeculectomy versus trabeculectomy using W-shaped incision. Nepal J Ophthalmol. (5; status =Regional Institute of Ophthalmology, Pt BD Sharma, Post Graduate Institute of Medical Sciences, Rohtak, Haryana, India.). 2011;3:13-8. [pmid: 21587324]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Kim CY, Hong S, Seong GJ. Brimonidine 0.2% versus brimonidine Purite 0.15% in Asian ocular hypertension. Unique comparators
Kim DM, Lim KH. Aqueous shunts: single-plate Molteno vs ACTSEB. Acta Ophthalmol Scand. 95;73(3):277-80. Data not abstractable
Kim HJ, Cho BJ. Long-Term Effect of Latanoprost on Central Corneal Thickness in Normal Tension Glaucoma. J Ocul Pharmacol Ther. 2010. Does not address any key questions
Kim HK, Kim CY, Lim CS, Lee JH, Hong YJ. EFFECTS ON INTRAOCULAR PRESSURE AND ADVERSE EFFECTS OF LATANOPROST. A COMPARISON WITH TIMOLOL. PASE III STUDY IN KOREA. Meeting abstract
Kim HY, Egbert PR, Singh K. Long-term comparison of primary trabeculectomy with 5-fluorouracil versus mitomycin C in West Africa. J Glaucoma. 2008;17(7):578-83. [pmid: 18854737]. It is not a RCT and has less than 100 patients
Kim JW, Jung CI, Hwang HS. Comparative study of three phacotrabeculectomy procedures through a single incision. Korean J Ophthalmol. 98;12(1):30-6. It is combined cataract/glaucoma surgery study published before April 2000
Kim P, Lertsumikul S. Cystoid macular oedema associated with brimonidine therapy. Clin Experiment Ophthalmol. 2003;31(2):165-6. [pmid: 12648055]. It is a case series
Kim YY, Glover B, Shin DH, Lee D. Fluorometholone-ALT Study Group. Effect of Topical Anti-Inflammatory Treatment on the Long-Term Outcome of Laser Trabeculoplasty. Meeting abstract
Kim YY, Glover BK, Shin DH, Lee D, Frenkel RE, Abreu MM. Effect of topical anti-inflammatory treatment on the long-term outcome of laser trabeculoplasty. Fluorometholone-Laser Trabeculoplasty Study Group. Am J Ophthalmol. 98;126(5):721-3. Does not address any key questions
Kimal Arici M, Topalkara A, Guler C. Additive effect of latanoprost and dorzolamide in patients with elevated intraocular pressure. Int Ophthalmol. 98; 22(1):37-42. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Kinshuck D. Glauline (metipranolol) induced uveitis and increase in intraocular pressure. Br J Ophthalmol. 91;75(9):575. It is a case series
Kirkness CM, Steele AD, Ficker LA, Rice NS. Coexistent corneal disease and glaucoma managed by either drainage surgery and subsequent keratoplasty or combined drainage surgery and penetrating keratoplasty. Br J Ophthalmol. 92;76(3):146-52. It is combined cataract/glaucoma surgery study published before April 2000
Kirwan JF, Cousens S, Venter L, Cook C, Stulting A, Roux P, Murdoch I. Effect of beta radiation on success of glaucoma drainage surgery in South Africa: randomised controlled trial. Kirwan 2009
Kirwan JF, Rennie C, Evans JR. Beta radiation for glaucoma surgery. Systematic review
KITAZAWA Yoshiaki, AZUMA Ikuo, Makoto ARAIE. Clinical evaluation of betaxolol hydrochloride in the treatment of primary open angle glaucoma and ocular hypertension. Multi-center double-masked study in comparison with timolol. Rinsho Hyoka (Clinical Evaluation). 89;17(2):243-274. Other (specify):foreign language
Kitazawa Y. An open-label multicenter study on the efficacy and safety of topical use of latanoprost for 156 weeks. Foreign language
Kitazawa Y, Tsuchisaka H. Effects of timolol on corneal sensitivity and tear production. Int Ophthalmol. 80;3(1):25-9. Does not address any key questions
Kitazawa Y. Multicenter double-blind comparison of carteolol and timolol in primary open-angle glaucoma and ocular hypertension. ADV THER. 93; 10(3):95-131. Other (specify):Age distributions show >5% below 40
Kitazawa Y. Phase III comparative study of MK-507 ophthalmic solution in primary open-angle glaucoma and ocular hypertension. FOLIA OPHTHALMOL JPN. 94;45(9):1023-1033. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Kitazawa Y. Prophylactic therapy of ocular hypertension. A prospective study. Trans Ophthalmol Soc N Z. 81;33:30-2. It is not a RCT and has less than 100 patients
Kitazawa Y, Azuma I, Iwata K, Tsukahara S, Shiose Y, Araie M, Shirato S, Mizogami K, Mishima H, Futa R, Komemushi S. Dorzolamide, A Topical Carbonic Anhydrase Inhibitor: A Two-Week Dose-Response Study in Patients with Glaucoma or Ocular Hypertension. J Glaucoma. 94; 3(4):275-279. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Kitazawa Y, Azuma I, Shirato S, Tsukahara S, Mishima H, Mizogami K, Ogawa N, Odo S. Phase III Clinical Study of AG-901 Ophthalmic Solution on Primary Open-Angle Glaucoma and Ocular Hypertension: A Multicenter, Double-Blind Comparison with 0.5% Timolol Maleate. Rinsho Iyaku (Journal of Clinical Therapeutics and Medicines). 97;13(11):2975-91. Does not address any key questions
Kitazawa Y, Kawase K, Matsushita H, Minobe M. Trabeculectomy with mitomycin. A comparative study with fluorouracil. Arch Ophthalmol. 91; 109(12):1693-8. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Kitazawa Y, Suemori-Matsushita H, Yamamoto T, Kawase K. Low-dose and high-dose mitomycin trabeculectomy as an initial surgery in primary open-angle glaucoma. Ophthalmology. 93;100(11):1624-8. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Kitazawa Y, Taniguchi T, Nakano Y, Shirato S, Yamamoto T. 5-Fluorouracil for trabeculectomy in glaucoma. Graefes Arch Clin Exp Ophthalmol. 87;225(6):403-5. It is not a RCT and has less than 100 patients
Kitazawa Y, Tsukahara S, Abe H, Araie M, Nakashima M. Prolonged Ocular Hypotensive Effect of WP-934 in Primary Open-Angle Glaucoma and Ocular Hypertensive Patients. Rinsho Iyaku (Journal of Clinical Therapeutics and Medicines). 96;12(12):2703-15. Does not address any key questions
Kitnarong N, Zhao Y, Netland PA, Kent AR. Efficacy of latanoprost and timolol maleate in black and white patients. Medical KQ 3 only
Kitsos G, Aspiotis M, Alamanos Y, Psilas K. Results of a modified non-penetrating deep sclerectomy in the treatment of open angle glaucoma with or without cataract. 2010;4(1):695-701. Does not address any key questions
Kjellgren D, Douglas G, Mikelberg FS, Drance SM, Alm A. The short-time effect of latanoprost on the intraocular pressure in normal pressure glaucoma. Acta Ophthalmol Scand. 95;73(3):233-6. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Klein HZ, Lugo M, Shields MB, Leon J, Duzman E. A dose-response study of piloplex for duration of action. Am J Ophthalmol. 85; 99(1):23-6. Other (specify):pilocarpine
Kleinmann G, Katz H, Pollack A, Schechtman E, Rachmiel R, Zalish M. Comparison of trabeculectomy with mitomycin C with or without phacoemulsification and lens implantation. Ophthalmic Surg Lasers. 2002;33(2):102-8. [pmid: 11942540]. Does not address any key questions
Knapp E, Kossionis P. Comparative study of 2 percent and 4 percent pilocarpine in the treatment of simple glaucoma. Klin Monbl Augenheilkd. 68;153(3):391-3. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Kobayashi H, Kobayashi K. Viscocanalostomy vs. Trabeculectomy with Mitomycin: A Randomized Comparison of Safety and 10P-lowering Effect. Meeting abstract
Kobayashi H, Iwakiri R, Kobayashi K, Okinami S. Hypotensive effect of unoprostone as adjunct to latanoprost during multiple drug therapy for glaucoma. Foreign language
Kobayashi H, Kobayashi K, Okinami S. A comparison of intraocular pressure-lowering effect of prostaglandin F2-alpha analogues, latanoprost, and unoprostone isopropyl. J Glaucoma. 2001;10(6):487-92. [pmid: 11740220]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Kobayashi H, Kobayashi K, Okinami S. A comparison of the intraocular pressure-lowering effect and safety of viscocanalostomy and trabeculectomy with mitomycin C in bilateral open-angle glaucoma. Cheng 2009 and Chai 2010
Kobayashi H, Kobayashi K, Okinami S. Efficacy of bunazosin hydrochloride 0.01% as adjunctive therapy of latanoprost or timolol. J Glaucoma. 2004;13(1):73-80. [pmid: 14704548]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Kobelt G, Jonsson L, Gerdtham U, Krieglstein GK. Direct costs of glaucoma management following initiation of medical therapy. A simulation model based on an observational study of glaucoma treatment in Germany. Graefes Arch Clin Exp Ophthalmol. 98;236(11):811-21. Does not address any key questions
Kobzeva VI, Kolotkova AI, Golovachev IuF. Clinical characteristics and results of conservative treatment of glaucoma with pseudoexfoliations. Foreign language
Kodjikian L, Durand B, Burillon C, Rouberol F, Grange JD, Renaudier P. Acetazolamide-induced thrombocytopenia. Arch Ophthalmol. 2004;122(10):1543-4. [pmid: 15477470]. It is a case series
Koeller AU, Pillunat LE, Mueller MF, Mollenhauer KA, Boehm AG. Comparison of Different Topical Beta blockers With Regard to Their Effect on Ocular Hemodynamics and Optic Nerve Head Blood Flow in Glaucoma Patients. Meeting abstract
Koeller AU, Pillunat LE, Schmidt J, Boehm AG, Allmeier HJ. EFFECT OF DIFFERENT BETA-BLOCKERS ON OCULAR HEMODYNAMICS, HYDRODYNAMICS AND OPTC NERVE HEAD BLOOD FLOW IN GLAUCOMA PATIENTS. Meeting abstract
Koerber NJ. Canaloplasty in One Eye Compared With Viscocanalostomy in the Contralateral Eye in Patients With Bilateral Open-angle Glaucoma. J Glaucoma. 2011. It is a case series
Kohler U, Schmoger E. Follow-up of cases of suspected glaucoma (author’s transl). Klin Monbl Augenheilkd. 75; 166(1):11-7. Does not address any key questions
Kolesnikova LN. Formation of the pathway for outflow of intraocular fluid after trabeculectomy. Foreign language
Kolker AE, Kass MA, Rait JL. Trabeculectomy with releasable sutures. Arch Ophthalmol. 94;112(1):62-6. Does not address any key questions
Kolker AE, Kass MA, Rait JL. Trabeculectomy with releasable sutures. Trans Am Ophthalmol Soc. 93; 91:131-41. discussion 141–5. Other (specify):Not a comparison of interest
Koller TLF, Sturmer J, Gloor B. Risk factors for trabeculectomy failure. Risikofaktoren fur das versagen einer trabekulektomie. Duplicate
Koller TL, Sturmer J, Gloor B. Risk factors for trabeculectomy failure. Foreign language
Koller T, Sturmer J, Reme CH, Gloor B, Fellman R. Membrane formation in the chamber angle after failure argon laser trabeculoplasty: Analysis of risk factors. Evid.-Based Eye Care. 2001;2(2):104-105. No original data (e.g., systematic review, narrative review, editorial, letter)
Konstas AGP, Holmes KT, Stewart WC. A compariosn of the efficacy and safety of latanoprost 0.005% every evening versus timolol/dorzolamide fixed combination twice daily. Meeting abstract
Konstas AGP, Lake S, Maltezos T, Holmes KT, Stweart WC. LATANOPROST COMPARED TO PILOCARPINE AS THIRD LINE THERAPY IN EXFOLIATION GLAUCOMA. Meeting abstract
Konstas AGP, Mantziris DA, Maltezos A, Cate EA, Stewart WC. Comparison of 24 hour control with Timoptic(registered trademark) 0.5% and Timoptic-XE(TM) 0.5% in exfoliation and primary open-angle glaucoma. Acta Ophthalmol Scand. 99; 77(5):541-543. It is not a RCT and has less than 100 patients
Konstas AG, Banyai L, Blask KD, Vath J, Kozobolis VP, Trub PR, Tsironi S, Maloutas S, Teus MA, Stewart WC. Intraocular pressure and safety in glaucoma patients switching to latanoprost/timolol maleate fixed combination from mono- and adjunctive therapies. Excluded drug
Konstas AG, Boboridis K, Tzetzi D, Kallinderis K, Jenkins JN, Stewart WC. Twenty-four-hour control with latanoprost-timolol-fixed combination therapy vs latanoprost therapy. Arch Ophthalmol. 2005;123(7):898-902. [pmid: 16009829]. Does not address any key questions
Konstas AG, Hollo G, Astakhov YS, Teus MA, Akopov EL, Jenkins JN, Stewart WC. Factors associated with long-term progression or stability in exfoliation glaucoma. Arch Ophthalmol. 2004;122(1):29-33. [pmid: 14718291]. Does not address any key questions
Konstas AG, Hollo G, Irkec M, Tsironi S, Durukan I, Goldenfeld M, Melamed S. Diurnal IOP control with bimatoprost versus latanoprost in exfoliative glaucoma: a crossover, observer-masked, three-centre study. Stewart 2010
Konstas AG, Hollo G, Mikropoulos D, Tsironi S, Haidich AB, Embeslidis T, Georgiadou I, Irkec M, Melamed S. Twenty-four-hour intraocular pressure control with bimatoprost and the bimatoprost/timolol fixed combination administered in the morning, or evening in exfoliative glaucoma. Non-FDA-approved drug combination
Konstas AG, Irkec MT, Teus MA, Cvenkel B, Astakhov YS, Sharpe ED, Hollo G, Mylopoulos N, Bozkurt B, Pizzamiglio C, Potyomkin VV, Alemu AM, Nasser QJ, Stewart JA, Stewart WC. Mean intraocular pressure and progression based on corneal thickness in patients with ocular hypertension. Eye (Lond). 2009;23(1):73-8. [pmid: 17917683]. Does not address any key questions
Konstas AG, Karabatsas CH, Lallos N, Georgiadis N, Kotsimpou A, Stewart JA, Stewart WC. 24-hour intraocular pressures with brimonidine purite versus dorzolamide added to latanoprost in primary open-angle glaucoma subjects. Ophthalmology. 2005;112(4):603-8. [pmid: 15808251]. Other (specify):applies to KQ3 but not RCT
Konstas AG, Katsimbris JM, Lallos N, Boukaras GP, Jenkins JN, Stewart WC. Latanoprost 0.005% versus bimatoprost 0.03% in primary open-angle glaucoma patients. Stewart 2010
Konstas AG, Katsimpris IE, Kaltsos K, Georgiadou I, Kordelou A, Nelson LA, Stewart WC. Twenty-four-hour efficacy of the brimonidine/timolol fixed combination versus therapy with the unfixed components. Unique comparators
Konstas AG, Kozobolis VP, Katsimpris IE, Boboridis K, Koukoula S, Jenkins JN, Stewart WC. Efficacy and safety of latanoprost versus travoprost in exfoliative glaucoma patients. Medical KQ 3 or KQ 3 and KQ 6 only
Konstas AG, Kozobolis VP, Lallos N, Christodoulakis E, Stewart JA, Stewart WC. Daytime diurnal curve comparison between the fixed combinations of latanoprost 0.005%/timolol maleate 0.5% and dorzolamide 2%/timolol maleate 0.5%. Eye (Lond). 2004;18(12):1264-9. [pmid: 15218522]. Other (specify):applies to KQ3 but not RCT
Konstas AG, Kozobolis VP, Tersis I, Leech J, Stewart WC. The efficacy and safety of the timolol/dorzolamide fixed combination vs latanoprost in exfoliation glaucoma. Just KQ 2 and/or 5
Konstas AG, Kozobolis VP, Tsironi S, Makridaki I, Efremova R, Stewart WC. Comparison of the 24-hour intraocular pressure-lowering effects of latanoprost and dorzolamide/timolol fixed combination after 2 and 6 months of treatment. Stewart 2010
Konstas AG, Lake S, Economou AI, Kaltsos K, Jenkins JN, Stewart WC. 24-Hour control with a latanoprost-timolol fixed combination vs timolol alone. Arch Ophthalmol. 2006;124(11):1553-7. [pmid: 17102001]. Other (specify):not approved combi
Konstas AG, Lake S, Economou AI, Kaltsos K, Jenkins JN, Stewart WC. 24-Hour Control With the Latanoprost/Timolol Maleate Fixed Combination versus Timolol Maleate. Meeting abstract
Konstas AG, Lake S, Maltezos AC, Holmes KT, Stewart WC. Twenty-four hour intraocular pressure reduction with latanoprost compared with pilocarpine as third-line therapy in exfoliation glaucoma. Excluded drug
Konstas AG, Maltezos AC, Gandi S, Hudgins AC, Stewart WC. Comparison of 24-hour intraocular pressure reduction with two dosing regimens of latanoprost and timolol maleate in patients with primary open-angle glaucoma. Stewart 2010
Konstas AG, Maltezos A, Bufidis T, Hudgins AG, Stewart WC. Twenty-four hour control of intraocular pressure with dorzolamide and timolol maleate in exfoliation and primary open-angle glaucoma. Eye (Lond). 2000;14(Pt 1):73-7. [pmid: 10755105]. It is not a RCT and has less than 100 patients
Konstas AG, Maltezos A, Mantziris DA, Sine CS, Stewart WC. The comparative ocular hypotensive effect of apraclonidine with timolol maleate in exfoliation versus primary open-angle glaucoma patients. Eye (Lond). 99;13(Pt 3a):314-8. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Konstas AG, Mantziris DA, Cate EA, Stewart WC. Effect of timolol on the diurnal intraocular pressure in exfoliation and primary open-angle glaucoma. Arch Ophthalmol. 97;115(8):975-9. Other (specify):Study design does not match KQ
Konstas AG, Mantziris DA, Maltezos A, Cate EA, Stewart WC. Comparison of 24 hour control with Timoptic 0.5% and Timoptic-XE 0.5% in exfoliation and primary open-angle glaucoma. Acta Ophthalmol Scand. 99;77(5):541-3. It is not a RCT and has less than 100 patients
Konstas AG, Mikropoulos DG, Embeslidis TA, Dimopoulos AT, Papanastasiou A, Haidich AB, Stewart WC. 24-h Intraocular pressure control with evening-dosed travoprost/timolol, compared with latanoprost/timolol, fixed combinations in exfoliative glaucoma. Non-FDA-approved drug combination
Konstas AG, Mikropoulos D, Dimopoulos AT, Moumtzis G, Nelson LA, Stewart WC. Second-line therapy with dorzolamide/timolol or latanoprost/timolol fixed combination versus adding dorzolamide/timolol fixed combination to latanoprost monotherapy. Medical KQ 3 only
Konstas AG, Mikropoulos D, Haidich AB, Ntampos KS, Stewart WC. Twenty-four-hour intraocular pressure control with the travoprost/timolol maleate fixed combination compared with travoprost when both are dosed in the evening in primary open-angle glaucoma. Non-FDA-approved drug combination
Konstas AG, Mikropoulos D, Kaltsos K, Jenkins JN, Stewart WC. 24-hour intraocular pressure control obtained with evening-versus morning-dosed travoprost in primary open-angle glaucoma. Unique comparators
Konstas AG, Mylopoulos N, Karabatsas CH, Kozobolis VP, Diafas S, Papapanos P, Georgiadis N, Stewart WC. Diurnal intraocular pressure reduction with latanoprost 0.005% compared to timolol maleate 0.5% as monotherapy in subjects with exfoliation glaucoma. Stewart 2010
Konstas AG, Nakos E, Tersis I, Lallos NA, Leech JN, Stewart WC. A comparison of once-daily morning vs evening dosing of concomitant latanoprost/timolol. Non-FDA-approved drug combination
Konstas AG, Papapanos P, Tersis I, Houliara D, Stewart WC. Twenty-four-hour diurnal curve comparison of commercially available latanoprost 0.005% versus the timolol and dorzolamide fixed combination. Stewart 2010
Konstas AG, Pikilidou MI, Tsironi S, Mikropoulos D, Kozobolis VP, Sarafidis PA, Lasaridis AN, Nelson LA, Stewart WC. 24-hour intraocular pressure and blood pressure levels with latanoprost/timolol fixed combination versus timolol. Curr Eye Res. 2009;34(5):369-77. [pmid: 19401880]. Other (specify):not FDA approved
Konstas AG, Stewart WC, Stroman GA, Sine CS. Clinical presentation and initial treatment patterns in patients with exfoliation glaucoma versus primary open-angle glaucoma. Ophthalmic Surg Lasers. 97;28(2):111-7. It is not a RCT and has less than 100 patients
Konstas AG, Stewart WC, Topouzis F, Tersis I, Holmes KT, Stangos NT. Brimonidine 0.2% given two or three times daily versus timolol maleate 0.5% in primary open-angle glaucoma. Medical KQ 3 only
Konstas AG, Tsironi S, Vakalis AN, Nasr MB, Nelson LA, Stewart WC. 24-Hour Intraocular Pressure Control Obtained With Evening versus Morning Dosed Travoprost/Timolol Maleate Fixed Combination in Patients With Open-Angle Glaucoma. Meeting abstract
Konstas AG, Tsironi S, Vakalis AN, Nasr MB, Stewart JA, Nelson LA, Stewart WC. Intraocular pressure control over 24 hours using travoprost and timolol fixed combination administered in the morning or evening in primary open-angle and exfoliative glaucoma. Acta Ophthalmol. 2009;87(1):71-6. [pmid: 19178390]. Other (specify):Not a comparison of interest
Kooner KS, Zimmerman TJ. Management of acute elevated intraocular pressure: Part II. Treatment. Ann Ophthalmol. 88 ; 20(3):87-8. No original data (e.g., systematic review, narrative review, editorial, letter)
Korte JM, Kaila T, Saari KM. Systemic bioavailability and cardiopulmonary effects of 0.5% timolol eyedrops. Graefes Arch Clin Exp Ophthalmol. 2002;240(6):430-5. [pmid: 12107508]. No subjects with open-angle glaucoma
Kosmin AS, Wishart PK, Ridges PJ. Long-term intraocular pressure control after cataract extraction with trabeculectomy: phacoemulsification versus extracapsular technique. J Cataract Refract Surg. 98 ;24(2):249-55. It is combined cataract/glaucoma surgery study published before April 2000
Kosmin AS, Wishart PK, Ridges PJ. Silicone versus poly(methyl methacrylate) lenses in combined phacoemulsification and trabeculectomy. J Cataract Refract Surg. 97 ;23(1):97-105. It is combined cataract/glaucoma surgery study published before April 2000
Kotecha A, Spratt A, Bunce C, Garway-Heath DF, Khaw PT, Viswanathan A. Optic disc and visual field changes after trabeculectomy. Invest Ophthalmol Vis Sci. 2009;50(10):4693-9. [pmid: 19474409]. Other (specify):I can’t tell what types of glaucoma the subjects had
Kotecha A, Spratt A, Garway-Heath DF, Khaw PT, Viswanathan AC. MoreFlow Study Group. The Influence of IOP on Structural and Functional Changes Following Trabeculectomy- Results From the MoreFlow Study. Meeting abstract
Kotecha A, White E, Schlottmann PG, Garway-Heath DF. Intraocular pressure measurement precision with the Goldmann applanation, dynamic contour, and ocular response analyzer tonometers. Systematic review
Kothe AC, Ripp KM, Sharma V, Von Tress MS, DeSantis L, Bergamini MVW, Robertson SM. IOP-Lowering Efficacy and Safety of Travoprost DID vs. Concomitantly Dosed Travoprost and Brimonidine BID vs. Placebo BID in Patients with Open-Angle Glaucoma or Ocula Hypertension. Meeting abstract
Kothy P, Toth M, Hollo G. Influence of selective laser trabeculoplasty on 24-hour diurnal intraocular pressure fluctuation in primary open-angle glaucoma: a pilot study. Ophthalmic Surg Lasers Imaging. 2010;41(3):342-7. [pmid: 20507019]. It is not a RCT and has less than 100 patients
Kountouras J, Zavos C, Chatzopoulos D. Ocular and systemic side effects of latanoprost. Eye (Lond). 2005;19(7):804-5. author reply 805–6. [pmid: 15359267]. No original data (e.g., systematic review, narrative review, editorial, letter)
Kovacic Z, Ivanisevic M, Stanic R, Bojic L, Capkun V, Rogosica V. Additive therapy with carboanhydrase inhibitors for open angle glaucoma previously treated with timolol 0.5% drops. Foreign language
Koz OG, Ozsoy A, Yarangumeli A, Kose SK, Kural G. Comparison of the effects of travoprost, latanoprost and bimatoprost on ocular circulation: a 6-month clinical trial. Medical KQ 3 or KQ 3 and KQ 6 only
Kozobolis VP, Christodoulakis EV, Tzanakis N, Zacharopoulos I, Pallikaris IG. Primary deep sclerectomy versus primary deep sclerectomy with the use of mitomycin C in primary open-angle glaucoma. Cheng 2009
Kozobolis VP, Konstas AGP, Makridaki I, Efremova R, Stewart WC. 24-Hour Intraocular Pressure Evaluation of the Dorzolamide/Timolol Maleate Fixed Combination versus Latanoprost. Meeting abstract
Kozuchowska I, Wolska-Borowska E. Evaluation of the results of treatment of glaucoma with timolol. Foreign language
Krasnov MM, Naumidi LP. Contact transscleral laser cyclocoagulation in glaucoma. Ann Ophthalmol. 90 ;22(9):354-8. It is not a RCT and has less than 100 patients
Krasnov MM, Akopian VS, Il’ina TS, Kazakova EL. Laser treatment of primary open-angle glaucoma. Randomized comparative studies. Cyclotrabeculospasis and trabeculoplasty. Foreign language
Krasnov MM, Kraus G, Akopian VS, Kazakova EL, Ruzhichkova E. Effectiveness of laser trabeculoplasty in primary open-angle and pseudoexfoliative glaucoma. Foreign language
Krause K, Kuchle HJ, Baumgart M. Comparative studies of pilocarpine gel and pilocarpine eyedrops. Foreign language
Krieglstein GK. Adrenergic therapy of glaucoma. Fortschr Ophthalmol. 88 ;85(2):125-9. [pmid: 1855727]. No original data (e.g., systematic review, narrative review, editorial, letter)
Krieglstein GK. Drug tolerance of glaucomatous eyes to beta-receptor blockers. Ber Zusammenkunft Dtsch Ophthalmol Ges. 78(75):357-60. It is not a RCT and has less than 100 patients
Krieglstein GK. The effect of timolol eye drops on the intraocular pressure in simple glaucoma (author’s transl). Klin Monbl Augenheilkd. 78 ;172(5):677-85. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Krieglstein GK, Fleig H. Nadolol/Timolol: A comparison of two different beta blockers in cronic glaucoma. Foreign language
Krieglstein GK, Novack GD, Voepel E, Schwarzbach G, Lange U, Schunck KP, Lue JC, Glavinos EP. Levobunolol and metipranolol: comparative ocular hypotensive efficacy, safety, and comfort. Unique comparators
Krishnan R, Kumar N, Wishart PK. Viscocanalostomy for refractory glaucoma secondary to intravitreal triamcinolone acetonide injection. Arch Ophthalmol. 2007;125(9):1284-6. [pmid: 17846375]. It is a case series
Krist P, Fric E, Al Marei S, Zapletalova J. Deep perforating trabeculectomy--results after up to six years follow-up. Foreign language
Kristinsson A. Fatal reaction to acetazolamide. Br J Ophthalmol. 67 ; 51(5):348-9. It is a case series
Krivitskii AK, Kozina LV. The late results of the surgical treatment of glaucoma in patients with atherosclerosis and diabetes mellitus. Foreign language
Krohn J, Hove VK. Recurring iris pigment epithelial cyst induced by topical prostaglandin F2 alpha analogues. Arch Ophthalmol. 2008;126(6):867-8. [pmid: 18541857]. It is a case series
Kronfeld PC. The efficacy of combinations of ocular hypotensive drugs. A tonographic approach. Arch Ophthalmol. 67 ;78(2):140-6. Does not address any key questions
Krott R, Diestelhost M, Zollweg M, Krieglstein GK. Dose-response relationship of trans-scleral contact cyclophotocoagulation. Ophthalmologe. 97 ;94(4):273-6. It is a case series
Krug J Jr, Chiavelli M, Borawski G, Devaney M, Epstein D, Berson F, Latina M, Melamed S, Berry I, Evans C, Johnson E, Joyner M, Kittay R, Lindenmeyer A, McGee R, Piva-Bowe D, Smith TJ, Stout K, Way R. The Glaucoma Laser Trial (GLT) and glaucoma laser trial follow-up study: 7. Results. Duplicate
Kruger A, Hille K, Kohlhof K, Spang S, Ruprecht KW. Laser-Flare in combined cataract and glaucoma surgery with and without intra-operative mitomycine application. Meeting abstract
Krupin T, Liebmann JM, Greenfield DS, Ritch R, Gardiner S, Low-Pressure Glaucoma Study Group. A randomized trial of brimonidine versus timolol in preserving visual function: results from the Low-Pressure Glaucoma Treatment Study. Duplicate of 80144
Krupin T. A clinical trial studying neuroprotection in low-pressure glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Krupin T, Liebmann JM, Greenfield DS, Ritch R, Rosenberg LF, Ruderman JM, Yang JW, Gonzales L, Sherwood MB, Cantor LB, Gross RL, Spaeth GL, Katz LJ, Myers JS, Dirks MS, Henry JC, Piltz-Seymour JR, Feitl ME, Grimes SR, Gieser D. The Low-Pressure Glaucoma Treatment Study (LoGTS): Study Design and Baseline Characteristics of Enrolled Patients. Meeting abstract
Krupin T, Liebmann JM, Greenfield DS, Rosenberg LF, Ritch R, Yang JW. The Low-pressure Glaucoma Treatment Study (LoGTS) study design and baseline characteristics of enrolled patients. Baseline LoGTS: use for review update.
Krupin T, Patkin R, Kurata FK, Bishop KI, Keates EU, Kozart DM, Stone RA, Werner EB. Argon laser trabeculoplasty in black and white patients with primary open-angle glaucoma. Ophthalmology. 86 ;93(6):811-6. Other (specify):no harms
Kruse W. Metipranolol--a new beta-blocker. Klin Monbl Augenheilkd. 83 ;182(6):582-4. It is not a RCT and has less than 100 patients
Kruse W. Metipranolol: A new beta-blocker. METIPRANOLOL - EIN NEUER BETAREZEPTORENBLOCKER. Duplicate
Kuang TM, Lin YC, Liu CJ, Hsu WM, Chou CK. Early and late endophthalmitis following trabeculectomy in a Chinese population. Eur J Ophthalmol. 2008;18(1):66-70. [pmid: 18203087]. Data not abstractable
Kubota M, Hara T, Kubota S, Hashimoto T, Tsuru T. Ocular hypotensive effect of brinzolamide after switching from dorzolamide. Foreign language
Kugleev AA, Lebekhov PI, Astakhov SIu. A method of treatment of open-angle glaucoma. Foreign language
Kumar H, Sony P, Gupta V. Profound sweating episodes and latanoprost. Clin Experiment Ophthalmol. 2005;33(6):675. [pmid: 16402972]. It is a case series
Kumar H, Sudan R, Sethi HS, Sony P. Timolol maleate 0.5% versus timolol maleate in gel forming solution 0.5% (Timolol GFS) in open angle glaucoma in India. Preliminary safety and efficacy study. Indian J Ophthalmol. 2002;50(1):21-3. [pmid: 12090082]. It is not a RCT and has less than 100 patients
Kumar RS, Istiantoro VW, Hoh ST, Ho CL, Oen FT, Aung T. Efficacy and safety of a systematic switch from latanoprost to travoprost in patients with glaucoma. J Glaucoma. 2007;16(7):606-9. [pmid: 18091178]. It is not a RCT and has less than 100 patients
Kumar S, Pannu BKS, Sawhney R, Jain R, Sood S. Comparative efficacy of gel-forming and ophthalmic solutions of 0.5% timolol in open-angle glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Kumari R, Badhu BP, Das H. Effectiveness of combination of permanent and releasable scleral flap sutures in trabeculectomy: a randomized clinical trial. Kathmandu Univ Med J (KUMJ). 2006;4(4):419-25. [pmid: 18603947]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Kupin TH, Juzych MS, Shin DH, Khatana AK, Olivier MM. Adjunctive mitomycin C in primary trabeculectomy in phakic eyes. Am J Ophthalmol. 95 ;119(1):30-9. It is not a RCT and has less than 100 patients
Kuroda S, Mizoguchi T, Terauchi H, Nagata M. Advanced nonpenetrating trabeculectomy (advanced NPT) and combined surgery of advanced NPT and phacoemulsification and intraocular lens implantation. Semin Ophthalmol. 2001;16(3):172-6. [pmid: 15513438]. It is not a RCT and has less than 100 patients
Kuroda S, Mizoguchi T, Terauchi H, Nagata M. Trabeculectomy combined with phacoemulsification and intraocular lens implantation. Semin Ophthalmol. 2001;16(3):168-71. [pmid: 15513437]. It is not a RCT and has less than 100 patients
Kurtz S, Mann O. Incidence of hyperemia associated with bimatoprost treatment in naive subjects and in subjects previously treated with latanoprost. Eur J Ophthalmol. 2009;19(3):400-3. [pmid: 19396785]. It is not a RCT and has less than 100 patients
Kurtz S, Shemesh G. The efficacy and safety of once-daily versus once-weekly latanoprost treatment for increased intraocular pressure. Unique comparators
Kurtz S, Ashkenazi I, Melamed S. Major depressive episode secondary to antiglaucoma drugs. Am J Psychiatry. 93 ;150(3):524-5. It is a case series
Kurumety UR, Lundy DC, Heuer DK, Minckler DS, Lee PP, Varma R. COMPARISON OF THE EFFECTIVENESS OF MITOMYCIN C APPLICATION BEFORE VERSUS AFTER TRABECULECTOMY FLAP DISSECTION. Meeting abstract
Kuwayama Y, Itoh N, Kano K, Sudo M, Okumura M, Tsujimoto M, Tokoro T. Comparison of timolol and latanoprost in diurnal variation of ypotensive effect. Meeting abstract
Kuwayama Y, Komemushi S. Tafluprost Multi-center Study Group. Intraocular pressure lowering effect of 0.0015% tafluprost as compared to placebo in patients with normal tension glaucoma: randomized, double-blind, multicenter, phase III study. Foreign language
Laake K. Systemic adverse affects of beta-blocking agents used in local treatment of the eye. Foreign language
Labbe A, Baudouin C. Treatment of glaucoma in patients with dry eye syndrome. Foreign language
Lachkar Y. Non penetrating deep sclerectomy with external trabeculectomy (NPT) vs trabeculectomy: prospsective study. Meeting abstract
Lachkar Y, Leyland M, Bloom P, Migdal C. Trabeculectomy with intraoperative sponge 5-fluorouracil in Afro-Caribbeans. Br J Ophthalmol. 97 ;81(7):555-8. It is not a RCT and has less than 100 patients
Lachkar Y, Migdal C, Dhanjil S. Effect of brimonidine tartrate on ocular hemodynamic measurements. Arch Ophthalmol. 98 ;116(12):1591-4. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Lachkar Y, Neverauskiene J, Jeanteur-Lunel MN, Gracies H, Berkani M, Ecoffet M, Kopel J, Kretz G, Lavat P, Lehrer M, Valtot F, Demailly P. Nonpenetrating deep sclerectomy: a 6-year retrospective study. Eur J Ophthalmol. 2004;14(1):26-36. [pmid: 15005582]. Other (specify):Study design does not match KQ
Lafuma A, Berdeaux G. Costs and effectiveness of travoprost versus a dorzolamide + timolol fixed combination in first-line treatment of glaucoma: analysis conducted on the United Kingdom General Practitioner Research Database (Structured abstract). Current Medical Research and Opinion. 2007;23(12):3009-3016. [pmid: 17958945]. Other (specify):Study design does not match KQ
Lafuma A, Berdeaux G. Costs and persistence of carbonic anhydrase inhibitor versus alpha-2 agonists, associated with beta-blockers, in glaucoma and ocular hypertension: an analysis of the UK-GPRD database. Curr Med Res Opin. 2008;24(5):1519-27. [pmid: 18413015]. OAG can’t be analyzed separately
Lai JSM, Ho PCP. TRABECULECTOMY COMBINED WITH BETA IRRADIATION IN UNCOMPLICATED PRIMARY OPEN ANGLE GLAUCOMA. Meeting abstract
Lai JS, Chua JK, Lam DS. Effect of latanoprost on IOP. J Cataract Refract Surg. 99 ;25(3):304. No original data (e.g., systematic review, narrative review, editorial, letter)
Laibovitz RA, Dubiner HB, Sall KN, Mundorf TK, Katz LJ, Sing K, Shulman DG, Siegel LI, Nussbaum LL, Stewart WC. OCULAR TOLERABILITY AND INTRAOCULAR PRESSURE EFFECTS OF CARTEOLOL AND TIMOLOL IN OLDER WOMEN WITH OCULAR HYPERTENSION OR PRIMARY OPEN ANGLE GLAUCOMA. Meeting abstract
Laibovitz RA, VanDenburgh AM, Felix C, David R, Batoosingh A, Rosenthal A, Cheetham J. Comparison of the ocular hypotensive lipid AGN 192024 with timolol: dosing, efficacy, and safety evaluation of a novel compound for glaucoma management. Arch Ophthalmol. 2001;119(7):994-1000. [pmid: 11448321]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Laibovitz R, Boyle J, Snyder E, Strohmaier K, Adamsons I. Dorzolamide versus pilocarpine as adjunctive therapies to timolol: a comparison of patient preference and impact on daily life. Clin Ther. 96 ; 18(5):821-32. Other (specify):pilo
Laibovitz R, Strahlman ER, Barber BL, Strohmaier KM. Comparison of quality of life and patient preference of dorzolamide and pilocarpine as adjunctive therapy to timolol in the treatment of glaucoma. J Glaucoma. 95 ;4(5):306-13. Other (specify):pilocarpine
Laibovitz R, Zimmerman K, Getson A, Shedden A, Laurence J, Adamsons I. COMPARISON OF THE EFFICACY AND TOLERABILITY OF PRESERVATIVEFREE 2.0% DORZOLAMIDE/0.5% TIMOLOL (PF DORZ/TIM) AND 2.0% DORZOLAMIDE/0.5% TIMOLOL (DORZ/TIM). Meeting abstract
Lamba PA, Pandey PK, Raina UK, Krishna V. Short-term results of initial trabeculectomy with intraoperative or postoperative 5-fluorouracil for primary glaucomas. Indian J Ophthalmol. 96 ;44(3):157-60. OAG can’t be analyzed separately
Lamba PA, Pandey PK, Raina UK, Krishna V. Short-term results of initial trabeculectomy with intraoperative or postoperative 5-fluorouracil for primary glaucomas. Indian J Ophthalmol. 97 ;45(3):173-6. Data not abstractable
Lamberti G, Pignalosa B, Fusco R, Pignalosa G, Di Govanni A, Sebastiani A. Short-term clinical trial evaluating the efficacy of the combination of apraclonidine 0.5% solution and betaxolol 0.25% suspension. Acta Ophthalmol Scand Suppl. 97(224):20-1. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Lamping KA, Belkin J. 5-Fluorouracil (5-FU) and Mitomycin-C in Pseudophakic Patients. Meeting abstract
Lamping KA, Belkin JK. 5-Fluorouracil and mitomycin C in pseudophakic patients. Ophthalmology. 95 ;102(1):70-5. Data not abstractable
Lamping KA, Bellows AR, Hutchinson BT, Afran SI. Long-term evaluation of initial filtration surgery. OPHTHALMOLOGY. 86 ;93(1):91-101. Does not address any key questions
Landa G, Pollack A, Rachmiel R, Bukelman A, Marcovich A, Zalish M. Results of combined phacoemulsification and trabeculectomy with mitomycin C in pseudoexfoliation versus non-pseudoexfoliation glaucoma. Graefes Arch Clin Exp Ophthalmol. 2005;243(12):1236-40. [pmid: 16003518]. Other (specify):comparison of 2 case series
Langerhorst CT, de Clercq B, van den Berg TJ. Visual field behavior after intra-ocular surgery in glaucoma patients with advanced defects. Doc Ophthalmol. 90; 75(3–4):281-9. It is not a RCT and has less than 100 patients
Langham ME, Carenini BB, Brogliatti A, Corenini AB, Sibour G. DIFFERENCES IN THE ACTIONS OF TIMOLOL AND BETAXOLOL ON VISION AND OCULAR PULSATILE BLOOD FLOW IN GLAUCOMA. Meeting abstract
Lankaranian D, Patel R, Moster MR, Wizov S, Alvim HS, Lopes JF, Tong M, Spaeth GL. A Randomized Prospective Clinical Trial of the Efficacy of Cyclosporine Ophthalmic Emulsion 0.05% Following Trabeculectomy With Antimetabolite. Meeting abstract
Lankaranian D, Reis R, Henderer JD, Choe S, Moster MR. Comparison of single thickness and double thickness processed pericardium patch graft in glaucoma drainage device surgery: a single surgeon comparison of outcome. J Glaucoma. 2008;17(1):48-51. [pmid: 18303385]. It is a case series
Larsson LI, Svensson B, Soderhlm G, Karlsson P. A comparison of the intraocular pressure reducing effect of selective laser trabeculoplasty and argon laser trabeculoplasty in patients with glaucoma. Meeting abstract
Larsson LI. Effect on intraocular pressure during 24 hours after repeated administration of the fixed combination of latanoprost 0.005% and timolol 0.5% in patients with ocular hypertension. J Glaucoma. 2001;10(2):109-14. [pmid: 11316092]. Other (specify):fixed combination
Larsson LI. The effect on diurnal intraocular pressure of the fixed combination of latanoprost 0.005% and timolol 0.5% in patients with ocular hypertension. Acta Ophthalmol Scand. 2001;79(2):125-8. [pmid: 11284748]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Larsson LI, Diestelhorst M. European-Canadian Latanoprost Fixed Combination Study Group. A 12-Week, Randomized, Double-Masked Multicenter Study of the Fixed Combination Latanoprost and Timolol in the Evening vs. the Individual Components. Meeting abstract
Lass JH, Simpson CV, Eriksson G. A Double-Masked, Randomized 1-Year Study Comparing the Corneal Effects of Latanoprost and Timolol. Meeting abstract
Lass JH, Khosrof SA, Laurence JK, Horwitz B, Ghosh K, Adamsons I. A double-masked, randomized, 1-year study comparing the corneal effects of dorzolamide, timolol, and betaxolol. Arch Ophthalmol. 98 ;116(8):1003-1010. Does not address any key questions
Lass JH, Khosrof SA, Laurence JK, Horwitz B, Ghosh K, Adamsons I. A double-masked, randomized, 1-year study comparing the corneal effects of dorzolamide, timolol, and betaxolol. Dorzolamide Corneal Effects Study Group. Arch Ophthalmol. 98 ;116(8):1003-10. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Lass JH, Khosrof S, Laurence JK, Ghosh K, Adamson I. The Dorzolamide Study Group. CORNEAL SAFETY OF DORZOLAMIDE, TIMOLOL, AND BETAXOLOL AFTER 1 YEAR OF THERAPY. Meeting abstract
Laster SF, Martin JL, Fleming JB. The effect of a medication alarm device on patient compliance with topical pilocarpine. J Am Optom Assoc. 96 ;67(11):654-8. Does not address any key questions
Lau G, Young S, Lehrer R. EFFICACY OF TRABECULECTOMY WITH AND WITHOUT THE EX-PRESS SHUNT. Duplicate
Lauande R, Costa VP, Rocha VA, Vidal R, Ribeiro MP, Antunes A, Velanes A. Travoprost 0,004% and Timolol Maleate 0.5% in Alternate Days Compared to Standard Monotherapy: Study of Intraocular Pressure-efficiency of a New Therapy Modality. Meeting abstract
Laube T, Ritters B, Selbach M, Hudde T. Clinical experiences and results of application of mitomycin C in trabeculectomy. Klin Monbl Augenheilkd. 2003;220(9):618-24. [pmid: 14533060]. It is not a RCT and has less than 100 patients
Laube T, Ritters B, Selbach M, Hudde T. Clinical Experiences and Results of Application of Mitomycin C in Trabeculectomy. Klinische Erfahrungen und Ergebnisse beim Einsatz von Mitomycin C bei der Trabekulektomie. Duplicate
Laurence J, Holder D, Vogel R, Gross RL, Haik BG, Karp DW, Koby MM, Zimmerman TJ. A double-masked, placebo-controlled evaluation of timolol in a gel vehicle. J Glaucoma. 93 ;2(3):177-82. No subjects with open-angle glaucoma
Lavado Landeo Lincoln, Paredes Portilla M nica. TrabeculoplastÆa con lbser diodo. Foreign language
Law SK. A modified technique of Ahmed glaucoma valve implantation with adjunctive use of antifibrotic agents. Am J Ophthalmol. 2008;146(2):156-8. [pmid: 18656583]. No original data (e.g., systematic review, narrative review, editorial, letter)
Law SK, Modjtahedi SP, Mansury A, Caprioli J. Intermediate-term comparison of trabeculectomy with intraoperative mitomycin-C between Asian American and Caucasian glaucoma patients: a case-controlled comparison. Eye (Lond). 2007;21(1):71-8. [pmid: 16227981]. It is a case series
Law SK, Nguyen AM, Coleman AL, Caprioli J. Severe loss of central vision in patients with advanced glaucoma undergoing trabeculectomy. Arch Ophthalmol. 2007;125(8):1044-50. [pmid: 17698750]. It is a case series
Law SK, Shih K, Tran DH, Coleman AL, Caprioli J. Long-term outcomes of repeat vs initial trabeculectomy in open-angle glaucoma. Am J Ophthalmol. 2009;148(5):685-695. e1. [pmid: 19596220]. It is a case series
Law SK, Song BJ, Yu F, Kurbanyan K, Yang TA, Caprioli J. Hemorrhagic complications from glaucoma surgery in patients on anticoagulation therapy or antiplatelet therapy. Am J Ophthalmol. 2008;145(4):736-746. [pmid: 18255047]. OAG can’t be analyzed separately
Lazaridou MN, Montgomery DM, Ho WO, Jaberoo D. Changes in intraocular pressure following a switch from latanoprost monotherapy to latanoprost/timolol fixed combination therapy in patients with primary open-angle glaucoma or ocular hypertension: results from a clinical practice database. Curr Med Res Opin. 2008;24(10):2725-8. [pmid: 18713491]. It is not a RCT and has less than 100 patients
Lazaro Garcia C, Castillo Gomez A, Garcia Feijoo J, Macias Benitez JM, Garcia Sanchez J. Study of the corneal endothelium after glaucoma surgery. Arch Soc Esp Oftalmol. 2000;75(2):75-80. [pmid: 11151123]. Does not address any key questions
Lazaro C, Benitez-del-Castillo JM, Castillo A, Garcia-Feijoo J, Macias JM, Garcia-Sanchez J. Lens fluorophotometry after trabeculectomy in primary open-angle glaucoma. Ophthalmology. 2002;109(1):76-9. [pmid: 11772583]. It is not a RCT and has less than 100 patients
Lazaro C, Garcia-Feijoo J, Castillo A, Perea J, Martinez-Casa JM, Garcia-Sanchez J. Impact of intraocular pressure after filtration surgery on visual field progression in primary open-angle glaucoma. Eur J Ophthalmol. 2007;17(3):357-62. [pmid: 17534816]. It is a case series
Lazzaroni F, Fanti MR, Fanti A, Tosti G. Treatment of glaucoma and visual field diminution. Ophtalmologie. 88 ;2(5):427-9. Data not abstractable
Le Jeunne CL, Hugues FC, Dufier JL, Munera Y, Bringer L. Bronchial and cardiovascular effects of ocular topical B-antagonists in asthmatic subjects: comparison of timolol, carteolol, and metipranolol. J Clin Pharmacol. 89 ;29(2):97-101. No subjects with open-angle glaucoma
Le Rebeller MJ. Our experience with timolol. Foreign language
Le HH, Chang MR, Cheng Q, Lee DA, Hartenbaum D. The effectiveness and safety of dorzolamide 2% in addition to multiple topical antiglaucoma medications. J Ocul Pharmacol Ther. 99 ;15(4):305-12. Other (specify):No control
LeBlanc RP, Krip G. Timolol. Canadian multicenter study. Ophthalmology. 81 ;88(3):224-8. Does not address any key questions
LeBlanc RP. Twelve-month results of an ongoing randomized trial comparing brimonidine tartrate 0.2% and timolol 0.5% Given twice daily in patients with glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
LeBlanc RP. Twelve-month results of an ongoing randomized trial comparing brimonidine tartrate 0.2% and timolol 0.5% given twice daily in patients with glaucoma or ocular hypertension. Brimonidine Study Group 2. Medical KQ 3 or KQ 3 and KQ 6 only
LeBlanc RP, Saheb NE, Krip G. Timolol: long-term Canadian multicentre study. Can J Ophthalmol. 85 ;20(4):128-30. Other (specify):No control
Lee DA, Gornbein JA. Effectiveness and safety of brimonidine as adjunctive therapy for patients with elevated intraocular pressure in a large, open-label community trial. Unique comparators
Lee DA. Efficacy of brimonidine as replacement therapy in patients with open-angle glaucoma or ocular hypertension. Unique comparators
Lee DA, Gornbein J, Abrams C. The effectiveness and safety of brimonidine as mono-, combination, or replacement therapy for patients with primary open-angle glaucoma or ocular hypertension: a post hoc analysis of an open-label community trial. Glaucoma Trial Study Group. J Ocul Pharmacol Ther. 2000;16(1):3-18. [pmid: 10673126]. OAG can’t be analyzed separately
Lee DA, Gornbein J, Abrams C. The effectiveness and safety of brimonidine as mono-, combination, or replacement therapy for patients with primary open-angle glaucoma or ocular hypertension: A post hoc analysis of an open-label community trial. J Ocul Pharmacol Ther. 2000;16(1):3-18. [pmid: 10673126]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Lee D. Alphagan Glaucoma Trial Study Group. THE EFFICACY AND SAFETY OF ALPHAGAN® (Brimonidine) FOR SUBJECTS WITH PRIMARY OPEN-ANGLE HYPERTENSION OR OCULAR HYPERTENSION. Meeting abstract
Lee GC, Katz LJ, Molineaux J, Fontanarosa J, Steinmann WC. Comparison of Intraocular Pressure Lowering Efficacy of Fixed Combination Timolol-Dorzolamide versus Timolol Plus Latanoprost. Meeting abstract
Lee JJ, Park KH, Youn DH. The effect of low-and high-dose adjunctive mitomycin C in trabeculectomy. Korean J Ophthalmol. 96 ; 10(1):42-7. OAG can’t be analyzed separately
Lee JW, Lai JS, Yick DW, Tse RK. Retrospective case series on the long-term visual and intraocular pressure outcomes of phacomorphic glaucoma. Eye (Lond). 2010;24(11):1675-80. [pmid: 20689570]. No subjects with open-angle glaucoma
Lee PF, Hsu CT, Lin AY, Shihab ZM. Argon laser trabeculoplasty in primary open angle glaucoma: long-term clinical results and its future. Yan Ke Xue Bao. 86 ;2(2):90-4. It is a case series
Lee PP, Walt JG, Chiang TH, Guckian A, Keener J. A gap analysis approach to assess patient persistence with glaucoma medication. Am J Ophthalmol. 2007;144(4):520-4. [pmid: 17692273]. Other (specify):study design does not match KQ (KQ2)
Lee PW, Doyle A, Stewart JA, Kristoffersen CJ, Stewart WC. Meta-analysis of timolol on diurnal and nighttime intraocular pressure and blood pressure. Systematic review
Lee P, Shen Y, Eberle M. The long-acting Ocusert-pilocarpine system in the management of glaucoma. Invest Ophthalmol. 75 ;14(1):43-6. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Lee SJ, Paranhos A, Shields MB. Does titration of mitomycin C as an adjunct to trabeculectomy significantly influence the intraocular pressure outcome. Clin Ophthalmol. 2009;3:81-7. [pmid: 19668548]. It is a case series
Lee YG, Hong YJ, Kim CY, Ho KK, Kim DH. The Effect of Mitomycin-C (MMC) on Primary Trabeculectomy: Comparative Study of the Same Person. Meeting abstract
Leibovici M. Iatrogenic pathogenesis of anti-glaucoma medical therapy. Foreign language
LemmMaraini G, Gandolfi SA, Rossetti L, Cimino L, Orzalesi N. SUBSTITUTION WITH LATANOPROST COMPARED WITH ADDITION OF LATANOPROST TO MAXIMALLY TOLERATED MEDICAL THERAPY IN UNCONTROLLED HUMAN GLAUCOMA: PROSPECTIVE, RANDOMIZED, 3 MONTH-CLINICAL TRIAL. Meeting abstract
Lemon LC, Shin DH, Kim C, Bendel RE, Hughes BA, Juzych MS. Limbus-based vs fornix-based conjunctival flap in combined glaucoma and cataract surgery with adjunctive mitomycin C. Am J Ophthalmol. 98 ;125(3):340-5. [pmid: 6540992]. It is combined cataract/glaucoma surgery study published before April 2000
Lemon LC, Shin DH, Kim C, Juzych MS, Hughes BA, Tinoosh F. LIMBUS- VERSUS FORNIX-BASED CONJUNCTIVAL FLAP IN PRIMARY GLAUCOMA TRIPLE PROCEDURE WITH ADJUNCTIVE MITOMYCIN-C: INTERMEDIATE-TERM FOLLOW-UP. Meeting abstract
Lemon LC, Shin DH, Reed SY, Birt CM, Hughes BA, Gianarelli TE, Khatana AK. COMPARATIVE STUDY OF FORNIX- VS LIMBUS-BASED CONJUNCTIVAL FLAP IN GLAUCOMA TRIPLE PROCEDURE WITH ADJUNCTIVE SUBCONJUNVITAL MITOMYCIN C. Meeting abstract
Lemon LC, Shin DH, Song MS, Lee JH, Bendel RE, Juzych MS, Hughes BA. Comparative study of silicone versus acrylic foldable lens implantation in primary glaucoma triple procedure. Ophthalmology. 97 ;104(10):1708-13. It is combined cataract/glaucoma surgery study published before April 2000
Leonard TJ. Iatrogenic factors in the management of glaucoma. Br J Clin Pract. 83; 37(11–12):365-6. No original data (e.g., systematic review, narrative review, editorial, letter)
Leroy C, Collignon-Brach J. Primary open-angle glaucoma. Effects of an eyedrop combining timolol and pilocarpine on the ocular pressure. Foreign language
Lesk MR, Koulis T, Sampalis F, Sampalis JS, Bastien NR. Effectiveness and safety of dorzolamide-timolol alone or combined with latanoprost in open-angle glaucoma or ocular hypertension. Unique comparators
Leske MC, Heijl A, Hussein M, Bengtsson B, Hyman L, Komaroff E. Factors for glaucoma progression and the effect of treatment: the early manifest glaucoma trial. EMGT
Leske MC, Heijl A, Hyman L, Bengtsson B, Dong L, Yang Z. Predictors of long-term progression in the early manifest glaucoma trial. Ophthalmology. 2007;114(11):1965-72. [pmid: 17628686]. Does not address any key questions
Leske MC, Hyman L, Hussein M, Heijl A, Bengtsson B. Comparison of glaucomatous progression between untreated patients with normal-tension glaucoma and patients with therapeutically reduced intraocular pressures. The effectiveness of intraocular pressure reduction in the treatment of normal-tension glaucoma. Am J Ophthalmol. 99 ; 127(5):625-6. No original data (e.g., systematic review, narrative review, editorial, letter)
Leskea MC, Heijl A, Hyman L, Bengtsson B, Komaroff E. Factors for progression and glaucoma treatment: the Early Manifest Glaucoma Trial. EMGT-Rolim de Moura 2009 and Maier 2005
Lesure P, Feicht B, Lippa EA, Sirbat D, Hofmann H, Strohmaier K, Brunner-Ferber F, George JL, von Denffer H. MK-507: ENHANCEMENT OF BID ACTIVITY OF A TOPICAL CAI BY FORMULATION IN A GELRITETM SOLUTION. Meeting abstract
Leszczynski R, Gierek-Ciaciura S, Forminska-Kapuscik M, Mrukwa-Kominek E, Rokita-Wala I. Nonpenetrating very deep sclerectomy with reticulated hyaluronic acid implant in glaucoma treatment. Med Sci Monit. 2008;14(2):CR86-89. [pmid: 18227766]. OAG can’t be analyzed separately
Leuenberger PM. Trabeculectomy and trabeculotomy (author’s transl). Foreign language
Levene RZ. Central visual field, visual acuity, and sudden visual loss after glaucoma surgery. Ophthalmic Surg. 92 ;23(6):388-94. It is not a RCT and has less than 100 patients
Levene RZ. Uniocular miotic therapy. Trans Sect Ophthalmol Am Acad Ophthalmol Otolaryngol. 75 ;79(2):OP376-80. It is not a RCT and has less than 100 patients
Levin ML. Phacoemulsification, foldable IOL, Holmium laser sclerostomy, and 5-FU. Ophthalmic Surg. 92 ;23(8):566. No original data (e.g., systematic review, narrative review, editorial, letter)
Levobunolol. A beta-adrenoceptor antagonist effective in the long-term treatment of glaucoma. The Levobunolol Study Group (Appended). Medical KQ 3 or KQ 3 and KQ 6 only Medical KQ 3 or KQ 3 and KQ 6 only
Levobunolol. A four-year study of efficacy and safety in glaucoma treatment. The Levobunolol Study Group. Medical KQ 3 or KQ 3 and KQ 6 only Medical KQ 3 or KQ 3 and KQ 6 only
Levy NS, Alsbury C, TIMOLOL-IN-GELRITE ONCE, DAILY IN. GLAUCOMA. Meeting abstract
Lewis RA, Gross RL, Sall KN, Schiffman RM, Liu CC, Batoosingh AL. Ganfort Investigators Group II. The safety and efficacy of bimatoprost/timolol fixed combination: a 1-year double-masked, randomized parallel comparison to its individual components in patients with glaucoma or ocular hypertension. Journal of glaucoma. 2010;19(6):424-6. [pmid: 19855289]. Other (specify):Not a medication available here
Lewis RA. Comparative Safety and Ocular Hypotensive Efficacy of Brimonidine Tartrate 0.2% and Timolol Maleate 0.5% in Patients with Glaucoma or Ocular Hypertension: 12-month Results from an Ongoing Study. Meeting abstract
Lewis RA, Gross RL, Sall KN, Schiffman RM, Liu CC, Batoosingh AL. The safety and efficacy of bimatoprost/timolol fixed combination: a 1-year double-masked, randomized parallel comparison to its individual components in patients with glaucoma or ocular hypertension. J Glaucoma. 2010;19(6):424-6. [pmid: 19855289]. Other (specify):not FDA approved, Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Lewis RA, Katz GJ, Weiss MJ, Landry TA, Dickerson JE, James JE, Hua SY, Sullivan EK, Montgomery DB, Wells DT, Bergamini MV. Travoprost 0.004% with and without benzalkonium chloride: a comparison of safety and efficacy. Unique comparators
Lewis RA, Schoenwald RD, Barfknecht CF, Phelps CD. Aminozolamide gel. A trial of a topical carbonic anhydrase inhibitor in ocular hypertension. Arch Ophthalmol. 86 ;104(6):842-4. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Lewis RA, von Wolff K, Tetz M, Koerber N, Kearney JR, Shingleton BJ, Samuelson TW. Canaloplasty: circumferential viscodilation and tensioning of Schlemm canal using a flexible microcatheter for the treatment of open-angle glaucoma in adults: two-year interim clinical study results. J Cataract Refract Surg. 2009;35(5):814-24. [pmid: 19393879]. Other (specify):Study design does not match KQ
Lewis RA, von Wolff K, Tetz M, Koerber N, Kearney JR, Shingleton BJ, Samuelson TW. Canaloplasty: Three-year results of circumferential viscodilation and tensioning of Schlemm canal using a microcatheter to treat open-angle glaucoma. J Cataract Refract Surg. 2011;3:682-90. [pmid: 21420593]. Other (specify):Harms not analyzed separately for the two interventions
Lewis RA, von Wolff K, Tetz M, Korber N, Kearney JR, Shingleton B, Samuelson TW. Canaloplasty: circumferential viscodilation and tensioning of Schlemm’s canal using a flexible microcatheter for the treatment of open-angle glaucoma in adults: interim clinical study analysis. J Cataract Refract Surg. 2007;33(7):1217-26. [pmid: 17586378]. Other (specify):Study design does not match KQ
Lewis RA, Weiss MJ, Landry TA, Dickerson JE Jr, James JE, Hua SY, Sullivan EK, Montgomery DB, Wells DT, Bergamini MVW. Travoprost 0.004% With and Without Benzalkonium Chloride: A Comparison of Safety and Efficacy. Meeting abstract
Leydhecker W, Krieglstein GK. The effect of low concentrations of pilocarpine with phenylephrine on intraocular pressure in glaucoma. Foreign language
Leydhecker W, Krieglstein GK. The effect of low concentrations of pilocarpine with phenylephrine on intraocular pressure in glaucoma. DIE WIRKUNG SCHWACHER KONZENTRATIONEN VON PILOKARPIN MIT PHENYLEPHRIN AUF DEN INTRAOKULAREN DRUCK BEI GLAUKOM. EINE DOPPELBLIND-CROSS-OVER STUDIE. Duplicate
Leyland M, Bloom P, Zinicola E, McAlister J, Rassam S, Migdal C. Single intraoperative application of 5-Fluorouracil versus placebo in low-risk trabeculectomy surgery: a randomized trial. J Glaucoma. 2001;10(6):452-7. [pmid: 11740214]. OAG can’t be analyzed separately
Li WJ, Ding YL, Zhu F, Li H. Comparison of two different conjunctival incisions of combined trabeculectomy. Foreign language
Lichter PR, Janz NK, Musch DC, Gillespie B, Guire KE, Wren PA, Mills RP. The collaborative initial glaucoma treatment study (cigts) interim outcomes report with up to 5 years of follow-up. Meeting abstract
Lichter PR, Musch DC, Gillespie BW, Guire KE, Janz NK, Wren PA, Mills RP. Interim clinical outcomes in the Collaborative Initial Glaucoma Treatment Study comparing initial treatment randomized to medications or surgery. CIGTS--part of 639 now.
Lichter PR, Musch DC, Gillespie BW, Niziol LN. the CIGTS Study Group. Trabeculectomy as Initial Treatment for OAG Patients with Substantial VF Defects. Meeting abstract
Lichter PR, Musch DC, Gillespie B, Niziol LM. CIGTS Study Group. Initial Surgery Favorable for Patients With Advanced Visual Field Loss in the Collaborative Initial Glaucoma Treatment Study (CIGTS). Meeting abstract
Lichter PR, Musch DC, Guire KM, Gillespie B. CIGTS Study Group. Risks and Benefits of Intraoperative 5-fluorouracil in the Collaborative Initial Glaucoma Treatment Study (CIGTS). Meeting abstract
Lichter PR, Musch DC, Medzihradsky F, Standardi CL. Intraocular pressure effects of carbonic anhydrase inhibitors in primary open-angle glaucoma. Am J Ophthalmol. 89 ;107(1):11-7. [pmid: 7356775]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Lichter PR, Newman LP, Wheeler NC, Beall OV. Patient tolerance to carbonic anhydrase inhibitors. Unique comparators
Liebmann JM, Ritch R, Marmor M, Nunez J, Wolner B. Initial 5-fluorouracil trabeculectomy in uncomplicated glaucoma. Ophthalmology. 91 ;98(7):1036-41. Other (specify):Study design does not match KQ (KQ3)
Lienert F, Busse H. One year’s experience with pilocarpin-ocusert in the therapy of glaucoma (author’s transl). Klin Monbl Augenheilkd. 75 ;167(6):870-1. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Lima FE, Magacho L, Guimaraes N, Avila M, Susanna R. A Prospective, Randomized, Comparative Study between Endoscopic Cyclophotocoagulation and the Ahmed Drainage Implant in Refractory Glaucoma. Meeting abstract
Lima MC, Paranhos A Jr, Salim S, Honkanen R, Devgan L, Wand M, Gaudio AR, Shields MB. Visually significant cystoid macular edema in pseudophakic and aphakic patients with glaucoma receiving latanoprost. J Glaucoma. 2000;9(4):317-21. [pmid: 10958605]. Does not address any key questions
Lima Vera Christina Waller de, Mello Paulo Augusto de Arruda, Prata Junior JoPo Antonio. CiclofotocoagulagPo com laser diodo em glaucoma refratbrio, resultado a longo prazo. Foreign language
Lin JC, Samuel F, Katz LJ, Spaeth GL, Hoop J, Cantor LB. The effect of topical glaucoma medications evaluated by perimetry. Br J Ophthalmol. 2003;87(6):792. No original data (e.g., systematic review, narrative review, editorial, letter)
Lin LL, Galin MA, Obstbaum SA, Katz I. Longterm timolol therapy. Surv Ophthalmol. 79 ;23(6):377-80. Does not address any key questions
Lin YP, Zurakowski D, Ayyala RS. Surgical outcomes of traditional limbal-based versus fornix-based trabeculectomy with corneal valve. Ophthalmic Surg Lasers Imaging. 2007;38(6):471-7. [pmid: 18050809]. It is not a RCT and has less than 100 patients
Linares Mata T, Pardo Sanchez J, de la Cuadra Oyanguren J. Contact dermatitis caused by allergy to dorzolamide. Contact Dermatitis. 2005;52(2):111-2. [pmid: 15725294]. It is a case series
Linden C, Alm A. Latanoprost and physostigmine have mostly additive ocular hypotensive effects in human eyes. Arch Ophthalmol. 97 ; 115(7):857-61. No subjects with open-angle glaucoma
Lindsay CL, Stewart JA, Day DG, Holmes KT, Stewart WC. THE EFFECT OF TIMOLOL MALEATE 0.5% GEL AND TIMOLOL MALEATE 0.5% SOLUTION TWICE DAILY VERSUS PLACEBO ON PULMONARY FUNCTION IN OLDER PRIMARY OPEN-ANGLE GLAUCOMA OR OCULAR HYPERTENSIVE PATIENTS. Meeting abstract
Lindstrom EE, Tredici TJ, Martin BG. Effects of topical ophthalmic 2 percent pilocarpine on visual performance of normal subjects. Aerosp Med. 68 ;39(11):1236-40. No subjects with open-angle glaucoma
Lippa EA, Aasved H, Airaksinen PJ, Alm A, Bertelsen T, Calissendorff B, Dithmer O, Eriksson LO, Gustad L, Hovding G, et al. Multiple-dose, dose-response relationship for the topical carbonic anhydrase inhibitor MK-927. Arch Ophthalmol. 91 ;109(1):46-9. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Lippa EA, Carlson LE, Ehinger B, Eriksson LO, Finnstrom K, Holmin C, Nilsson SE, Nyman K, Raitta C, Ringvold A, et al. Dose response and duration of action of dorzolamide, a topical carbonic anhydrase inhibitor. Medical KQ 3 or KQ 3 and KQ 6 only
Lippa EA, Clineschmidt CM, Tipping RW, Strohmaier KM. DORZOLAMIDE HYDROCHLORIDE: SIX-WEEK, DOSE-RESPONSE STUDY OF AN ACTIVE TOPICAL CARBONIC ANHYDRASE INHIBITOR. Meeting abstract
Lippa E, Sherwood M, Laibovitz R, Miller E, McMahon C, Clineschmidt C, Caprioli J. MK-417 VS. TIMOLOL: COMPARATIVE ACTIVITY. Meeting abstract
Littmann L, Kempler P, Rohla M, Fenyvesi T. Severe atrioventricular block caused by pilocarpine eyedrops. Foreign language
Liu CJ, Ko YC, Cheng CY, Chou JCK, Hsu WM, Liu JH. Changes in intraocular pressure and hemodynamic parameters after brimonidine or latanoprost in progressive normal-tension glaucoma. Meeting abstract
Liu CJL, Chou JCK, Hsu W-M, Liu J-H. Effects of latanoprost 50 (mu)g/ml on Chinese patients with primary open- angle glaucoma and ocular hypertension. Foreign language
Liu CJ, Chou JC, Hsu WM, Liu JH. Effects of latanoprost 50 micrograms/ml on Chinese patients with primary open-angle glaucoma and ocular hypertension. Zhonghua Yi Xue Za Zhi (Taipei). 99 ;62(10):703-9. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Liu HN, Chen XL, Li X, Nie QZ, Zhu Y. Efficacy and tolerability of one-site versus two-site phacotrabeculectomy: a meta-analysis of randomized controlled clinical trials. Systematic review
Liu JH, Kripke DF, Weinreb RN. Comparison of the nocturnal effects of once-daily timolol and latanoprost on intraocular pressure. Am J Ophthalmol. 2004;138(3):389-95. [pmid: 15364220]. It is a case series
Liu JH, Medeiros FA, Slight JR, Weinreb RN. Comparing diurnal and nocturnal effects of brinzolamide and timolol on intraocular pressure in patients receiving latanoprost monotherapy. Unique comparators
Liu Y, Birt CM. Argon Versus Selective Laser Trabeculoplasty in Younger Patients: 2-year Results. J Glaucoma. 2011. OAG can’t be analyzed separately
Liu Y, Sponsel WE, Paris GR. Nonpenetrating deep sclerectomy (npds) with mmc versus trabeculectomy with mmc: comparison of efficacy and perioperative complications. Meeting abstract
Lloyd MA, Baerveldt G, Fellenbaum PS, Sidoti PA, Minckler DS, Martone JF, LaBree L, Heuer DK. Intermediate-term results of a randomized clinical trial of the 350- versus the 500-mm2 Baerveldt implant. Ophthalmology. 94 ;101(8):1456-63. discussion 1463–4. Data not abstractable
Lobstein A, Flament J. Residual effect of timoptol in ocular hypertension. Foreign language
Lochhead J, Casson RJ, Salmon JF. Long term effect on intraocular pressure of phacotrabeculectomy compared to trabeculectomy. Br J Ophthalmol. 2003;87(7):850-2. [pmid: 12812883]. Other (specify):Study design does not match KQ
Lochman J, Novak J, Rozsival P. Trabeculectomy - Long term results. Trabekulektomie - Dlouhodobe vysledky. Foreign language
Lockey SD Sr. Bronchospasm precipitated by ophthalmic instillations of timolol. Ann Allergy. 81 ;46(5):267. It is a case series
Loewenstein A, Lazar M. Patient selection in the Timpilo Study. Arch Ophthalmol. 93 ;111(10):1313. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Lofors KT, Hovding G, Viksmoen L, Aasved H, Bergaust B, Bulie T. Twelve-hour IOP control obtained by a single dose of timolol/pilocarpine combination eye drops. Acta Ophthalmol (Copenh). 90 ;68(3):323-6. Other (specify):Not inc drug
Loftfield K, Ball SF. S-FLUOROURACIL (5-FU) IN PRIMARY TRABECULECTOMY: A RANDOMIZED TRIAL. Meeting abstract
Long DA, Johns GE, Mullen RS, Bowe RG, Alexander D, Epstein DL, Weiss MJ, Masi RJ, Charap AD, Eto CY, et al. Levobunolol and betaxolol. A double-masked controlled comparison of efficacy and safety in patients with elevated intraocular pressure. Unique comparators
Long D, Zimmerman T, Spaeth G, Novack G, Burke PJ, Duzman E. Minimum concentration of levobunolol required to control intraocular pressure in patients with primary open-angle glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Lopes JF, Moster MR, Wilson RP, Altangerel U, Alvim HS, Tong MG, Fontanarosa J, Steinmann WC. Subconjunctival sodium hyaluronate 2.3% in trabeculectomy: a prospective randomized clinical trial. Ophthalmology. 2006;113(5):756-60. [pmid: 16650669]. Other (specify):Not a comparison of interest
Lotti R, Traverso CE, Murialdo U, Frau B, Calabria GA, Zingirian M. Argon laser trabeculoplasty: long-term results. Ophthalmic Surg. 95 ;26(2):127-9. Other (specify):Study design does not match KQ
Low M, Buhler C, Mester U. Comparison of Healon, Healon GV, and Healon 5 in viscotrabeculectomy. Ophthalmologe. 2003;100(7):539-44. [pmid: 12920554]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Lteif Y, Berete-Coulibaly R, Labbe A, Bouassida W, Lachkar Y. Mid-term effects of two-site phacotrabeculectomy with limbal-based conjunctival flap and microincision trabeculectomy with adjustable sutures. Foreign language
Lu D, Liu W, Li H, Ji J. The application of human anterior lens capsule autotransplantation in phacotrabeculectomy: a prospective, comparative and randomized clinical study. Eye (Lond). 2009;23(1):195-201. [pmid: 18404160]. OAG can’t be analyzed separately
Lubeck MJ. Aplastic anemia following acetazolamide therapy. Am J Ophthalmol. 70 ;69(4):684-5. It is a case series
Luchik VI. Efficacy of combined conservative treatment of patients with initial open-angle glaucoma. Foreign language
Luchik VI. The dynamic glaucomatous process based on the data from the long-term dispensary observations of patients operated on in the initial stage of the disease. Foreign language
Luke C, Dietlein TS, Jacobi PC, Konen W, Kriegistein GK. Comparison of viscocanalostomy and trabeculectomy in open-angle glaucoma - a prospective randomized study. Meeting abstract
Luke C, Dietlein TS, Jacobi PC, Konen W, Krieglstein GK. A prospective randomized trial of viscocanalostomy versus trabeculectomy in open-angle glaucoma: a 1-year follow-up study. Cheng 2009 and Chai 2010
Luke C, Dietlein TS, Luke M, Konen W, Krieglstein GK. A prospective trial of phaco-trabeculotomy combined with deep sclerectomy versus phaco-trabeculectomy. Graefes Arch Clin Exp Ophthalmol. 2008;246(8):1163-8. [pmid: 18414886]. It is a case series
Lumme P, Tuulonen A, Airaksinen PJ, Alanko HI. Neuroretinal rim area in low tension glaucoma: effect of nifedipine and acetazolamide compared to no treatment. Acta Ophthalmol (Copenh). 91 ; 69(3):293-8. It is not a RCT and has less than 100 patients
Lund OE, Zink H. Long-term results following argon laser trabeculoplasty. Klin Monbl Augenheilkd. 88 ;193(6):572-8. No original data (e.g., systematic review, narrative review, editorial, letter)
Luntz MH, Freedman J. The fornix-based conjunctival flap in glaucoma filtration surgery. Ophthalmic Surg. 80 ;11(8):516-21. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Luntz MH, Schlossman A. Trabeculectomy: a modified surgical technique. J Cataract Refract Surg. 94 ;20(3):350-2. It is not a RCT and has less than 100 patients
Luo RJ, Zhuo YH, Liu SR, Lin MK, Tian Z. Long-term effects of non-penetrating trabecular surgery versus trabeculectomy for treating glaucoma. Foreign language
Lupinacci AP, Netland PA, Fung KH, Evans D, Zhao Y. Comparison of twice-daily and three-times-daily dosing of dorzolamide in ocular hypertension and primary open-angle glaucoma patients treated with latanoprost. Unique comparators
Luque Aranda R, Cabarga Del, Nozal C, Silva Silva G, Vazquez Salvi A, Garcia Campos JM. Study on hypotensive effect of latanoprost vs timolol-dorzolamide association. Arch Soc Esp Oftalmol. 2002;77(4):205-10. [pmid: 11973662]. It is not a RCT and has less than 100 patients
Lusky M, Ticho U, Glovinsky J, Weinberger D, Nesher R, Yassur Y, Melamed S. A comparative study of two dose regimens of latanoprost in patients with elevated intraocular pressure. Ophthalmology. 97 ;104(10):1720-4. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Lustgarten JS. Topical timolol-induced arthropathy. Am J Ophthalmol. 88 ;105(6):687-8. It is a case series
Lustgarten J, Podos SM, Ritch R, Fischer R, Stetz D, Zborowski L, Boas R. Laser trabeculoplasty. A prospective study of treatment variables. Archives of ophthalmology. 84 ;102(4):517-9. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Lutfalla AI. Clinical results of a 1-stage cataract extraction with trabeculectomy. Foreign language
Luu KT, Raber SR, Nickens DJ, Vicini P. A model-based meta-analysis of the effect of latanoprost chronotherapy on the circadian intraocular pressure of patients with glaucoma or ocular hypertension. Systematic review
Luu ST, Lee AW, Chen CS. Transient monocular visual loss following administration of topical latanoprost: a case report. Can J Ophthalmol. 2009;44(6):715. [pmid: 20029498]. It is a case series
Lynch MG, Whitson JT, Brown RH, Nguyen H, Drake MM. Topical beta-blocker therapy and central nervous system side effects. A preliminary study comparing betaxolol and timolol. Arch Ophthalmol. 88 ;106(7):908-11. Data not abstractable
Ma H, Shao H, Lee PY, Comer G, Ma A. A COMPARISON OF IOP-REDUCING EFFECT OF LATANOPROST AND TIMOLOL IN OCULAR HYPERTENSION AND PRIMARY OPEN-ANGLE GLAUCOMA. Meeting abstract
Ma J-X. Treating patients with primary open angle glaucoma or ocular hypertension with domestic and imported latanoprost drop: Comparison on efficacy and cost. Foreign language
Maas S, Ros FE, De Heer LJ, De Keizer RJ. Efficacy and safety of the combination therapy Pilogel/beta-blocker: interim results. Doc Ophthalmol. 89; 72(3–4):391-8. It is not a RCT and has less than 100 patients
MacKeen DL. Effects of aqueous instillation. Ophthalmology. 1853;99 ; 106(10). No original data (e.g., systematic review, narrative review, editorial, letter)
Macky TA. Bimatoprost versus travoprost in an Egyptian population: a hospital-based prospective, randomized study. Duplicate of 80213
Macky TA. Bimatoprost versus travoprost in an Egyptian population: a hospital-based prospective, randomized study. Journal of ocular pharmacology and therapeutics : the official journal of the Association for Ocular Pharmacology and Therapeutics. 2010;26(6):605-10. [pmid: 21034177]. Other (specify):Mean age less than 50
Macky TA. Bimatoprost versus travoprost in an egyptian population: a hospital-based prospective, randomized study. Only addresses med KQ 3 and 6.
Madelain J, Isorni MC, Malthieu D, Turut P. Trabeculoretraction using argon laser and open-angle glaucoma: results after 4 years. Bull Soc Ophtalmol Fr. 88; 88(8–9):1041-5. Data not abstractable
Maffrand RA. Surgery of glaucoma: intrascleral trabeculo-irido encleisis. Rev Fac Cien Med Univ Nac Cordoba. 93 ;51(1):13-8. It is not a RCT and has less than 100 patients
Maffrand Roque Alejandro. Cirugia del glaucoma: trabeculo-irido-encleisis intraescleral. Foreign language
Mafwiri M, Bowman RJ, Wood M, Kabiru J. Primary open-angle glaucoma presentation at a tertiary unit in Africa: intraocular pressure levels and visual status. Ophthalmic Epidemiol. 2005;12(5):299-302. [pmid: 16272049]. It is a case series
Magacho L, Queiroz CF, Medeiros M, Lima FE, Magacho B, Avila M. Improvement in glaucomatous visual field thresholds after reduction of intraocular pressure: Clinical vs. surgical treatment. Melhora dos limiares de sensibilidade do campo visual apos reducao da pressao intra-ocular em pacientes com glaucoma: Tratamento cirurgico vs. clinico. Foreign language
Magacho L, Reis R, Shetty RK, Santos LC, Avila MP. Efficacy of latanoprost or fixed-combination latanoprost-timolol in patients switched from a combination of timolol and a nonprostaglandin medication. Ophthalmology. 2006;113(3):442-5. [pmid: 16458964]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Magacho Leopoldo, Costa Marcelus Layguel, Lima Francisco Eduardo, Magacho Bernardo, -vila Marcos Pereira de. Anblogos das prostaglandinas diminuem a sensibilidade do teste provocativo da ibopamina no glaucoma. Foreign language
Magacho Leopoldo, Queiroz Carlos Frederico, Medeiros Mariele, Lima Francisco Eduardo, Magacho Bernardo, Avila Marcos. Melhora dos limiares de sensibilidade do campo visual ap£s reducPo da pressPo intra-ocular em pacientes com glaucoma: tratamento cir·rgico vs. clÆnico. Foreign language
Magder H, Boyaner D. The use of a longer acting pilocarpine in the management of chronic simple glaucoma. Duplicate
Magder H, Boyaner D. The use of a longer pilocarpine in the management of chronic simple glaucoma. Can J Ophthalmol. 74 ;9(3):285-8. It is not a RCT and has less than 100 patients
Mahdaviani S, Kitnarong N, Kropf JK, Netland PA. Efficacy of laser trabeculoplasty in phakic and pseudophakic patients with primary open-angle glaucoma. Ophthalmic Surg Lasers Imaging. 2006;37(5):394-8. [pmid: 17017199]. It is not a RCT and has less than 100 patients
Mahroo OA, Stanbury R, Lim KS. Were the groups in the trabeculectomy versus Ahmed valve study really comparable. Br J Ophthalmol. 2010;94(11):1551-2. [pmid: 20962356]. No original data (e.g., systematic review, narrative review, editorial, letter)
Maichuk IuF, Erichev VP. Pharmaceutical and clinical evaluation of soluble pilocarpine eye films. Foreign language
Makabe R. Mydriasis tonography during treatment with miotics. Foreign language
Malagola R, Motolese ED, De Luca T. Long-term tonometry control of laser therapy of open-angle glaucoma. Fortschr Ophthalmol. 88 ;85(4):366-8. It is a case series
Malik SR, Sood GC, Bhardwaj PC, Saha SK. Effect of sustained release acetazolamide on the intraocular tension in normal and glaucomatous eyes. J All India Ophthalmol Soc. 65 ;13(4):151-7. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Malta Roberto Freire Santiago. Reprodutibilidade do Teste de prono-posigåo em quarto escuro. Foreign language
Mamalis N, Lohner S, Rand AN, Crandall AS. Combined phacoemulsification, intraocular lens implantation, and trabeculectomy. J Cataract Refract Surg. 96 ;22(4):467-73. It is combined cataract/glaucoma surgery study published before April 2000
Mamedov NG, Shtilerman AL, Frolov AV. Comparative studies of the efficacy of laser therapy of common and pseudoexfoliative primary open-angle glaucoma. Foreign language
Mancuso G, Berdondini RM. Allergic contact blepharoconjunctivitis from dorzolamide. Contact Dermatitis. 2001;45(4):243. [pmid: 11683843]. It is not a RCT and has less than 100 patients
Mandia J·nior Carmo, Rodrigues Maria de Lourdes Veronese. Trabeculectomia com mitomicina-C no tratamento de glaucomas refratbrios: avaliagPo dos resultados de 108 casos. Foreign language
Mandia Junior Carmo, Kasahara Niro, Seixas Francisco Soares, Paolera MaurÆcio Della, Almeida Geraldo Vicente de, Cohen Ralph. ComparagPo a longo prazo entre a facectomia extracapsular combinada a trabeculectomia e a facotrabeculectomia. Foreign language
Mandic Z, Ivekovic R. Glaucoma triple procedure: comparison of ECCE and phacoemulsification combined with trabeculectomy. Meeting abstract
Mandic Z, Bencic G, Zoric Geber M, Bojic L. Fornix vs limbus based flap in phacotrabeculetomy with mitomycin C: prospective study. Croat Med J. 2004;45(3):275-8. [pmid: 15185416]. Other (specify):Study design does not match KQ
Mandic Z, Bojic L, Novak-Laus K, Saric D. Evaluation of the intraocular pressure-reducing effect of latanoprost as monotherapy in open-angle glaucoma. Excluded drug
Mandic Z, Ivekovic R, Petric I, Zoric-Geber M. Glaucoma triple procedure: a one-site vs. a two-site approach. Coll Antropol. 2000;24(2):367-71. [pmid: 11216404]. It is not a RCT and has less than 100 patients
Mani KM. Experiencia con la trabeculectomia en la poblacion de Jamaica. Foreign language
Manni G, Bucci M. Substitution with Latanoprost monotherapy or additional with Dorzolamide in Timolol treated patients. A randomized, multicenter study in Italy. Meeting abstract
Manni G. Demographic and clinical factors associated with brimonidine-induced ocular allergy. Eur J Ophthalmol. 2007;17(SUPPL 5):S22-23. Does not address any key questions
Manni GL, Centofanti M, Napoli D, Parisi V, Bucci MG. Hypotensive effects of dorzolamide eyewash in maximal therapy glaucoma patients: a comparative study with oral acetazolamide. Acta Ophthalmol Scand Suppl. 97(224):22-3. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Manni G, Centofanti M, Parravano M, Oddone F, Bucci MG. A 6-month randomized clinical trial of bimatoprost 0.03% versus the association of timolol 0.5% and latanoprost 0.005% in glaucomatous patients. Non-FDA-approved drug combination
Manni G, Centofanti M, Sacchetti M, Oddone F, Bonini S, Parravano M, Bucci MG. Demographic and clinical factors associated with development of brimonidine tartrate 0.2%-induced ocular allergy. J Glaucoma. 2004;13(2):163-7. [pmid: 15097264]. Animal or in vitro data
Manni G, Denis P, Chew P, Sharpe ED, Orengo-Nania S, Coote MA, Laganovska G, Volksone L, Zeyen T, Filatori I, James J, Aung T. The safety and efficacy of brinzolamide 1%/timolol 0.5% fixed combination versus dorzolamide 2%/timolol 0.5% in patients with open-angle glaucoma or ocular hypertension. J Glaucoma. 2009;18(4):293-300. [pmid: 19365194]. Other (specify):Brinz/Tim not fda-approved
Manni G, Denis P, Zeyen T, Aung T, Filatori I, James J, Salem C, Smoot T. Comparison of Safety and Efficacy of Brinzolamide/Timolol (AZARGATM) vs. COSOPT® in Patients With Open-Angle Glaucoma or Ocular Hypertension. KQ 3 only.
Manni G, Migliardi R, Lorenzano D, Minchiotti S, Bucci MG. Comparison between Surgical and Medical Treatment Effect on Diurnal Intraocular Pressure Fluctuations in Open Angle Glaucoma Patients. Meeting abstract
Mansberger SL. Are you compliant with addressing glaucoma adherence. Am J Ophthalmol. 2010;149(1):1-3. [pmid: 20103035]. No original data (e.g., systematic review, narrative review, editorial, letter)
Mansberger SL, Hughes BA, Gordon MO, Spaner SD, Beiser JA, Cioffi GA, Kass MA. Comparison of initial intraocular pressure response with topical beta-adrenergic antagonists and prostaglandin analogues in African American and white individuals in the Ocular Hypertension Treatment Study. KQ 6 Medical only.
Mansouri K, Tran HV, Ravinet E, Mermoud A. Comparing deep sclerectomy with collagen implant to the new method of very deep sclerectomy with collagen implant: a single-masked randomized controlled trial. Journal of glaucoma. 2010;19(1):24-30. [pmid: 19373103]. OAG can’t be analyzed separately
Mansouri K, Orguel S, Mermoud A, Haefliger I, Flammer J, Ravinet E, Shaarawy T. Quality of diurnal intraocular pressure control in primary open-angle patients treated with latanoprost compared with surgically treated glaucoma patients: a prospective trial. Br J Ophthalmol. 2008;92(3):332-6. [pmid: 18211927]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Mansouri K, Shaarawy T, Wedrich A, Mermoud A. Comparing polymethylmethacrylate implant with collagen implant in deep sclerectomy: a randomized controlled trial. J Glaucoma. 2006;15(3):264-70. [pmid: 16778652]. OAG can’t be analyzed separately
Mansouri K, Tran HV, Ravinet E, Mermoud A. Comparing deep sclerectomy with collagen implant to the new method of very deep sclerectomy with collagen implant: a single-masked randomized controlled trial. J Glaucoma. 2010;19(1):24-30. [pmid: 19373103]. Other (specify):Not a comparison of interest
Maquet JA, Dios E, Aragon J, Bailez C, Ussa F, Laguna N. Protocol for mitomycin C use in glaucoma surgery. Acta Ophthalmol Scand. 2005;83(2):196-200. [pmid: 15799732]. OAG can’t be analyzed separately
Maquet JA, Hernandez Velasco E, Pastor Jimeno JC. Double blind trial of dipivefrine and epinephrine bitartrate. ESTUDIO DOBLE CIEGO DE LA DIPIVALYL EPINEFRINA Y EL BITARTRATO DE EPINEFRINA. ARCH. SOC. ESP OFTALMOL. 84 ;47(1):1-5. [pmid: 19173132]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Maraini G, Vinciguerra E, Barberini E. Personal experience with pilocarpine-Ocusert in the treatment of glaucoma. Foreign language
Marcel HM, Dimitris P, Philipp M, Gerasimos G, Michael D. Adherence with brimonidine in patients with glaucoma aware and not aware of electronic monitoring. Acta Ophthalmol. 2010. Does not address any key questions (see below for questions), Data not abstractable
March W. Brinzolamide Study Groups. A COMPARISON OF THE EFFICACY, SAFETY AND OCULAR COMFORT OF BRINZOLAMIDE AND DORZOLAMIDE AS PRIMARY THERAPY FOR OPEN-ANGLE GLAUCOMA AND OCULAR HYPERTENSION. Meeting abstract
March WF, Ochsner KI. The long-term safety and efficacy of brinzolamide 1.0% (Azopt) in patients with primary open-angle glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
March WF, Ochsner KI. The long-term safety and efficacy of brinzolamide 1.0% (azopt) in patients with primary open-angle glaucoma or ocular hypertension. The Brinzolamide Long-Term Therapy Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
March WF, Kothe AC. The Brinzolamide Long-Term Therapy Study Group. EFFECT OF LONG-TERM THERAPY WITH BID OR TID-DOSED BRINZOLAMIDE 1% (AZOPTTM) COMPARED TO TIMOLOL 0.5% ON THE IOP, CORNEAL HEALTH AND VISUAL FIELDS OF PATIENTS WITH POAG OR OHT. Meeting abstract
March WF, Silver LH. The Brinzolamide Long-Term Therapy Study Group. THE LONG-TERM SAFETY AND EFFICACY OF BRINZOLAMIDE (AZOPT), A NEW TOPICAL CARBONIC ANHYDRASE INHIBITOR, IN PATIENTS WITH OPEN-ANGLE GLAUCOMA AND OCULAR HYPERTENSION. Meeting abstract
Marchini G, Ghilotti G, Bonadimani M, Babighian S. Effects of 0.005% latanoprost on ocular anterior structures and ciliary body thickness. J Glaucoma. 2003;12(4):295-300. [pmid: 12897573]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Marcon Italo Mundialino, Mello Paulo Augusto de Arruda, CorrWa Zqlia Maria da Silva, Marcon Alexandre Seminoti. Correlagåo entre os achados b biomicroscopia ultra-sónica de bolhas filtrantes, com ou sem mitomicina C, e a pressåo intra-ocular. Foreign language
Marcus C, Moster M, Wilson R. A FOUR YEAR FOLLOW UP COMPARISON OF 180° VS. 360° NEODYMIMIUM:YAG TRANSSCLERAL CYCLOPHOTOCOAGULATION. Meeting abstract
Marek R, Joanna W, Lewczuk K, Siemiatkowska A, Stankiewicz A. Efficacy and safety of deep sclerectomy and phacoemulsification and deep sclerectomy in clinical material of Military Health Service Institute--yearly observations. Klin Oczna. 2006;108(10–12):385-91. [pmid: 17455710]. It is not a RCT and has less than 100 patients
Margio Flavio A, Assumpgåo Deborah, Cronemberger Sebastiåo, Calixto Nassim. ColÆrios antiglaucomatosos e eficbcia da trabeculectomia: II-critqrios de definigåo do sucesso da cirurgia. Foreign language
Marigo FA, Cronemberger S, Calixto N. LONG-TERM USE OF TOPICAL ANTIGLAUCOMATOUS DRUGS AND SUCCESS OF TRABECULECTOMY. Meeting abstract
Marigo Flavio A, Cronemberger Sebastiåo, Calixto Nassim. ColÆrios antiglaucomatosos e eficbcia da trabeculectomia: I. estudo clÆnico. Foreign language
Maris PJ Jr, Ishida K, Netland PA. Comparison of trabeculectomy with Ex-PRESS miniature glaucoma device implanted under scleral flap. J Glaucoma. 2007;16(1):14-9. [pmid: 17224744]. OAG can’t be analyzed separately
Maroteaux I. Experience with topical brimonidine in the treatment of glaucomas. J Fr Ophtalmol. 2001;24(7):748-9. [pmid: 11680422]. No original data (e.g., systematic review, narrative review, editorial, letter)
Marquardt D, Lieb WE, Grehn F. Intensified postoperative care versus conventional follow-up: a retrospective long-term analysis of 177 trabeculectomies. Graefes Arch Clin Exp Ophthalmol. 2004;242(2):106-13. [pmid: 14648140]. Animal or in vitro data
Marquardt D, Lieb WE, Grehn F. Intensified postoperative care versus conventional follow-up: A retrospective long-term analysis of 177 trabeculestomies. Graefe’s Arch Clin Exp Ophthalmol. 2004;242(2):106-113. OAG can’t be analyzed separately
Marquardt R, Schubert T. Modification of tear film break-up time by beta blocker eyedrops without preservatives. Foreign language
Martenet AC, Gruber P. Trabeculectomy. Role of its localization. Foreign language
Martin E, Martinez-de-la-Casa JM, Garcia-Feijoo J, Troyano J, Larrosa JM, Garcia-Sanchez J. A 6-month assessment of bimatoprost 0.03% vs timolol maleate 0.5%: hypotensive efficacy, macular thickness and flare in ocular-hypertensive and glaucoma patients. Medical KQ 3 or KQ 3 and KQ 6 only
Martin FJ. Timolol maleate. A report from the Glaucoma Clinic, Sydney Eye Hospital. Aust J Ophthalmol. 80 ;8(2):177-8. Data not abstractable
Martin L, Wanger P. Five-year follow-up of treated patients with glaucoma using resolution perimetry. J Glaucoma. 98 ;7(1):22-6. Does not address any key questions
Martin L. Clinical experience with latanoprost: a retrospective study of 153 patients. Acta Ophthalmol Scand. 99 ;77(3):336-9. It is a case series
Martin-Boglind L, Wanger P. The effect of treatment on the results of high-pass resolution perimetry in glaucoma. Acta Ophthalmol (Copenh). 94 ;72(4):423-8. It is not a RCT and has less than 100 patients
Martinez A, Sanchez M. A comparison of the effects of 0.005% latanoprost and fixed combination dorzolamide/timolol on retrobulbar haemodynamics in previously untreated glaucoma patients. Medical KQ 3 only
Martinez A, Sanchez M. A comparison of the safety and intraocular pressure lowering of bimatoprost/timolol fixed combination versus latanoprost/timolol fixed combination in patients with open-angle glaucoma. Curr Med Res Opin. 2007;23(5):1025-32. [pmid: 17519068]. Other (specify):non FDA approved drug
Martinez A, Sanchez M. Bimatoprost/timolol fixed combination vs latanoprost/timolol fixed combination in open-angle glaucoma patients. Eye (Lond). 2009;23(4):810-8. [pmid: 18535605]. Does not address any key questions
Martinez A, Sanchez M. Effects of dorzolamide 2% added to timolol maleate 0.5% on intraocular pressure, retrobulbar blood flow, and the progression of visual field damage in patients with primary open-angle glaucoma: a single-center, 4-year, open-label study. Clin Ther. 2008;30(6):1120-34. [pmid: 18640468]. Other (specify):study design does not match KQ (KQ3)
Martinez A, Sanchez M. Intraocular pressure lowering effect of dorzolamide/timolol fixed combination in patients with glaucoma who were unresponsive to prostaglandin analogs/prostamides. Curr Med Res Opin. 2007;23(3):595-9. [pmid: 17355740]. It is a case series
Martinez A, Sanchez M. Retrobulbar haemodynamic effects of the latanoprost/timolol and the dorzolamide/timolol fixed combinations in newly diagnosed glaucoma patients. Int J Clin Pract. 2007;61(5):815-25. [pmid: 17343668]. Other (specify):not FDA approved combination
Martinez A, Sanchez-Salorio M. A comparison of the long-term effects of dorzolamide 2% and brinzolamide 1%, each added to timolol 0.5%, on retrobulbar hemodynamics and intraocular pressure in open-angle glaucoma patients. Medical KQ 3 only
Martinez A, Sanchez-Salorio M. Predictors for visual field progression and the effects of treatment with dorzolamide 2% or brinzolamide 1% each added to timolol 0.5% in primary open-angle glaucoma. Unique comparators
Martinez JA, Brown RH, Lynch MG, Caplan MB. Risk of postoperative visual loss in advanced glaucoma. Am J Ophthalmol. 93 ; 115(3):332-7. Data not abstractable
Martinez-de-la-Casa JM, Castillo A, Garcia-Feijoo J, Mendez-Hernandez C, Fernandez-Vidal A, Garcia-Sanchez J. Concomitant administration of travoprost and brinzolamide versus fixed latanoprost/timolol combined therapy: three-month comparison of efficacy and safety. Non-FDA-approved drug combination
Martinez-de-la-Casa JM, Garcia-Feijoo J, Castillo A, Matilla M, Macias JM, Benitez-del-Castillo JM, Garcia-Sanchez J. Selective vs argon laser trabeculoplasty: hypotensive efficacy, anterior chamber inflammation, and postoperative pain. Eye (Lond). 2004;18(5):498-502. [pmid: 15131681]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Martini E, Laffi GL, Sprovieri C, Scorolli L. Low-dosage mitomycin C as an adjunct to trabeculectomy. A prospective controlled study. Included in Wilkins 2010
Martone G, Frezzotti P, Tosi GM, Traversi C, Mittica V, Malandrini A, Pichierri P, Balestrazzi A, Motolese PA, Motolese I, Motolese E. An in vivo confocal microscopy analysis of effects of topical antiglaucoma therapy with preservative on corneal innervation and morphology. Am J Ophthalmol. 2009;147(4):725-735. e1. [pmid: 19181302]. It is not a RCT and has less than 100 patients
Maruyama K, Shirato S. Additive effect of dorzolamide or carteolol to latanoprost in primary open-angle glaucoma: a prospective randomized crossover trial. Unique comparators
Maruyama K, Shirato S, Haneda M. Evaluation of the additive effect of bunazosin on latanoprost in primary open-angle glaucoma. Jpn J Ophthalmol. 2005;49(1):61-2. [pmid: 15692779]. It is a case series
Masieri LT, Parmeggiani F, Gasparrini E, Gavioli I, Peruz G, Graziani F, Costagliola C. Effects of topical administration of clonidine 0.125% and brimonidine 0.2% on ocular perfusion pressure and visual field parameters in patients with primary open-angle glaucoma. Effetti della somministrazione topica di clonidina 0.125% e brimonidina 0.2% sulla pressione di perfusione oculare e sugli indici perimetrici in pazienti affetti da glaucoma primario ad angolo aperto. Foreign language
Mastropasqua L, Carpineto P, Ciancaglini M. Brimonidine and pupillary diameter. Ophthalmology. 98 ;105(8):1352-3. No original data (e.g., systematic review, narrative review, editorial, letter)
Mastropasqua L, Carpineto P, Ciancaglini M, Gallenga PE. A 12-month, randomized, double-masked study comparing latanoprost with timolol in pigmentary glaucoma. Ophthalmology. 99 ;106(3):550-5. Data not abstractable
Mastropasqua L, Ciancaglini M, Carpineto P, Verdesca G, Ciafre M, Costagliola C. The effect of 1% apraclonidine on visual field parameters in patients with glaucoma and ocular hypertension. Ann. Ophthalmol. Glaucoma. 98 ;30(1):41-45. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Mastropasqua L, Ciancaglini M, Carpineto P, Zuppardi E, Falconio G, Gallenga PE. Effects of brimonidine 0.2% on blue-yellow perimetry of glaucomatous patients. Acta Ophthalmol Scand Suppl. 98(227):36. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Mastropasqua L, Costagliola C, Ciancaglini M, Carpineto P, Gallenga PE. Ocular hypotensive effect of ketanserin in patients with primary open angle glaucoma. Acta Ophthalmol Scand Suppl. 97(224):24-5. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Masuda K. Eye and prostaglandins. Clinical application of prostaglandin synthetase inhibitor. Foreign language
Mattox C, Chung P, Schuman J. COMPARISON OF 5.5 MM VERSUS 3.5 MM SCLERAL FLAPS IN COMBINED PHACOEMULSIFICATION AND TRABECULECTOMY WITH MITOMYCIN C. Meeting abstract
Maul de la Puente Eugenio, Vega Sabaleta Rebeca. Efecto de la pilocarpina gel al 4 sobre la presi£n intraocular en glaucoma cr£nico simple. Foreign language
Maul E, Carrasco FG, Costa VP, Casiraghi JF, Vargas EMG, Sarmina JS, Maylo R. A Six-Week Double-Masked Study Comparing Travoprost 0.004% to Latanoprost 0.005% Followed by a Six-Week Open-Label Treatment on Travoprost 0.004%. Meeting abstract
Maul E, Carrasco FG, Costa VP, Casiraghi JF, Vargas E, Sarmina JS, Mayol R. A 6-week, multicenter, randomized, double-masked, parallel-group study comparing travoprost 0.004% to latanoprost 0.005% followed by 6-week, open-label treatment with travoprost 0.004%. Medical KQ 3 or KQ 3 and KQ 6 only
Mayer H, von der Ohe N. Efficacy of a novel hydrogel formulation in human volunteers. Ophthalmologica. 96 ;210(2):101-3. It is not a RCT and has less than 100 patients
Mazzeo V, Brienza D, Ilari L, Perri P, Rossi A. Trabeculectomy: A retrospective study of results of long-term follow-up. Our experience on 198 eyes. NEW TRENDS OPHTHALMOL. 96 ; 11(1):33-40. Data not abstractable
Mazzola C. Timoptol. Foreign language
McAllister JA, Schwartz LW, Moster M, Spaeth GL. Laser peripheral iridectomy comparing Q-switched neodymium YAG with argon. Transactions of the ophthalmological societies of the United Kingdom. 85 ;104(Pt 1):67-9. [pmid: 5227212]. No subjects with open-angle glaucoma
McCartney DL, Memmen JE, Stark WJ, Quigley HA, Maumenee AE, Gottsch JD, Bernitsky DA, Wong SK. The efficacy and safety of combined trabeculectomy, cataract extraction, and intraocular lens implantation. Ophthalmology. 88 ;95(6):754-63. It is combined cataract/glaucoma surgery study published before April 2000
McCarty CA, Mukesh BN, Kitchner TE, Hubbard WC, Wilke RA, Burmester JK, Patchett RB. Intraocular pressure response to medication in a clinical setting: the Marshfield Clinic Personalized Medicine Research Project. J Glaucoma. 2008;17(5):372-7. [pmid: 18703947]. Does not address any key questions
McCarty G, Stewart WC, Quayle W, Levin J, Rienhart M. EVALUATION OF MORNING IOP CONTROL BY BEDTIME PILOCARPINE GEL DOSING. Meeting abstract
McGuigan LJ, Gottsch J, Stark WJ, Maumenee AE, Quigley HA. Extracapsular cataract extraction and posterior chamber lens implantation in eyes with preexisting glaucoma. Arch Ophthalmol. 86 ;104(9):1301-8. Data not abstractable
McHam ML, Migdal CS, Netland PA. Early trabeculectomy in the management of primary open-angle glaucoma. INT. OPHTHALMOL CLIN. 94 ;34(3):163-172. No original data (e.g., systematic review, narrative review, editorial, letter)
McIlraith I, Strasfeld M, Colev G, Hutnik CM. Selective laser trabeculoplasty as initial and adjunctive treatment for open-angle glaucoma. J Glaucoma. 2006;15(2):124-30. [pmid: 16633226]. Other (specify):Study design does not match KQ
McKinley SH, Singh R, Chang PT, Gross RL, Orengo-Nania S. Intraocular pressure control among patients transitioned from latanoprost to travoprost at a Veterans Affairs Medical Center Eye Clinic. J Ocul Pharmacol Ther. 2009;25(2):153-7. [pmid: 19284329]. Other (specify):Mixed glaucoma
McMahon CD, Shaffer RN, Hoskins HD Jr, Hetherington J Jr. Adverse effects experienced by patients taking timolol. Am J Ophthalmol. 79 ;88(4):736-8. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
McNeal E, Yablonski ME. A Paired Comparison of Travoprost and Latanoprost on IOP and Conjunctival Hyperemia. Meeting abstract
Medeiros FA, Susanna R Jr. Bimatoprost. Ophthalmology. 2005;112(8):1478. author reply 1479. [pmid: 16061098]. No original data (e.g., systematic review, narrative review, editorial, letter)
Medeiros FA, Alencar LM, Zangwill LM, Sample PA, Weinreb RN. The Relationship between intraocular pressure and progressive retinal nerve fiber layer loss in glaucoma. Systematic review
Medeiros FA, Pinheiro A, Moura FC, Leal BC, Susanna R Jr. Intraocular pressure fluctuations in medical versus surgically treated glaucomatous patients. J Ocul Pharmacol Ther. 2002;18(6):489-98. [pmid: 12537675]. It is not a RCT and has less than 100 patients
Medeiros Felipe, Andrade Borges, Adriana S, Susanna J·nior Remo. Alteragões longitudinais na espessura da camada de fibras nervosas da retina ap£s trabeculectomia. Foreign language
Megevand GS, Salmon JF, Scholtz RP, Murray AD. The effect of reducing the exposure time of mitomycin C in glaucoma filtering surgery. Ophthalmology. 95 ;102(1):84-90. It is not a RCT and has less than 100 patients
Mehrotra AN, Jain BS, Anand GS. Comparative evaluation of pilocarpine 2% and combined guanethidine 1% & adrenaline 0.5% in the treatment of chronic simple glaucoma. Indian J Ophthalmol. 87 ;35(3):146-8. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Mehta HK. Subconjunctival injection of pilocarpine. Trans Ophthalmol Soc U K. 76 ;96(1):184-8. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Mehta KR, Sathe SN, Karyekar SD. Trabeculectomy ab-externo. Indian J Ophthalmol. 74 ;22(3):9-12. Does not address any key questions
Mehta NH, Simmons ST. Alphagan/Trusopt Study Group. THE SAFETY AND EFFICACY OF BRIMONIDINE AND DORZOLAMIDE AS CONCOMITANT THERAPY IN PRIMARY OPEN ANGLE GLAUCOMA AND OCULAR HYPERTENSION. Meeting abstract
Mehta R, Puthuran G, Krishnadas R, Mahalakshmi R. Efficacy of transscleral diode laser cyclophotocoagulation for refractory glaucomas in a South Indian population. Asian J Ophthalmol. 2006;8(6):232-235. No subjects with open-angle glaucoma
Meirelles Sergio Henrique Sampaio, Liporaci Simone Duarte, Bloise Renata Rianelli, -vila Ediane Gongalves. Resultado em longo prazo da trabeculectomia no tratamento do glaucoma congWnito primbrio. Foreign language
Meirelles Sergio Henrique Sampaio, Mathias Cristina Rodrigues, Wagner Raquel Young, -vila Ediane Gongalves, Alves Simone de Ara·jo, Ferreira DWnia Rezende. Trabeculoplastia com Laser de Argónio e com Laser de Diodo - Anblise comparativa de 2 anos de seguimento. Rev. bras oftalmol. 2003;62(10):727-732. It is not a RCT and has less than 100 patients
Mekki QA, Turner P. Dopamine-2 receptor blockade does not affect the ocular hypotensive action of timolol. British Journal of Ophthalmology. 88 ; 72(8):598-600. Does not address any key questions
Melamed S, David R. Ongoing clinical assessment of the safety profile and efficacy of brimonidine compared with timolol: Year-three results. Medical KQ 3 or KQ 3 and KQ 6 only
Melamed S, Bossawska I, Laroch C. Bimatoprost Adjunctive to Timolol Study Group. Effectiveness of Bimatoprost (LUMIGAN) as Adjunctive Therapy with Topical Beta-blockers in Patients with Glaucoma or Ocular Hypertension: A 3-Month, Multi-center, Double-masked, Randomized, Vehicle-controlled Trial with Double-masked Extension of Bimatoprost Treatment to 1 Year. Meeting abstract
Melamed S, Goldenfeld M, Simo G. A Prospective, Randomized Study to Compare a Gold Micro Shunt With the Ahmed Glaucoma Valve in Glaucoma Patients. Meeting abstract
Melamed S, Nordmann J, Yannoulis N, Mertz B, Schwenninger C, Kapik B. The efficacy and safety of unoprostone isopropyl 0.15%, timolol maleate 0.5%, and betaxolol hydrochloride 0.5% in patients with primary open-angle glaucoma or ocular hypertension. Month 12 data. Meeting abstract
Mellin KB, Heiligenhaus A, Schrenk M. Argon laser trabeculoplasty in chronic simple glaucoma with visual field defects and papillary damage. Ophthalmologe. 94; 91(5):585-8. It is not a RCT and has less than 100 patients
Mello e Oliveira Nilson de, Porto Ricardo B, Freitas Telam Gondim, Lacava Augusto Cezar. Estudo comparativo entre a eficbcia da trabeculectomia com e sem uso de 5-Fluorouracil ou Mitomiina -C. Foreign language
Membrey WL, Hitchings RA, Poinoosawmy D, Bunce C. Trabeculectomy in Normal-Tension Glaucoma (NTG) 2 Year Results: Intraocular Pressure (IOP) Control and Complications. Meeting abstract
Membrey WL, Bunce C, Poinoosawmy DP, Fitzke FW, Hitchings RA. Glaucoma surgery with or without adjunctive antiproliferatives in normal tension glaucoma: 2 Visual field progression. Br J Ophthalmol. 2001;85(6):696-701. [pmid: 11371491]. Does not address any key questions
Membrey WL, Poinoosawmy DP, Bunce C, Hitchings RA. Glaucoma surgery with or without adjunctive antiproliferatives in normal tension glaucoma: 1 intraocular pressure control and complications. Br J Ophthalmol. 2000;84(6):586-90. [pmid: 10837381]. It is not a RCT and has less than 100 patients
Menon GJ, Vernon SA. Topical brinzolamide and metabolic acidosis. Br J Ophthalmol. 2006;90(2):247-8. [pmid: 16424547]. It is a case series
Merkle W. Effect of methazolamide on the intraocular pressure of patients with open-angle glaucoma (author’s transl). Klin Monbl Augenheilkd. 80 ;176(1):181-5. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Merkle W. Effect of methazolamide on the intraocular pressure of patients with open-angle glaucoma. Duplicate
Mermoud A, Herbort CP, Schnyder CC, Pittet N. Comparison of the effects of trabeculoplasty using the Nd-YAG laser and the argon laser. Foreign language
Mermoud A, Karlen ME, Schnyder CC, Sickenberg M, Chiou AG, Hediguer SE, Sanchez E. Nd:Yag goniopuncture after deep sclerectomy with collagen implant. Ophthalmic Surg Lasers. 99 ;30(2):120-5. It is a case series
Mermoud A, Salmon JF, Murray AD. Trabeculectomy with mitomycin C for refractory glaucoma in blacks. Am J Ophthalmol. 93 ;116(1):72-8. It is not a RCT and has less than 100 patients
Mermoud A, Schnyder CC, Sickenberg M, Chiou AG, Hediguer SE, Faggioni R. Comparison of deep sclerectomy with collagen implant and trabeculectomy in open-angle glaucoma. J Cataract Refract Surg. 99 ;25(3):323-31. It is not a RCT and has less than 100 patients
Merte HJ, Merkle W. Experiences in a double-blind study with different concentrations of timolol and pilocarpine (author’s transl). Klin Monbl Augenheilkd. 80 ;177(4):443-50. It is not a RCT and has less than 100 patients
Merte HJ, Heilmann K, Hollwich I. Investigations on the effect of various doses of acetazolamide (Diamox) on intraocular pressure (author’s transl). Foreign language
Merte HJ, Stryz JR, Mertz M. Comparative studies of initial pressure reduction using 0.3% metipranolol and 0.25% timolol in eyes with wide-angle glaucoma. Klin Monbl Augenheilkd. 83 ;182(4):286-9. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Merte HJ, Stryz JR, Mertz M. Pindolol eye drops: Six months follow-up of an antiglaucomatous therapy. PINDOLOL-AUGENTROPFEN (GLAUCO-VISKEN(registered trademark)): HALBJAHRESERGEBNISSE EINER GLAUKOMTHERAPIE. KLIN. MONATSBL AUGENHEILKD. 84 ;184(3):227-232. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Mesci C, Aydin N, Erbil HH. Twenty-four-hour Intraocular Pressure Control With Latanoprost-timolol-fixed Combination Versus Bimatoprost in Patients Who Switched From Timolol. J Glaucoma. 2010. Does not include treatment for open-angle glaucoma (medical, surgical or combined; See addendum for list of interventions), Other (specify): not included drug
Mesci C, Aydin N, Erbil HH. Twenty-four-hour Intraocular Pressure Control With Latanoprost-timolol-fixed Combination Versus Bimatoprost in Patients Who Switched From Timolol. J Glaucoma. 2010. Other (specify):Latanoprost-timolol-fixed Combination not included
Messmer C, Stumpfig D, Flammer J. Effect of betaxolol and timolol on visual fields in glaucoma patients. Foreign language
Messmer C, Stumpfig D, Flammer J. Influence of betaxolol and timolol on the visual field in glaucoma patients. EINFLUSS VON BETAXOLOL UND TIMOLOL AUF DAS GESICHTSFELD BEI GLAUKOMPATIENTEN. Duplicate
Meuche C, Heidrich H, Bleckmann H. Raynaud syndrome following timolol-containing eyedrops. Fortschr Ophthalmol. 90 ;87(1):45-7. It is a case series
Meyer J, Samples J. EFFICACY OF DORZOLAMIDE IN GLAUCOMA SUBPOPULATIONS INCLUDING PEDIATRIC AND SECONDARY GLAUCOMAS. Meeting abstract
Meyer-Rusenberg HW, Lawin-Brussel C, Emmerich KH. Long-term results following goniotrepanation (Elliot-Fronimopoulos). Fortschr Ophthalmol. 88 ;85(4):375-7. It is a case series
Michalikova L, Ferkova S, Jakabovicova E, Strmen P. Antimetabolites in glaucoma surgery - The long term study. Antimetabolity v chirurgii glaukomu - Dlhodobe vysledky. Foreign language
Michaud JE, Friren B. Comparison of topical brinzolamide 1% and dorzolamide 2% eye drops given twice daily in addition to timolol 0.5% in patients with primary open-angle glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Michelson G, Junemann A, Hanel B, Naumann GO. Intraocular pressure after filtering operation or combined filter-cataract operation. Foreign language
Mielke C, Dawda VK, Anand N. Intraoperative 5-fluorouracil application during primary trabeculectomy in Nigeria: a comparative study. Eye (Lond). 2003;17(7):829-34. [pmid: 14528245]. OAG can’t be analyzed separately
Mietz H, Krieglstein GK. Postoperative application of mitomycin c improves the complete success rate of primary trabeculectomy: a prospective, randomized trial. Graefes Arch Clin Exp Ophthalmol. 2006;244(11):1429-36. [pmid: 16598468]. OAG can’t be analyzed separately
Mietz H, Krieglstein GK. Short-term clinical results and complications of trabeculectomies performed with mitomycin C using different concentrations. Int Ophthalmol. 95 ;19(1):51-6. Data not abstractable
Mietz H, Krieglstein GK. Suramin to enhance glaucoma filtering procedures: a clinical comparison with mitomycin. Ophthalmic Surg Lasers. 2001;32(5):358-69. [pmid: 11563779]. OAG can’t be analyzed separately
Mietz H, Jacobi PC, Krieglstein GK. Postoperative topical versus intraoperative episcleral application of mitomycin for trabeculectomy in secondary glaucoma and repeat trabeculectomy. Meeting abstract
Mietz H, Jacobi PC, Krieglstein GK. Trabeculectomy in complicated glaucoma: Topical application of mitomycin. Meeting abstract
Mietz H, Jacobi PC, Krieglstein GK. Intraoperative episcleral versus postoperative topical application of mitomycin-C for trabeculectomies. Ophthalmology. 2002;109(7):1343-9. [pmid: 12093661]. OAG can’t be analyzed separately
Mietz H, Jacobi PC, Krieglstein GK. Postoperative application of mitomycin for trabeculectomies. Arch Ophthalmol. 2000;118(10):1341-8. [pmid: 11030815]. OAG can’t be analyzed separately
Mietz H, Jacobi PC, Jonescu-Cuypers CP, Welsandt G, Krieglstein GK. Postoperative Topical Application of Mitomycin For Primary Trabeculectomy. Meeting abstract
Mietz H, Jacobi PC, Jonescu-Cuypers C, Welsandt G, Krieglstein GK. Primary trabeculectomy in simple glaucoma: Postoperative, low-dose mitomycin application. Meeting abstract
Mietz H, Jacobi PC, Welsandt G, Krieglstein GK. Trabeculectomies in fellow eyes have an increased risk of tenon’s capsule cysts. Ophthalmology. 2002;109(5):992-7. [pmid: 11986109]. Other (specify):No control group
Mietz H, Raschka B, Krieglstein GK. Risk factors for failures of trabeculectomies performed without antimetabolites. Br J Ophthalmol. 99 ;83(7):814-21. It is a case series
Migdal C, Hitchings R. Control of chronic simple glaucoma with primary medical, surgical and laser treatment. Trans Ophthalmol Soc U K. 86 ;105(Pt 6):653-6. Data not abstractable
Migdal C, Hitchings R. Morbidity following prolonged postoperative hypotony after trabeculectomy. Ophthalmic Surg. 88 ; 19(12):865-7. It is not a RCT and has less than 100 patients
Migdal C, Hitchings R. Primary therapy for chronic simple glaucoma the role of argon laser trabeculoplasty. Trans Ophthalmol Soc U K. 85 ;104(Pt 1):62-6. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Migdal CS, Hitchings RA, Gregory W. Long-Term Functional Outcome After Early Surgery Compared With Laser and Medicine in Open-Angle Glaucoma. Meeting abstract
Migdal C, Gregory W, Hitchings R. Long-term functional outcome after early surgery compared with laser and medicine in open-angle glaucoma. Ophthalmology. 94 ; 101(10):1651-6. discussion 1657. Data not abstractable
Miglior S, Grunden JW, Kwok K. Efficacy and safety of fixed combinations of latanoprost/timolol and dorzolamide/timolol in open-angle glaucoma or ocular hypertension. Eye (Lond). 2010;24(7):1234-42. [pmid: 20019759]. Other (specify):not fda approv drug
Miglior S, Pfeifer N, Cunba-Vaz J, Zeyen T. European Glaucoma Prevention Study Group. THE EUROPEAN GLAUCOMA PREVENTION STUDY, BASELINE DESCRIPTION OF THE PARTICIPANTS. Meeting abstract
Miglior S, Pfeiffer N, Cunha-Vaz J, Zeyen T. European Glaucoma Prevention Study Group. THE EUROPEAN GLAUCOMA PREVENTION STUDY. OBJECTIVES AND METHODS. Meeting abstract
Miglior S, Torri V, Zeyen T, Pfeiffer N, Cunha-Vaz J, Adamsons I. EGPS Group. The Effect of IOP and Other Inter-Current Factors on the Development of Open Angle Glaucoma in the European Glaucoma Prevention Study. Meeting abstract
Miglior S, Torri V, Zeyen T, Pfeiffer N, Vaz JC, Adamsons I. Intercurrent factors associated with the development of open-angle glaucoma in the European glaucoma prevention study. EMGT.
Mikelberg FS. Safety and effectiveness of topical bimatoprost. Can J Ophthalmol. 2009;44(2):209. author reply 209. [pmid: 19491959]. No original data (e.g., systematic review, narrative review, editorial, letter)
Miki H, Miki K. The effects on the intraocular pressure and visual field resulting from a switch in the treatment from timolol to betaxolol. J Ocul Pharmacol Ther. 2004;20(6):509-17. [pmid: 15684810]. It is not a RCT and has less than 100 patients
Mikropoulos D, Konstas AGP, Haidich B, Ntampos KS, Stewart WC. 24-Hour Intraocular Pressure Control With the Travoprost/Timolol Fixed Combination Compared With Travoprost When Both Are Dosed in the Evening in Primary Open-Angle Glaucoma. Meeting abstract
Miller HA, Morlot C. Preliminary note on the use of the pilocarpine Ocusert in primary glaucoma. Foreign language
Miller KN, Blasini M, Shields MB, Ho CH. A comparison of total and partial tenonectomy with trabeculectomy. Am J Ophthalmol. 91 ; 111(3):323-6. [pmid: 7011037]. Data not abstractable
Miller RD, Barber JC. Trabeculectomy in black patients. Ophthalmic Surg. 81 ;12(1):46-50. OAG can’t be analyzed separately
Mills KB, Wright G. A blind randomised cross-over trial comparing metipranolol 0.3% with timolol 0.25% in open-angle glaucoma: a pilot study. Unique comparators
Mills KB. Blind randomised non-crossover long-term trial comparing topical timolol 0.25% with timolol 0.5% in the treatment of simple chronic glaucoma. KQ 3 RCT
Mills KB. Trabeculectomy: a retrospective long-term follow-up of 444 cases. Br J Ophthalmol. 81 ;65(11):790-5. OAG can’t be analyzed separately
Mills KB, Jacobs NJ, Vogel R. A study of the effects of four concentrations of D-timolol, 0.25% L-timolol, and placebo on intraocular pressure on patients with raised intraocular pressure. Br J Ophthalmol. 88 ; 72(6):469-72. [pmid: 15031157]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Minckler D, Baerveldt G, Ramirez MA, Mosaed S, Wilson R, Shaarawy T, Zack B, Dustin L, Francis B. Clinical results with the Trabectome, a novel surgical device for treatment of open-angle glaucoma. Trans Am Ophthalmol Soc. 2006;104:40-50. [pmid: 17471324]. It is a case series
Minckler D, Mosaed S, Dustin L, Ms BF. Trabectome (trabeculectomy-internal approach): additional experience and extended follow-up. Trans Am Ophthalmol Soc. 2008;106:149-59. discussion 159–60. [pmid: 19277230]. OAG can’t be analyzed separately
Ming YZ. The ocular hypotensive effect and side reactions of domestic clonidine eyedrops. Foreign language
Mirza GE, Karakucuk S, Dogan H, Erkilic K. Filtering surgery with mitomycin-C in uncomplicated (primary open angle) glaucoma. Acta Ophthalmol (Copenh). 94 ;72(2):155-61. It is not a RCT and has less than 100 patients
MISHIMA Saiichi, AZUMA Ikuo, AIZAWA Futaba, TAKAHASHI Nobuo, TANAKA Yasuo, IWATA Kazuo, TOMONO Masaaki, NAMBA Katsuhiko, KITAZAWA Yoshiaki, TAKASE Masahiro, FUTEMMA Minoru, MATSUO Harutake, HAMADA Minejiro, OGAWA Tetsuro, KOMOTO Shoichi, KAGEYAMA Mariko, SHINRIKI Shinobu, ENDO Yohko, EIRAKU Hiroto, YOSHIDA Kimio, YASUDA Noriko, TANE Sadanao, ISHIKAWA Kiyoshi, AOKI Sachie, SHIMIZU Naokata, et al. Clinical Evaluation of Timolol in the Treatment of Patients with Ocular Hypertension and Primary Open Angle Glaucoma Who have been Controlled on Pilocarpine -Double blind study-. Rinsho Hyoka (Clinical Evaluation). 80 ;8(3):789-820. Other (specify):
MISHIMA Saiichi, AZUMA Ikuo, TAKASE Masahiro, AIZAWA Futaba, SOMA Keiko, KATSUSHIMA Harumi, KIMURA Ryozo, NANBA Hisayoshi, KOMURO Sono, YANAGISAWA Yoriko, KAMEYAMA Kazuko, MIYASAKA Yumiko, KIKUCHI Ryuzi, KOIKE Yuji, TOKORO Takashi, YAGI Takashi, MATSUO Harutake, HAMADA Reijiro, OGAWA Tetsuro, NAKANO Naoki, UEDA Tatsuko, TONO Iwao, INAGAKI Masayasu, SHIMIZU Nobuo, SHIMIZU Naokata, et al. Clinical Evaluation of Bupranolol Hydrochloride Drop in the Treatment of Primary Open-Angle Glaucoma and Ocular Hypertension -Multi Center Double-Blind Study in Comparison with Pilocarpine Drop-. Foreign language
Mishima HK, Masuda K, Kitazawa Y, Azuma I, Araie M. A comparison of latanoprost and timolol in primary open-angle glaucoma and ocular hypertension. A 12-week study. Medical KQ 3 or KQ 3 and KQ 6 only
Mishima S, Azuma I, Tane S, Takase M, Kosaki H. Clinical evaluation of befunolol in the treatment of primary open angle glaucoma and ocular hypertension under controlled with pilocarpine -Multi-center double blind study in comparing between three masked dosages. Rinsho Hyoka (Clinical Evaluation). 82 ;10:469-513. Other (specify):not FDA approved
Mishima S, Kitazawa Y, Shirato S. Surgical treatment of open-angle glaucoma. Aust N Z J Ophthalmol. 85 ;13(3):211-23. Does not address any key questions
Mital S, Avasthi P, Anand N. A comparative study of trabeculectomy in cases of chronic simple glaucoma. Indian Journal of Ophthalmology. 79 ;27(4):113-5. It is not a RCT and has less than 100 patients
Mitchell P, Wang JJ, Cumming RG, House P, England JD. Long-term topical timolol and blood lipids: the Blue Mountains Eye Study. J Glaucoma. 2000;9(2):174-8. [pmid: 10782628]. Does not address any key questions
Miura K, Ito K, Okawa C, Sugimoto K, Matsunaga K, Uji Y. Comparison of ocular hypotensive effect and safety of brinzolamide and timolol added to latanoprost. Unique comparators
Miyake T, Sawada A, Yamamoto T, Miyake K, Sugiyama K, Kitazawa Y. Incidence of disc hemorrhages in open-angle glaucoma before and after trabeculectomy. J Glaucoma. 2006;15(2):164-71. [pmid: 16633231]. Does not address any key questions
Mizoguchi T, Nagata M, Matsumura M, Kuroda S, Terauchi H, Tanihara H. Surgical effects of combined trabeculotomy and sinusotomy compared to trabeculotomy alone. Acta Ophthalmol Scand. 2000;78(2):191-5. [pmid: 10794255]. Other (specify):Not a treatment modality of interest
Mizokami K, Tanaka Y. Comparison of a trabeculotomy and trabeculectomy combined with phacoemulsification and foldable lens implantation. Foreign language
Mochizuki K, Jikihara S, Ando Y, Hori N, Yamamoto T, Kitazawa Y. Incidence of delayed onset infection after trabeculectomy with adjunctive mitomycin C or 5-fluorouracil treatment. Br J Ophthalmol. 97 ;81(10):877-83. OAG can’t be analyzed separately
Mochizuki M, Kitazawa Y. Trabeculectomy: a follow up study. Foreign language
Mogk LG, Cyrlin MN. Blood dyscrasias and carbonic anhydrase inhibitors. Ophthalmology. 88 ;95(6):768-71. It is a case series
Molfino F, Frau B, Semino E, Venzano D, Traverso CE. IOP- LOWERING.EFFECT OF DORZOLAMIDE 2% VERSUS BRIMONIDINE TARTRATE 0.2%. A PROSPECTIVE RANDOMIZED CROSS OVER STUDY. Meeting abstract
Molteno AC. A new implant for glaucoma. Effect of removing implants. Br J Ophthalmol. 71 ;55(1):28-37. It is a case series
Molteno AC, Bevin TH, Herbison P, Houliston MJ. Otago glaucoma surgery outcome study: long-term follow-up of cases of primary glaucoma with additional risk factors drained by Molteno implants. Ophthalmology. 2001;108(12):2193-200. [pmid: 11733258]. It is a case series
Molteno AC, Bosma NJ, Kittelson JM. Otago glaucoma surgery outcome study: long-term results of trabeculectomy--1976 to 1995. Ophthalmology. 99 ;106(9):1742-50. It is a case series
Molteno AC, Straughan JL, Ancker E. Control of bleb fibrosis after glaucoma surgery by anti-inflammatory agents. S Afr Med J. 76 ; 50(23):881-5. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Molteno AC, Whittaker KW, Bevin TH, Herbison P. Otago Glaucoma Surgery Outcome Study: long term results of cataract extraction combined with Molteno implant insertion or trabeculectomy in primary glaucoma. Br J Ophthalmol. 2004;88(1):32-5. [pmid: 14693768]. It is a case series
Monta±o Moreno Gustavo, Babaybn Mena Juan Ignacio, Escudero Bache Eduardo. TrabeculectomÆa: anblisis retrospectivo de 100 casos. Foreign language
Montanari P, Italia A, Marangoni P, Pinotti D, Miglior M. Diode laser trans-scleral cyclophotocoagulation in refractory glaucoma treatment. Acta Ophthalmol Scand Suppl. 97(224):38. It is not a RCT and has less than 100 patients
Montoro JB, Lalueza P, Cano SM, Escobar C, Linares F. Drop size and systemic adverse effects in timolol ophthalmic solution. Unique comparators
Montoya Pizarro Olga. Eficacia comparativa del Betaxol y el Timolol. Library can’t find
Mora JS, Nguyen N, Iwach AG, Gaffney MM, Hetherington J Jr, Hoskins HD Jr, Wong PC, Tran H, Dickens CJ. Trabeculectomy with intraoperative sponge 5-fluorouracil. Ophthalmology. 96 ;103(6):963-70. Other (specify):Study includes angle-closure glaucoma among other types of glaucomas we’re excluding
Mori K, Kawashima A. Crossover Comparative Study of Betaxolol and Timolol Effect on Retinal Circulation in Glaucoma and Ocular Hypertension. Meeting abstract
Moriarty AP, Dowd TC. Timolol-pilocarpine fixed-ratio combinations in the treatment of chronic open angle glaucoma. Arch Ophthalmol. 93 ; 111(10):1313-4. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Moriarty AP, McHugh JD, Spalton DJ, Ffytche TJ, Shah SM, Marshall J. Comparison of the anterior chamber inflammatory response to diode and argon laser trabeculoplasty using a laser flare meter. Ophthalmology. 93 ; 100(8):1263-7. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Moriarty BJ, Char JN, Acheson RW, Dunn DT. Argon laser trabeculoplasty in primary open-angle glaucoma--results in black Jamaican population. Rolim de Moura 2009
Moro F, Borellini S, Cavallaro N. Antiglaucomatous trabeculectomy (author’s transl). Klin Monbl Augenheilkd. 78; 172(5):670-6. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Morrison JC, Robin AL. Adjunctive glaucoma therapy. A comparison of apraclonidine to dipivefrin when added to timolol maleate. Ophthalmology. 89 ;96(1):3-7. Does not address any key questions
Mortada A. Role of pre and post operative diuretics (acetazolamide) when given with tranquilizers (chlorpromazine) for quick formation of anterior chamber with cataract extraction partial penetrating keratoplasty and glaucoma fistulising operations. BULL. OPHTHALMOL. SOC. EGYPT. 73 ;66(70):185-191. It is a case series
Moschos M, Brouzas D, Papantonis F. Extracapsular cataract extraction and posterior chamber lens in the management of phacolytic glaucoma. EUR. J. IMPLANT REFRACTIVE SURG. 93 ; 5(2):145-147. It is combined cataract/glaucoma surgery study published before April 2000
Moss AP, Ritch R, Hargett NA. A comparison of the effects of timolol and epinephrine on the intraocular pressure. AM. J. OPHTHALMOL. 78 ; 86(4):489-495. [pmid: 4414556]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Moss A, Ritch R, Hargett N. Comparison of timolol and epinephrine on intraocular pressure of humans. INVEST. OPHTHALMOL. VIS. SCI. 78 ; 17(Suppl):122. It is not a RCT and has less than 100 patients
Mostafaei A. Augmenting trabeculectomy in glaucoma with subconjunctival mitomycin C versus subconjunctival 5-fluorouracil: a randomized clinical trial. Clin Ophthalmol. status =Nikoukari Ophthalmology University Hospital, Tabriz University of Medical Sciences, Tabriz, Iran. 2011;5:491-4. [pmid: 21573097]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Moster MR, Moster ML. Wipe-out: a complication of glaucoma surgery or just a blast from the past. Am J Ophthalmol. 2005;140(4):705-6. [pmid: 16226523]. No original data (e.g., systematic review, narrative review, editorial, letter)
Moster MR, Leen MM, Gandham S, Sith M, Michael AJ. SUBCONJUNCTIVAL VS. PERIBULBAR ANESTHESIA IN TRABECULECTOMY SURGERY: A PROSPECTIVE, RANDOMIZED STUDY. Meeting abstract
Motolko MA. Comparison of allergy rates in glaucoma patients receiving brimonidine 0.2% monotherapy versus fixed-combination brimonidine 0.2%-timolol 0.5% therapy. Curr Med Res Opin. 2008;24(9):2663-7. [pmid: 18691444]. Other (specify):combination not FDA approved?
Moubayed SP, Hamid M, Choremis J, Li G. An unusual finding of corneal edema complicating selective laser trabeculoplasty. Can J Ophthalmol. 2009;44(3):337-8. [pmid: 19491996]. It is a case series
Moulin F, Haut J. Argon laser trabeculoplasty. Results over 10 years. Foreign language
Moulin F, Haut J. Results of argon laser treatment of 100 eyes with open-angle glaucoma (trabeculoplasty, trabeculoretraction). Foreign language
Moulin F, Haut J. Argon laser trabeculoplasty: a 10-year follow-up. Ophthalmologica. 93 ;207(4):196-201. Does not address any key questions
Moulin F, Ameline B, Redor Y, Bey Boumerzag A, Haut J. Trabeculoretraction by argon laser. 5 and 8-year results. Foreign language
Moulin F, Haut J, Abi Rached J. Late failures of trabeculoplasty. INT. OPHTHALMOL. 87 ;10(1):61-66. Does not address any key questions
Moulin F, Haut J, Le Mer Y, Vidal-Cherbonneau A. Adverse effects and complications of argon laser trabecular retraction: practical results. Foreign language
Moulin F, Le Mer Y, Haut J. Five-year results of the first 159 consecutive phakic chronic open-angle glaucomas treated by argon laser trabeculoplasty. Ophthalmologica. 91 ;202(1):3-9. It is a case series
Mqrula Rafael Vidal, Diniz Filho Alberto, Gomes Roberto de Alencar, Cronemberger SebastiPo, Calixto Nassim. Espessura corneana central e densidade das cqlulas endoteliais corneanas centrais ap£s trabeculectomia com e sem mitomicina C. Foreign language
Muckley ED, Lehrer RA. Late-onset blebitis/endophthalmitis: incidence and outcomes with mitomycin C. Optom Vis Sci. 2004;81(7):499-504. [pmid: 15252348]. OAG can’t be analyzed separately
Muermans M, Faubert J, Overbury O, Balazsi AG. THE ACUTE EFFECTS OF TIMOLOL MALEATE ON TEMPORAL MODULATION FIELDS AND SPATIAL CONTRAST SENSITIVITY. Meeting abstract
Mukhina EA. Experience with simultaneous cataract extraction and trabeculectomy. Foreign language
Mulaney J, Sonty S, Ahmad A, Stewart JA, Stewart WC. Comparison of daytime efficacy and safety of dorzolamide/timolol maleate fixed combination versus latanoprost. Medical KQ 3 or KQ 3 and KQ 6 only
Muller O, Knobel HR. Effectiveness and tolerance of metipranolol--results of a multi-center long-term study in Switzerland. Foreign language
Mundorf TK, Dirks M. Efficacy of Brimonidine Purite 0.15% Compared With Timolol 0.5% in Patients With Glaucoma and Ocular Hypertension. Meeting abstract
Mundorf TK, Noecker R, Earl M. A Multicenter, Investigator-Masked, Randomized Comparison of the IOP-Lowering Efficacy of Bimatoprost 0.03% versus Travoprost 0.004% in African Americans with Glaucoma or Ocular Hypertension. Meeting abstract
Mundorf TK. Brimonidine Outcomes Study Group, I. I. BRIMONIDINE 0.2% VERSUS BETAXOLOL 0.25% AS MEASURED BY THE CLINICAL SUCCESS RATE AND QUALITY OF LIFE EFFECTS IN PATIENTS WITH GLAUCOMA OR OCULAR HYPERTENSION. Meeting abstract
Mundorf TK, Batoosingh AL, Safyan E, Liu CCR. Three-Month Comparison Study of Brimonidine Purite 0.1 % and 0.15% for Reducing IOP in Glaucoma and Ocular Hypertension. Meeting abstract
Mundorf TK, Noecker R, Earl M, Frenkel R. Brimonidine Purite 0.15% versus Dorzolamide 2% Used as Adjunctive Therapy to Latanoprost. Meeting abstract
Mundorf TK, Ogawa T, Naka H, Novack GD, Crockett RS. A 12-month, multicenter, randomized, double-masked, parallel-group comparison of timolol-LA once daily and timolol maleate ophthalmic solution twice daily in the treatment of adults with glaucoma or ocular hypertension. Unique comparators
Mundorf TK, Ogawa T, Novack GD, Crockett RS. US ISTALOL Study Group. A Double-masked, Randomized, Parallel Study of the Safety and Efficacy of Timolol-LA in Patients with Ocular Hypertension or Open-angle Glaucoma. Meeting abstract
Mundorf TK, Rauchman SH, Williams RD, Notivol R. A patient preference comparison of Azarga (brinzolamide/timolol fixed combination) vs Cosopt (dorzolamide/timolol fixed combination) in patients with open-angle glaucoma or ocular hypertension. Clin Ophthalmol. 2008;2(3):623-8. [pmid: 19668763]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Mundorf T, Dirks M, Nocker RJ, Earl M. Brimonidine Purite 0.15% versus Timolol 0.5% as Adjunctive Therapy with Lipids. Meeting abstract
Mundorf T, Noecker RJ, Earl ML. A Multicenter, Randomized, Investigator-Masked Comparison of the Efficacy of Bimatoprost 0.03% versus Travoprost 0.004% in African Americans with Glaucoma or Ocular Hypertension. Meeting abstract
Mundorf T, Wilcox KA, Ousler GW 3rd, Welch D, Abelson MB. Evaluation of the comfort of Alphagan P compared with Alphagan in irritated eyes. Adv Ther. 2003;20(6):329-36. [pmid: 15058750]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Mundorf T, Williams R, Whitcup S, Felix C, Batoosingh A. A 3-month comparison of efficacy and safety of brimonidine-purite 0.15% and brimonidine 0.2% in patients with glaucoma or ocular hypertension. Unique comparators
Murchison JF Jr, Shields MB. Limbal-based vs fornix-based conjunctival flaps in combined extracapsular cataract surgery and glaucoma filtering procedure. Am J Ophthalmol. 90 ;109(6):709-15. It is combined cataract/glaucoma surgery study published before April 2000
Murray SB, Jay JL. Trabeculectomy. Its role in the management of glaucoma. Trans Ophthalmol Soc U K. 79 ;99(4):492-4. Does not address any key questions
Murthy SK, Damji KF, Pan Y, Hodge WG. Trabeculectomy and phacotrabeculectomy, with mitomycin-C, show similar two-year target IOP outcomes. Can J Ophthalmol. 2006;41(1):51-9. [pmid: 16462873]. OAG can’t be analyzed separately
Musch DC, Gillespie BW, Lickter PR, Varma R, Skuta GL, Guire KE. CIGTS Study Group. Does Initial Treatment Approach Matter for Newly-Diagnosed Open-Angle Glaucoma? The Differential Role of Baseline Visual Field Severity in Subsequent Loss. Meeting abstract
Musch DC, Gillespie BW, Lichter PR, NIziol LM. Intraocular Pressure Control as a Contributing Factor to Long-Term Visual Field Loss in the Collaborative Initial Glaucoma Treatment Study. Meeting abstract
Musch DC, Gillespie BW, Lichter PR, Niziol LM, Janz NK. Visual field progression in the Collaborative Initial Glaucoma Treatment Study the impact of treatment and other baseline factors. CIGTS--part of 639 now
Musch DC, Gillespie BW, Niziol LM, Cashwell LF, Lichter PR. Factors associated with intraocular pressure before and during 9 years of treatment in the Collaborative Initial Glaucoma Treatment Study. Ophthalmology. 2008;115(6):927-33. [pmid: 17964655]. Other (specify):Study design does not match KQ
Musch DC, Lichter PR, Guire KE, Standardi CL. The Collaborative Initial Glaucoma Treatment Study: study design, methods, and baseline characteristics of enrolled patients. Ophthalmology. 99 ;106(4):653-62. Other (specify):link to CIGTS
Muskens RP, Wolfs RC, Witteman JC, Hofman A, de Jong PT, Stricker BH, Jansonius NM. Topical beta-blockers and mortality. Ophthalmology. 2008;115(11):2037-43. [pmid: 18801580]. OAG can’t be analyzed separately
Mwanza JC, Kabasele PM. Trabeculectomy with and without mitomycin-C in a black African population. Eur J Ophthalmol. 2001;11(3):261-3. [pmid: 11681505]. Other (specify):only 82 percent over 40
Nagar M, Luhishi E, Shah N. Intraocular pressure control and fluctuation: the effect of treatment with selective laser trabeculoplasty. Br J Ophthalmol. 2009;93(4):497-501. [pmid: 19106150]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Nagar M, Ogunyomade A, O’Brart DP, Howes F, Marshall J. A randomised, prospective study comparing selective laser trabeculoplasty with latanoprost for the control of intraocular pressure in ocular hypertension and open angle glaucoma. Br J Ophthalmol. 2005;89(11):1413-7. [pmid: 16234442]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Nagar M, Shah N, Luihishi E. Effect of Selective Laser Trabeculoplasty and Prostaglandins on Diurnal 10P Fluctuations: Randomized Clinical Trial. Meeting abstract
Nagasubramanian S, Hitchings RA. Comparison of Apraclonidine and Timolol in Chronic Open-Angle Glaucoma -- Three-Month Study. Meeting abstract
Nagasubramanian S, Bloom J, Poinoosawmy D, Hitchings RA. The effects of a topical acetazolamide preparation on intraocular pressure in patients with ocular hypertension. Glaucoma Update III. 87:255-9. Other (specify):not an FDA drug
Nagasubramanian S, George JL, Honrubia FL, Airaksinen J, Serra M. A THREE-MONTH, TRIPLE-MASKED, ADJUNCTIVE-THERAPY STUDY OF THE EFFICACY AND SAFETY OF BID-DOSED BRINZOLAMIDE 1% OPHTHALMIC SUSPENSION AND DORZOLAMIDE 2% OPHTHALMIC SOLUTION (TRUSOPT) IN THE TREATMENT OF PATIENTS WITH POAG OR OH MAINTAINED ON TIMOLOL THERAPY. Meeting abstract
Nagasubramanian S, Hitchings RA, Demailly P, Chuniaud M, Pannarale MR, Pecori-Giraldi J, Stodtmeister R, Parsons DG. Comparison of apraclonidine and timolol in chronic open-angle glaucoma. A three-month study. Ophthalmology. 93 ;100(9):1318-23. Does not address any key questions
Nagasubramanian S, Sheth GP, Hitchings RA, Stjernschantz J. Intraocular pressure-reducing effect of PhXA41 in ocular hypertension. Comparison of dose regimens. Ophthalmology. 93 ;100(9):1305-11. Does not address any key questions
Nagasubramanian S, Tripathi RC, Poinoosawmy D, Gloster J. Low concentration guanethidine and adrenaline therapy of glaucoma. A preliminary report. TRANS. OPHTHALMOL. SOC. U. K. 76 ;96(1):179-183. Other (specify):not used drugs
Nakamoto K, Yasuda N. Effect of concomitant use of latanoprost and brinzolamide on 24-hour variation of IOP in normal-tension glaucoma. Unique comparators
Nakamoto K, Yasuda N, Nanno M, Fukuda T. Comparison of the effects of latanoprost and timolol gel-forming solution on diurnal variation of intraocular pressure in normal-tension glaucoma. Foreign language
Nakamura Y, Ishikawa S, Nakamura Y, Sakai H, Henzan I, Sawaguchi S. 24-hour intraocular pressure in glaucoma patients randomized to receive dorzolamide or brinzolamide in combination with latanoprost. Clin Ophthalmol. 2009;3:395-400. [pmid: 19688026]. Data not abstractable
Nakano Y, Araie M, Shirato S. Effect of postoperative subconjunctival 5-fluorouracil injections on the surgical outcome of trabeculectomy in the Japanese. Graefes Arch Clin Exp Ophthalmol. 89 ; 227(6):569-74. Other (specify):Mixed glaucomas for analysis of side effects
Nakatani H, Maeda K, Sumie K. The pilocarpine ocusert system. Long-term clinical trials in the management of glaucoma or ocular hypertension. Foreign language
Narayanaswamy A, Neog A, Baskaran M, George R, Lingam V, Desai C, Rajadhyaksha V. A randomized, crossover, open label pilot study to evaluate the efficacy and safety of Xalatan in comparison with generic Latanoprost (Latoprost) in subjects with primary open angle glaucoma or ocular hypertension. Unique comparators
Nassiri N, Nassiri N, Mohammadi B, Rahmani L. Comparison of 2 surgical techniques in phacotrabeculectomy: 1 site versus 2 sites. European journal of ophthalmology. 2010;20(2):316-26. [pmid: 19967669]. OAG can’t be analyzed separately
Nassiri N, Kamali G, Rahnavardi M, Mohammadi B, Nassiri S, Rahmani L, Nassiri N. Ahmed glaucoma valve and single-plate Molteno implants in treatment of refractory glaucoma: a comparative study. Am J Ophthalmol. 2010;149(6):893-902. [pmid: 20451896]. Data not abstractable
Nassiri N, Nassiri N, Mohammadi B, Rahmani L. Comparison of 2 surgical techniques in phacotrabeculectomy: 1 site versus 2 sites. Eur J Ophthalmol. 2010;20(2):316-26. [pmid: 19967669]. Data not abstractable
Naveh N, Kottass R, Glovinsky J, Blumenthal M, Bar-Sever D. The long-term effect on intraocular pressure of a procedure combining trabeculectomy and cataract surgery, as compared with trabeculectomy alone. Ophthalmic Surg. 90 ;21(5):339-45. It is combined cataract/glaucoma surgery study published before April 2000
Naveh-Floman N, Blumenthal M, Belkin M. Complications of medical therapy in glaucoma. Foreign language
Naveh-Floman N, Stahl V, Korczyn AD. Effect of pilocarpine on intraocular pressure in ocular hypertensive subjects. Ophthalmic Res. 86 ;18(1):34-7. No subjects with open-angle glaucoma
Nazm N, Dubey S, Gandhi M, Pegu J. Re: Outcome of raised intraocular pressure in uveitic eyes with and without a corticosteroid-induced hypertensive response. Am J Ophthalmol. 2010;149(3):525-6. author reply 526–7. [pmid: 20172078]. No subjects with open-angle glaucoma, No original data (e.g., systematic review, narrative review, editorial, letter)
Neelakantan A, Rao BS, Vijaya L, Grandham SB, Krishnan N, Priya VS, Murugeshan R. Effect of the concentration and duration of application of mitomycin C in trabeculectomy. Ophthalmic Surg. 94 ;25(9):612-5. It is not a RCT and has less than 100 patients
Neetens A, Rubbens MC, Van Rompaey J, Hendrata Y. Intraocular pressure lowering effect of timolol in the fellow untreated eye. Bull Soc Belge Ophtalmol. 79 ;186:39-46. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Negi AK, Kiel AW, Vernon SA. Does the site of filtration influence the medium to long term intraocular pressure control following microtrabeculectomy in low risk eyes. Br J Ophthalmol. 2004;88(8):1008-11. [pmid: 15258015]. It is not a RCT and has less than 100 patients
Negi A, Thoung D, Dabbous F. Nightmares with topical beta-blocker. Eye (Lond). 2000;14(Pt 5):813-4. [pmid: 11116726]. It is a case series
Nelson ME, Andrzejowski AZ. Systemic hypertension in patients receiving dipivalyl adrenaline for glaucoma. BMJ. 88 ;297(6650):741-2. It is a case series
Nelson WL, Kuritsky JN. Early postmarketing surveillance of betaxolol hydrochloride, September 1985-September 1986. Am J Ophthalmol. 87 ;103(4):592. Other (specify):summary of FDA AE reports; no denominator
Nesher R, Ticho U. Switching from systemic to the topical carbonic anhydrase inhibitor dorzolamide: effect on the quality of life of glaucoma patients with drug-related side effects. Unique comparators
Nesher R, Kass MA, Gans LA. Corneal endothelial changes in ocular hypertensive individuals after long-term unilateral treatment with timolol. Am J Ophthalmol. 90 ;110(3):309-10. [pmid: 7425047]. It is not a RCT and has less than 100 patients
Nesher R, Schwartzenberg T, Ticho U. Comparison of timolol and pilocarpine combination versus concomitant therapy: A 6-month follow-up study. ANN. OPHTHALMOL. GLAUCOMA. 96 ;28(6):390-395. It is not a RCT and has less than 100 patients
Ness T, Funk J. Increase of intraocular pressure after topical administration of prostaglandin analogs. Arch Ophthalmol. 99 ;117(12):1646-7. [pmid: 7283817]. It is a case series
Nesterov AP, Egorov EA, Babushkin AE, Kolesnikova LN. Trabeculectomy with laminar resection of the sclera in the treatment of primary open-angle glaucoma. Foreign language
Netland PA, Kenneth Sullivan EK. EFFECT OF TRAVOPROST ON IOP IN BLACK AND NON-BLACK PATIENTS WITH OCULAR HYPERTENSION AND OPEN-ANGLE GLAUCOMA IN A TWELVE-MONTH STUDY. Meeting abstract
Netland PA, Landry T, Silver LH, Sullivan EK, Andrew R, Weiner AL, Bergamini MVW, Robertson SM, Mallick S, Davis AA. Travoprost Study Group. IOP-lowering efficacy and safety of travoprost compared to latanoprost and timolol in patients with open-angle glaucoma or ocular hypertension. Meeting abstract
Netland PA. Travoprost Study Group. SAFETY AND EFFICACY OF TRAVOPROST IN THE TREATMENT OF OPENANGLE GLAUCOMA OR OCULAR HYPERTENSION IN COMPARISON WITH LATANOPROST AND TIMOLOL. Meeting abstract
Netland PA, Landry T, Sullivan EK, Andrew R, Silver L, Weiner A, Mallick S, Dickerson J, Bergamini MV, Robertson SM, Davis AA. Travoprost compared with latanoprost and timolol in patients with open-angle glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Netland PA, Michael M, Rosner SA, Katzman B, Macy JI. Brimonidine Purite and bimatoprost compared with timolol and latanoprost in patients with glaucoma and ocular hypertension. Adv Ther. 2003;20(1):20-30. [pmid: 12772815]. Other (specify):excluded drug
Netland PA, Robertson SM, Sullivan EK, Silver L, Bergamini MV, Krueger S, Weiner AL, Davis AA. Response to travoprost in black and nonblack patients with open-angle glaucoma or ocular hypertension. Medical KQ 3 only
Netland PA, Schwartz B, Feke GT, Takamoto T, Konno S, Goger DG. Diversity of response of optic nerve head circulation to timolol maleate in gel-forming solution. Medical KQ 3 or KQ 3 and KQ 6 only
Netland PA, Shapiro A, Chapin M. DUAL THERAPY USING BRIMONIDINE WITH LATANOPROST COMPARED TO TIMOLOL-DORZOLAMIDE COMBINATION THERAPY. Meeting abstract
Netland PA, Sullivan EK, Bergamini MVW, Weiner AL, Landry TA, Robertson SM. Central Corneal Thickness of Black and Non-Black Patients with Open-Angle Glaucoma or Ocular Hypertension and IOP Response to Travoprost 0.004% Therapy. Meeting abstract
Netland PA, Weiss HS, et al. Cardiovascular effects of topical carteolol hydrochloride and timolol maleate in patients with ocular hypertension and primary open-angle glaucoma. Duplicate
Netland P, Landry T, Sullivan E, Andrew R, Silver L, Weinger A, Mallick S, Dickerson J, Bergamini M, Robertson S, Davis A. Travoprost compared with Latanoprost and Timolol as primary therapy. Meeting abstract
Nguyen QH, Budenz DL, Parrish RK 2nd. Complications of Baerveldt glaucoma drainage implants. Arch Ophthalmol. 98 ;116(5):571-5. OAG can’t be analyzed separately
Nguyen TQT, Rioux N, Lesk MR, Assalian A, Amyot M, Desjardins DC, Duperre J. DIURNAL VARIATION OF INTRAOCULAR PRESSURE IN GLAUCOMA PATIENTS TAKING COMBINATION TIMOLOL-PILOCARPINE (TIMPILO) THERAPY b.i.d. Meeting abstract
Nguyen TYT, Boisjoly HM, Giasson C, Charest M, Amyot M, Lesk M, Assalian A, Rioux N. CORNEAL HYDRATION CONTROL AFTER SHORT-TERM USE OF TRUSOPT. Meeting abstract
Niazi MK, Raja N. Comparison of latanoprost and dorzolamide in the treatment of patients with open angle glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Niedermeier S. Bivalent vegetative glaucoma therapy. Foreign language
Nielsen NV. A diurnal study of the ocular hypotensive effect of metoprolol mounted on ophthalmic rods compared to timolol eye drops in glaucoma patients. Acta Ophthalmol (Copenh). 81 ;59(4):495-502. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Nielsen NV, Eriksen JS. Timolol and metoprolol in glaucoma. A comparison of the ocular hypotensive effect, local and systemic tolerance. Acta Ophthalmol (Copenh). 81 ;59(3):336-46. Other (specify):Metoprolol not an intervention of interest
Nielsen NV, Eriksen JS. Timolol and metoprolol. A diurnal study of the ocular and systemic effects in glaucoma patients. Acta Ophthalmol (Copenh). 81 ;59(4):517-25. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Nielsen NV. The ocular hypotensive effect of timolol in long-term treatment of glaucoma. A 4 year study. Acta Ophthalmol (Copenh). 82 ;60(6):961-6. It is not a RCT and has less than 100 patients
Nielsen NV, Eriksen JS, Larsen G, Mortensen KK, Kemp A, Andersen F, Buhl H, Olsen J, Dalsgard C, Frandsen E, Vase I, Glissov B, Pugesgaard T, Jensen S, Heuer HE. Timolol eye drops in the treatment of glaucoma and ocular hypertension. A multicentre study. Foreign language
Nielsen PG, Ahrendt N, Buhl H, Byrn E. Metoprolol eyedrops 3%, a short-term comparison with pilocarpine and a five-month follow-up study. (Multicenter). Acta Ophthalmol (Copenh). 82 ;60(3):347-52. Other (specify):pilocarpine
Nino M, Balato A, Ayala F, Balato N. Allergic contact dermatitis due to levobunolol with cross-sensitivity to befunolol. Contact Dermatitis. 2007;56(1):53-4. [pmid: 17177718]. Does not address any key questions
Nino M, Napolitano M, Scalvenzi M. Allergic contact dermatitis due to the beta-blocker betaxolol in eyedrops, with cross-sensitivity to timolol. Contact Dermatitis. 2010;62(5):319-20. [pmid: 20536484]. It is a case series
Nixon DR, Hollander D. Comparison of the Efficacy and Tolerability of Twice-Daily Combigan vs. Cosopt Fixed-Combination Therapies. Meeting abstract
Nixon DR. Evaluation of the Safety and Efficacy of Brimonidine Tartrate-Timolol Maleate Ophthalmic Solution (Combigan®)and Dorzolamide Hydrochloride-Timolol Maleate Ophthalmic Solution (Cosopt®) in Patients with Open-Angle Glaucoma or Ocular Hypertension. Meeting abstract
Nixon DR, Yan DB, Hollander DA. Randomized, Parallel Comparison of the Efficacy and Tolerability of Twice-Daily 0.2% Brimonidine/0.5% Timolol (Combigan®) vs. 2.0% Dorzolamide/0.5% Timolol (Cosopt®) Fixed Combination Therapies in Patients with Glaucoma or Ocular Hypertension. Meeting abstract
Nixon DR, Yan DB, Chartrand JP, Piemontesi RL, Simonyi S, Hollander DA. Three-month, randomized, parallel-group comparison of brimonidine-timolol versus dorzolamide-timolol fixed-combination therapy. Medical KQ 3 or KQ 3 and KQ 6 only
Nixon DR, Yan DB, Chartrand JP, Piemontesi RL, Simonyi S, Hollander DA. Three-month, randomized, parallel-group comparison of brimonidine-timolol versus dorzolamide-timolol fixed-combination therapy. Systematic review
Noben KJ, Linsen MC, Zeyen TG. Is combined phacoemulsification and trabeculectomy as effective as trabeculectomy alone?. Bull Soc Belge Ophtalmol. 98 ;270:85-90. It is combined cataract/glaucoma surgery study published before April 2000
Noecker R. Intraocular pressure-lowering efficacy of bimatoprost 0.03% and travoprost 0.004% in patients with glaucoma or ocular hypertension. Br J Ophthalmol. 2006;90(11):1336-7. [pmid: 17057169]. No original data (e.g., systematic review, narrative review, editorial, letter)
Noecker RJ, Bulau SA. COMPARISON OF EFFICACY OF ALPHAGAN VERSUS TRUSOPT IN MEXICAN-AMERICANS. Meeting abstract
Noecker RJ, Earl M. Comparison of the IOP-Lowering Efficacy of Bimatoprost and Travoprost in Black Patients With Glaucoma or Ocular Hypertension. Meeting abstract
Noecker RJ. Brimonidine.2% as a replacement for beta blockers in geriatric patients with glaucoma. Adv Ther. 2002;19(2):91-7. [pmid: 12069372]. OAG can’t be analyzed separately
Noecker RJ. Evaluation of Bimatoprost 0.03% versus Latanoprost 0.005%: A Paired Comparison Study. Meeting abstract
Noecker RJ, Dirks M, Mundorf T, Williams R, Earl M. Evaluation of Bimatoprost 0.03% versus Latanoprost 0.005%: A Bilateral Monocular Trial. Meeting abstract
Noecker RJ, Earl ML, Mundorf TK, Silverstein SM, Phillips MP. Comparing bimatoprost and travoprost in black Americans. Medical KQ 3 or KQ 3 and KQ 6 only
Noecker RJ, Earl ML, Mundorf T, Peace J, Williams RD. Bimatoprost 0.03% versus travoprost 0.004% in black Americans with glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Noecker RS, Dirks MS, Choplin N. Comparison of latanoprost, bimatoprost, and travoprost in patients with elevated intraocular pressure: a 12-week, randomized, masked-evaluator multicenter study. Am J Ophthalmol. 2004;137(1):210-1. author reply 211–2. [pmid: 14700685]. No original data (e.g., systematic review, narrative review, editorial, letter)
Noecker RS, Dirks MS, Choplin NT, Bernstein P, Batoosingh AL, Whitcup SM. A six-month randomized clinical trial comparing the intraocular pressure-lowering efficacy of bimatoprost and latanoprost in patients with ocular hypertension or glaucoma. KQ 3 medical
Noecker R, Bulau S, Kay J. EFFICACY AND TOLERABILITY OF ALPHAGAN AND TRUSOPT IN MEXICAN-AMERICAN PATIENTS WITH GLAUCOMA OR OCULAR HYPERTENSION. Meeting abstract
Nomura Y, Nakakura S, Moriwaki M, Takahashi Y, Shiraki K. Effect of travoprost on 24-hour intraocular pressure in normal tension glaucoma. 2010;4(1):643-647. It is not a RCT and has less than 100 patients
Norden LC. Adverse reactions to topical ocular autonomic agents. J Am Optom Assoc. 78 ;49(1):75-80. No original data (e.g., systematic review, narrative review, editorial, letter)
Nordmann JP, Auzanneau N, Ricard S, Berdeaux G. Vision related quality of life and topical glaucoma treatment side effects. Health Qual Life Outcomes. 2003:75. [pmid: 14667241]. Data not abstractable
Nordmann JP, Baudouin C, Bron A, Denis P, Rouland JF, Sellem E, Renard JP. Xal-Ease: impact of an ocular hypotensive delivery device on ease of eyedrop administration, patient compliance, and satisfaction. Unique comparators
Nordmann JP, Baudouin C, Renard JP, Denis P, Lafuma A, Laurendeau C, Jeanbat V, Berdeaux G. Measurement of treatment compliance using a medical device for glaucoma patients associated with intraocular pressure control: a survey. Clin Ophthalmol. 2010;4:731-9. [pmid: 20689790]. Does not address any key questions (see below for questions), Data not abstractable
Nordmann JP, Lepen C, Lilliu H, Berdeaux G. Estimating the long-term visual field consequences of average daily intraocular pressure and variance : a clinical trial comparing timolol, latanoprost and travoprost. Clin Drug Investig. 2003;23(7):431-8. Data not abstractable
Nordmann JP, Mertz B, Yannoulis NC, Schwenninger C, Kapik B, Shams N. A double-masked randomized comparison of the efficacy and safety of unoprostone with timolol and betaxolol in patients with primary open-angle glaucoma including pseudoexfoliation glaucoma or ocular hypertension. 6 month data. Am J Ophthalmol. 2002;133(1):1-10. [pmid: 11755834]. Other (specify):unoprostone
Nordmann JP, Rouland JF, Mertz BP. A comparison of the intraocular pressure-lowering effect of 0.5% timolol maleate and the docosanoid derivative of a PGF2 alpha metabolite, 0.12% unoprostone, in subjects with chronic open-angle glaucoma or ocular hypertension. Curr Med Res Opin. 99 ;15(2):87-93. Other (specify):unoprostone and PGF2
Nordmann JP, Soderstrom M, Rouland JF, Malecaze F. Comparison of the intraocular pressure lowering effect of latanoprost and a fixed combination of timolol-pilocarpine eye drops in patients insufficiently controlled with beta adrenergic antagonists. French Latanoprost Study Group, and the Swedish Latanoprost Study Group. Br J Ophthalmol. 2000;84(2):181-5. [pmid: 10655195]. Other (specify):Pilocarpine excluded
Nordmann J-P, Baudouin C, Bron A, Denis P, Rouland J-F, Sellem E, Renard J-P. Xal-Ease(registered trademark): Impact of an ocular hypotensive delivery device on ease of eyedrop administration, patient compliance, and satisfaction. Duplicate
Nordmann J-P, Soderstrom M, Rouland J-F, Malecaze F. Comparison of the intraocular pressure lowering effect of latanoprost and a fixed combination of timolol-pilocarpine eye drops in patients insufficiently controlled with (beta) adrenergic antagonists. Duplicate
Norell SE, Granstrom PA. Self-medication with pilocarpine among outpatients in a glaucoma clinic. Br J Ophthalmol. 80 ;64(2):137-41. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Norell S. Medication behaviour. A study of outpatients treated with pilocarpine eye drops for primary open-angle glaucoma. Acta Ophthalmol Suppl. 80(143):1-28. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Norris Eleonore J, Schiffman Joyce C, Palmberg Paul F, Mello Paulo Augusto de Arruda. Resultado a longo prazo do uso de drogas antiproliferativas na trabeculectomia primbria. Foreign language
Noske W, Pahlitzsch T, Kirchner J. Effect of indomethacin on the ocular hypertension after cataract extraction. A double-blind study. EFFET DE L’INDOMETACINE SUR L’HYPERTENSION OCULAIRE APRES OPERATION DE LA CATARACTE. ETUDE EN DOUBLE AVEUGLE. Foreign language
Nouri-Mahdavi K, Caprioli J. Evaluation of the hypertensive phase after insertion of the Ahmed Glaucoma Valve. Am J Ophthalmol. 2003;136(6):1001-8. [pmid: 14644209]. Data not abstractable
Novack GD, David R, Lee PF, Freeman MI, Duzman E, Batoosingh AL. Effect of changing medication regimens in glaucoma patients. Medical KQ 3 or KQ 3 and KQ 6 only
Novack GD, Kelley EP, Lue JC. A multicenter evaluation of levobunolol (Vistagan) in Germany. Ophthalmologica. 88 ;197(2):90-6. It is a case series
Novack GD, Mundorf TK, Ogawa T, Crockett RS. US/ISTALOL Study Group. Randomized, Controlled, One-Year Treatment Comparison of Timolol-LA (ISTALOL™) Given q.d. vs Timolol Maleate Solution Given b.i.d. in Patients With Ocular Hypertension or Open-Angle Glaucoma. Meeting abstract
Novak S, Stewart RH. The Ocusert system in the management of glaucoma. Tex Med. 75 ;71(12):63-5. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Novak-Laus K, Mandic Z, Ivekovic R, Korsic J, Tedeschi-Reiner E, Masnec-Paskvalin S, Bojic L. Trabeculectomy with mitomycin C in glaucoma associated with uveitis. Coll Antropol. 2005;29(Suppl 1):17-20. [pmid: 16193669]. No subjects with open-angle glaucoma
Novakovic A, Vujosevic E, Alajbegovic R, Hodzic S. 2 years’ administration of timolol to patients with chronic open-angle glaucoma. Foreign language
Nowroozzadeh MH, Razeghinejad MR. Brimonidine and eye pressure. Ophthalmology. 2010;117(7):1463. author reply 1463–4. [pmid: 20610002]. No original data (e.g., systematic review, narrative review, editorial, letter)
Nowroozzadeh MH. Impact of oncedaily versus twice daily application of adjunctive timolol on the intraocular pressure-lowering effect of latanoprost. Ophthalmic Res. 2010;44(2):140. [pmid: 20516726]. No original data (e.g., systematic review, narrative review, editorial, letter)
Nuzzi R, Finazzo C, Cerruti A. Adverse effects of topical antiglaucomatous medications on the conjunctiva and the lachrymal (Brit. Engl) response. Excluded drug
Nyman K. Intraocular pressure reduction with topically administered pilocarpine, timolol and betaxolol in normal tension glaucoma. Acta Ophthalmol (Copenh). 93 ;71(5):686-90. It is not a RCT and has less than 100 patients
Oancea I, Pop R, Calugaru M, Grigorescu R, Vladutiu C, Sandovici EM, Popa L, Marin C, Lazarov E, Trif V. Early results following trabeculectomy at the Cluj-Napoca Ophthalmological Clinic. Foreign language
Ober M, Scharrer A. The effect of timolol and parasympathicomimetica in the treatment of the elevated intraocular pressure (author’s transl). Albrecht Von Graefes Arch Klin Exp Ophthalmol. 79 ;211(1):59-66. It is not a RCT and has less than 100 patients
Ober MD, Lemon LC, Shin DH, Nootheti P, Cha SC. A Long-Term Comparative Study of Silicone versus Acrylic Intraocular Lens in Phaco-Trabeculectomy. Meeting abstract
Ober M, Scharrer A, Dausch D. Guanethidine/dipivefrin and pilocarpine in the treatment of increased intraocular pressure. Klin Monbl Augenheilkd. 87 ;190(2):103-4. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Ober M, Scharrer A, David R. Long-term ocular hypotensive effect of levobunolol: Results of a one-year study. Medical KQ 3 or KQ 3 and KQ 6 only
Ober M, Scharrer A, Novack GD, Lue JC. Local subjective tolerance of levobunolol and metipranolol in a double-blind comparative study in patients with increased intraocular pressure. Ophthalmologica. 86 ;192(3):159-64. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
O’Brart DP, Rowlands E, Islam N, Noury AM. A randomised, prospective study comparing trabeculectomy augmented with antimetabolites with a viscocanalostomy technique for the management of open angle glaucoma uncontrolled by medical therapy. Cheng 2009 and Chai 2010
O’Brart DP, Shiew M, Edmunds B. A randomised, prospective study comparing trabeculectomy with viscocanalostomy with adjunctive antimetabolite usage for the management of open angle glaucoma uncontrolled by medical therapy. Cheng 2009 and Chai 2010
O’Brart D, Noury S, Rowlands E, Islam N. A prospective, randomized study to compare Trabeculectomy with Viscocanalostomy technique for the management of open angle glaucoma uncontrolled by medical therapy. Meeting abstract
O’Brart D, Rowlands E, Islam N. A randomised, prospective study comparing trabeculectomy with viscocanalostomy for the management of open angle glaucoma uncontrolled by medical therapy: 12 month follow-up. Meeting abstract
Obstbaum SA, Galin MA, Katz IM. Timolol: Effect on intraocular pressure in chronic open-angle glaucoma. Duplicate
Obstbaum SA, Galin MA, Katz IM. Trimolol: effect on intraocular pressure in chronic open-angle glaucoma. Ann Ophthalmol. 78 ;10(10):1347-51. Does not address any key questions
Obstbaum SA, Kolker AE, Phlps CD. Low dose epinephrine. Effct on intraocular pressure. ARCH. OPHTHALMOL. 74 ;92(2):118-120. Other (specify):not used as a drug at present
O’Connor D, Caprioli J. Indications for postoperative fluorouracil therapy. Arch Ophthalmol. 92 ;110(1):25. No original data (e.g., systematic review, narrative review, editorial, letter)
O’Connor GR. Granulomatous uveitis and metipranolol. Br J Ophthalmol. 93 ;77(8):536-8. No original data (e.g., systematic review, narrative review, editorial, letter)
Odberg T, Sandvik L. The medium and long-term efficacy of primary argon laser trabeculoplasty in avoiding topical medication in open angle glaucoma. Acta Ophthalmol Scand. 99 ;77(2):176-81. It is a case series
Odberg T. The effect of long-term medical therapy on the outcome of filtration surgery. Am J Ophthalmol. 94 ;118(4):537-8. No original data (e.g., systematic review, narrative review, editorial, letter)
Oddone F, Manni G, Parravano M, Cupo G, Costa G, Bucci MG. Six-Months Comparison of the Efficacy and Safety of Bimatoprost 0.03% Versus the Association of Timolol 0.5% and Latanoprost 0.005%. Meeting abstract
O’Donnell BF, Foulds IS. Contact allergy to beta-blocking agents in ophthalmic preparations. Contact Dermatitis. 93 ;28(2):121-2. It is a case series
O’Donoghue EP. A comparison of latanoprost and dorzolamide in patients with glaucoma and ocular hypertension: a 3 month, randomised study. Ireland Latanoprost Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
O’Donoghue EP. A comparison of latanoprost and dorzolamide in patients with glaucoma and ocular hypertension: A 3 month, randomised study. Medical KQ 3 or KQ 3 and KQ 6 only
O’Donoghue EP. STRONTIUM 90 VS 5-FU AS ADJUNCT TO SURGERY FOR PATIENTS AT HIGH RISK OF TRABECULECTOMY FAILURE: A PROSPECTIVE RANDOMISED TRIAL. Meeting abstract
O’Donoghue EP, Saunders DC, Ayliffe W, Ridgway AEA. STRONTIUM 90 VS 5-FU AS ADJUNCT TO SURGERY FOR PATIENTS AT HIGH RISK OF TRABECULECTOMY FAILURE: A PROSPECTIVE RANDOMISED TRIAL. Meeting abstract
Offret H, Bechetoille A. Medical treatment of wide-angle chronic glaucoma. Foreign language
Ogawa T, Dake Y, Saitoh AK, Deguchi HE, Koyanagi Y, Yamashita M, Kuroki AM, Motoda M, Amemiya T. Improved nonpenetrating trabeculectomy with trabeculotomy. J Glaucoma. 2001;10(5):429-35. [pmid: 11711844]. It is not a RCT and has less than 100 patients
O’Grady JM, Juzych MS, Shin DH, Lemon LC, Swendris RP. Trabeculectomy, phacoemulsification, and posterior chamber lens implantation with and without 5-fluorouracil. Am J Ophthalmol. 93 ; 116(5):594-9. [pmid: 6177246]. It is combined cataract/glaucoma surgery study published before April 2000
O’Grady J, Juzych M, Shin D, Swendris R, Parrow K, Stewart D. GLAUCOMA TRIPLE PROCEDURE WITH AND WITHOUT ADJUNCTIVE 5 FLUOROURACIL. Meeting abstract
Oguz H. Mitomycin C Molteno tube implantation. Clin Experiment Ophthalmol. 2003;31(5):458. author reply 458–9. [pmid: 14516442]. No original data (e.g., systematic review, narrative review, editorial, letter)
Oh JY, Park KH. The effect of latanoprost on intraocular pressure during 12 months of treatment for normal-tension glaucoma. Korean J Ophthalmol. 2005;19(4):297-301. [pmid: 16491821]. It is not a RCT and has less than 100 patients
Oh SY, Youn DH, Kim DM, Hong C. The effects of intraoperative mitomycin-C or 5-fluorouracil on glaucoma filtering surgery. Korean J Ophthalmol. 94 ;8(1):6-13. It is not a RCT and has less than 100 patients
Ohrstrom A, Kattstrom O, Polland W, Mortensen J, Stenstrom B. Oral and topical adrenergic beta-receptor blockers in glaucoma treatment. A multicenter study. Excluded drug
Ohta H, Uji Y, Hattori Y, Sugimoto M, Higuchi K. Seasonal variation of intraocular pressure after trabeculotomy. Foreign language
Ohtake Y, Tanino T, Kimura I, Mashima Y, Oguchi Y. Long-term efficacy and safety of combined topical antiglaucoma therapy--timolol & unoprostone vs. betaxolol & unoprostone. Foreign language
Oksala A, Salminen L. Influence of pilocarpine on ocular tension in new chronic glaucoma cases. Foreign language
Oksala A, Salminen L. Tachyphylaxis in chronic timolol-treated glaucoma. Foreign language
Oksala A, Salminen L, Palkama A. Comparative study of timolol and pilocarpine in chronic glaucoma. Foreign language
Olander KW, Galet VA, Jia G, Smugar SS, Stewart WC. Relationship between visual field severity and response to fixed combination dorzolamide/timolol or timolol alone. J Ocul Pharmacol Ther. 2009;25(4):357-64. [pmid: 19441888]. Other (specify):post hoc analysis
Olander K, Zimmerman TJ, Downes N, Schoenfelder J. Switching from latanoprost to fixed-combination latanoprost-timolol: a 21-day, randomized, double-masked, active-control study in patients with glaucoma and ocular hypertension. Clin Ther. 2004;26(10):1619-29. [pmid: 15598478]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Olivalves Edilberto, Olivalves Stella, Tortelli Liliane. Comparagåo do efeito do maleato de timolol e pilocarpina na queda da pressåo intraocular. Foreign language
Oliveira Maria Vitoria F de, Brasil Oswaldo Ferreira Moura, Gongalves Isabela, Meirelles Sqrgio Henrique Sampaio, Costa Filho Adroaldo de Alencar Costa. UtilizagPo do laser de argónio no extravasamento da bolha filtrante. Foreign language
Oliver JE, Hattenhauer MG, Herman D, Hodge DO, Kennedy R, Fang-Yen M, Johnson DH. Blindness and glaucoma: a comparison of patients progressing to blindness from glaucoma with patients maintaining vision. Am J Ophthalmol. 2002;133(6):764-772. [pmid: 12036667]. Does not address any key questions
Olivier M, Bartlett J, Richardson T, Whitaker R, Greenidge K, Pensyl D. OCULAR AND SYSTEMIC TOLERABILITY OF CARTEOLOL AND TIMOLOL IN POSTMENOPAUSAL BLACK WOMEN WITH PRIMARY OPEN-ANGLE GLAUCOMA OR OCULAR HYPERTENSION. Meeting abstract
Ollila M, Falck A, Airaksinen PJ. Placing the Molteno implant in a long scleral tunnel to prevent postoperative tube exposure. Acta Ophthalmol Scand. 2005;83(3):302-5. [pmid: 15948781]. OAG can’t be analyzed separately
Omi Carlos, Akira Almeida, Geraldo Vicente de, Belfort Mattos Rubens. Estudo duplo mascarado sobre o uso t£pico de levobunolol e maleato de timolol em pacientes com glaucoma crónico simples ou hipertenso ocular. Foreign language
Ong LB, Liza-Sharmini AT, Chieng LL, Cheong MT, Vengadasalam SR, Shin HC, Balaravi P. The efficacy of timolol in gel-forming solution after morning or evening dosing in Asian glaucomatous patients. J Ocul Pharmacol Ther. 2005;21(5):388-94. [pmid: 16245965]. It is a case series
Onol M, Aktas Z, Hasanreisoglu B. Enhancement of the success rate in trabeculectomy: large-area mitomycin-C application. Clin Experiment Ophthalmol. 2008;36(4):316-22. [pmid: 18700917]. It is not a RCT and has less than 100 patients
Opitz D, Tung S, Park J, Jang U. SILICONE PUNCTAL PLUGS AS AN ADJUNCTIVE THERAPY TO TRAVOPROST 0.004% OPHTHALMIC SOLUTION IN PRIMARY OPEN ANGLE GLAUCOMA AND OCULAR HYPERTENSION. Foreign language
Orcelli L. The influence of previous medical therapy on the success of trabeculectomy. Influenza della protratta terapia medica sul successo della trabeculectomia. Foreign language
Orchard RT, Taylor DJ, Parkins RA. Sulphonamide crystalluria with acetazolamide. Br Med J. 72(5827):646. It is a case series
Orengo-Nania S. Travoprost Study Group. TRAVOPROST IS EFFECTIVE ADJUNCTIVE THERAPY IN PATIENTS WITH UNCONTROLLED IOP WHILE USING TIMOPTIC 0.5%. Meeting abstract
Orengo-Nania SD, Landry T, Von Tress M, Silver LH, Dickerson J, Weiner AL, Davis AA. Travoprost Study Group. Travoprost significantly decreased IOP in patients with open-angle glaucoma or ocular hypertension when used adjunctively with timolol. Meeting abstract
Orengo-Nania SD, Gross RL, Mallick S, Wells DT, Sullivan EK, Landry TA. Pooled Results of Two Randomized Clinical Trials Comparing the Efficacy and Safety of Travoprost 0.004%/Timolol 0.5% in Fixed Combination Versus Concomitant Travoprost 0.004% and Timolol 0.5%. Meeting abstract
Orengo-Nania S, Landry T, Von Tress M, Silver LH, Weiner A, Davis AA. Evaluation of travoprost as adjunctive therapy in patients with uncontrolled intraocular pressure while using timolol 0.5%. Medical KQ 3 or KQ 3 and KQ 6 only
Orengo-Nania S, Oram O, Severin TD, Gross RL. EFFECT OF ATROPINE ON CENTRAL AND PERIPHERAL ANTERIOR CHAMBER DEPTH AND ANTERIOR CHAMBER ANGLE AFTER TRABECULECTOMY. Meeting abstract
Orme M, Collins S, Dakin H, Kelly S, Loftus J. Mixed treatment comparison and meta-regression of the efficacy and safety of prostaglandin analogues and comparators for primary open-angle glaucoma and ocular hypertension. Systematic review
Ornek K, Onaran Z, Turgut Y. Anterior uveitis associated with fixed-combination latanoprost and timolol. Can J Ophthalmol. 2008;43(6):727-8. [pmid: 19020649]. It is a case series
Ortiz Arismendi GE, Nova Gloria M. SÆndrome de Axenfeld-Rieger con glaucoma bilateral y descompensaci£n de cornea en ojo izquierdo. Foreign language
Ortiz Gonzblez Elier, Miqueli RodrÆguez Maritza, Gonzblez GarcÆa Alberto Omar. Estudio del brea quir·rgica en pacientes trabeculectomizados. Foreign language
Orzalesi N, Rossetti I, Bottoli A, Invernizzi T, Fumagalli E, Fogagnolo P. Comparison of latanoprost, brimonidine and a fixed combination of timolol and dorzolamide on circadian intraocular pressure in patients with primary open-angle glaucoma and ocular hypertension. Acta Ophthalmol Scand Suppl. 2002;236:55. [pmid: 12390144]. Data not abstractable
Orzalesi N, Rossetti L, Bottoli A, Fogagnolo P. Comparison of the Effect of Latanoprost, Travoprost, and Bimatoprost on Circadian Intraocular Pressure in Patients with Glaucoma or Ocular Hypertension. Meeting abstract
Orzalesi N, Rossetti L, Bottoli A, Fumagalli E, Fogagnolo P. The effect of latanoprost, brimonidine, and a fixed combination of timolol and dorzolamide on circadian intraocular pressure in patients with glaucoma or ocular hypertension. Arch Ophthalmol. 2003;121(4):453-7. [pmid: 12695241]. Other (specify):study design does not match KQ (KQ3)
Orzalesi N, Rossetti L, Bottoli A, Invernizzi T, Fumagalli E, Fogagnolo P. Comparison of the effect of latanoprost, brimonidine, and a fixed combination of timolol and dorzolamide on circadian intraocular pressure in patients with glaucoma or ocular hypertension. Meeting abstract
Orzalesi N, Rossetti L, Invernizzi T, Bottoli A. A COMPARISON OF THE EFFECT OF TIMOLOL, LATANOPROST, AND DORZOLAMIDE ON CIRCADIAN INTRAOCULAR PRESSURE IN PATIENTS WITH GLAUCOMA OR OCULAR HYPERTENSION. Meeting abstract
Orzalesi N, Rossetti L, Invernizzi T, Bottoli A, Autelitano A. Effect of timolol, latanoprost, and dorzolamide on circadian IOP in glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Osako M, Asaoka R, Tachibana K, Okano T, Usui M. Evaluation of Corneal Endothelial Cell Reduction Rates After Combined Glaucoma and Cataract Surgery and After Glaucoma Surgery Alone. Meeting abstract
Osborne SA, Montgomery DM, Morris D, McKay IC. Alphagan allergy may increase the propensity for multiple eye-drop allergy. Unique comparators
Ostfeld B, Halevy J, Theodor E. Acetazolamide-induced metabolic acidosis in elderly patients with mild renal failure. Foreign language
Otori Y. Side effects of antiglaucoma eye drops. Foreign language
Otori Y, Tokugawa H, Morimura H, Okada M, Goto H, Miki A, Tano Y. The effect of substituting latanoprost 0.005% for unoprostone 0.12%. Foreign language
Ottaiano Josq Augusto Alves, Moreira Josq Belmiro de Castro, Fudo Aurea, Ueda Eder Masso, Bosso Evandro Portaluppe, Martin Rosana TerWsa Alves Lois. Apraclonidine a 1 por cento em olhos submetidos a trabeculoplastia por laser de argónio. Foreign language
Otto SR, Hoh HR. EFFICACY AND OCULAR TOLERANCE OF TIMOLOL-GEL 01% (T-GEL 01%) ONCE DAILY VERSUS TIMOLOL 0.25% AQUEOUS EYE DROPS TWICE DAILY. Meeting abstract
Ouhadj O, Degheb N, Chergui I, Nouri MT. Late endophthalmitis complicating glaucoma filtering surgery without adjunctive antifibrotic agents. Foreign language
Ourgaud AG. Adverse effects of local medical treatment in glaucoma. Foreign language
Ourgaud AG, Chagnon AM, Roux JJ. Clinical study of a new anti-glaucoma treatment in comparison with pilocarpine. Foreign language
Oya Y, Fujii S, Yoshizawa T, Iwata K. COMPARISON OF NON-PENETRATING LAMELLAR TRAVECULECTOMY WITH PENETRATIN TRABECULECTOMY. Meeting abstract
Ozdemir M, Ozdemir G. Comparison of the intraocular pressure lowering effect of latanoprost and carteolol-pilocarpine combination in newly diagnosed glaucoma. Jpn J Ophthalmol. 2003;47(1):72-6. [pmid: 12586182]. Other (specify):pilocarpine
Ozkurt YB, Sengor T, Evciman T, Haboglu M, Bas G, Aydin S. Administration of the fixed combination of latanoprost 0.005% and timolol 0.5% in glaucoma patients with an intraocular pressure over 30 mmHg. Clin Ophthalmol. 2009:337-339. [pmid: 19668587]. It is not a RCT and has less than 100 patients
Ozturk F, Ermis SS, Inan UU. Comparison of the ocular hypotensive effects of bimatoprost and timolol-dorzolamide combination in patients with elevated intraocular pressure: a 6-month study. KQ 3 RCT
Pab£n Claudia, Fraga Olga, Beaujon Balbi Oscar. Efectos de la dorzolamida latanoprost y combinaci£n dorzolamida-timolol sobre la c£rnea. Foreign language
Pacella E, Pacella F, Cavallotti C, Librando A, Feher J, Pecori-Giraldi J. The combination latanoprost-timolol versus twice daily 0.50% timolol administration either associated or not with latanoprost: efficacy and tolerability in the primary open-angle glaucoma. Eur Rev Med Pharmacol Sci. 2010;14(5):477-80. [pmid: 20556928]. Data not abstractable
Pache M, Wilmsmeyer S, Funk J. Laser surgery for glaucoma: excimer-laser trabeculotomy. Foreign language
Pache M, Wilmsmeyer S, Funk J. Laser surgery for glaucoma: Excimer-laser trabeculotomy. Laserchirurgie und glaukom: Excimer-laser-trabekulotomie. Foreign language
Pager M. Problems in estimating the therapeutic results in glaucoma. Foreign language
Pajic B. Experience with COSOPT, the fixed combination of timolol and dorzolamide, gained in Swiss ophthalmologists’ offices. Curr Med Res Opin. 2003;19(2):95-101. [pmid: 12740152]. OAG can’t be analyzed separately
Pajic B, Pajic-Eggspuehler B, Hafliger IO. Comparison of the effects of dorzolamide/timolol and latanoprost/timolol fixed combinations upon intraocular pressure and progression of visual field damage in primary open-angle glaucoma. Unique comparators
Pakravan M, Yazdani S, Shahabi C, Yaseri M. Superior versus inferior Ahmed glaucoma valve implantation. Ophthalmology. 2009;116(2):208-13. [pmid: 19062098]. Other (specify):Mixed glaucoma
Palanca-Capistrano AM, Hall J, Cantor LB, Morgan L, Hoop J, WuDunn D. Long-term outcomes of intraoperative 5-fluorouracil versus intraoperative mitomycin C in primary trabeculectomy surgery. Ophthalmology. 2009;116(2):185-90. [pmid: 18930550]. OAG can’t be analyzed separately
Paletta Guedes RA, Paletta Guedes VM. Nonpenetrating deep sclerectomy in Brazil: A 3-year retrospective study. Sclerectomie profonde non perforante au Bresil: Etude retrospective sur trois ans. Foreign language
Palmberg P, Kim EE, Kwok KK, Tressler CS. A 12-week, randomized, double-masked study of fixed combination latanoprost/timolol versus latanoprost or timolol monotherapy. Non-FDA-approved drug combination
Palmer SS. Mitomycin as adjunct chemotherapy with trabeculectomy. Ophthalmology. 91 ;98(3):317-21. Data not abstractable
Pan R-G, Chen X-M, Li M, Liu D-J. Trabeculectomy with scleral tunnel treating refractory glaucoma. Foreign language
Pan S-X, Zhao G-Q. Clinical observation of compound trabeculectomy in refractory glaucoma. Foreign language
Pan YI, Damji KF, Rock WJ, Bovell AM, Buhrmann R, Hodge WG. Comparing the Time to Treatment Failure Rate at 1-Year Post-Treatment: Results From a SLT vs. ALT Randomized Clinical Trial. Meeting abstract
Pannarale MR, Virno M, Pecori GJ, Garofalo G, Grechi G. l-Bunolol in the treatment of open-angle glaucoma: double-blind study versus timolol. Bolletino de Oculistica. 88 ;67:3-13. Other (specify):non english
Papachristou GC, Ritch R, Liebmann JM. Gastrointestinal adverse effects of prostaglandin analogues. Arch Ophthalmol. 2008;126(5):732-3. [pmid: 18474790]. It is a case series
Papaconstantinou D, Georgalas I, Karmiris E, Diagourtas A, Koutsandrea C, Ladas I, Apostolopoulos M, Georgopoulos G. Trabeculectomy with OloGen versus trabeculectomy for the treatment of glaucoma: a pilot study. Acta ophthalmologica. 2010;88(1):80-5. [pmid: 19900209]. OAG can’t be analyzed separately
Papaconstantinou DS, Georgopoulos GT, Andreanos DC, Vergados J, Patsea EE, Theodossiadis GP. EFFECT OF TOPICAL BRIMONIDINE ON OCULAR BLOOD FLOW. Meeting abstract
Papaconstantinou DS, Georgopoulos GT, Patsea ES, Chalkiadakis I, Amariotakis A, Maragos A, Iliakis E, Andreanos DG, Moschos M. Results of Combined Phacoemulsification and Trabeculectomy. Meeting abstract
Papaconstantinou D, Georgalas I, Karmiris E, Diagourtas A, Koutsandrea C, Ladas I, Apostolopoulos M, Georgopoulos G. Trabeculectomy with OloGen versus trabeculectomy for the treatment of glaucoma: a pilot study. Acta Ophthalmol. 2010;88(1):80-5. [pmid: 19900209]. Other (specify):Ologen implant not a treatment of interest, Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Papapanos P, Wedrich A, Pfleger T, Menapace R. Induced astigmatism following small incision cataract surgery combined with trabeculectomy. Doc Ophthalmol. 92 ;82(4):361-8. It is combined cataract/glaucoma surgery study published before April 2000
Papendick U, Rappe S. Contribution to the modern drug therapy of various forms of glaucoma. Med Monatsschr. 77 ;31(12):570-5. It is not a RCT and has less than 100 patients
Pappas RM, Pusin S, Higginbotham EJ. Evidence of early change in iris color with latanoprost use. Arch Ophthalmol. 98 ;116(8):1115-6. [pmid: 7387518]. It is a case series
Paranhos J·nior A, Lima MC, Salim S, Caprioli J, Shields MB. Trabeculectomy and optic nerve head topography. Braz. j. med. biol. Res. 2006;39(1):149-155. [pmid: 16400475]. it is not a RCT and has less than 100 patients
Paranhos A, Mendonca M, Silva MJ, Giampani J, Almeida Torres RJ, Della Paolera M, Russ H, Lottenberg CL. Hyperemia reduction after administration of a fixed combination of bimatoprost and timolol maleate to patients on prostaglandin or prostamide monotherapy. J Ocul Pharmacol Ther. 2010;26(6):611-5. [pmid: 21029020]. It is a case series
Paranhos A, Mendonca M, Silva MJ, Giampani J, Torres RJ, Della Paolera M, Russ H, Lottenberg CL. Hyperemia reduction after administration of a fixed combination of bimatoprost and timolol maleate to patients on prostaglandin or prostamide monotherapy. J Ocul Pharmacol Ther. 2010;26:611-5. [pmid: 21029020]. Other (specify):Medication not approved in US
Paranhos A, Spadaro F, Queiroz CM, Sagawa APG, Avila MP. Effects of Topical Indomethacin in Patients With Open Angle Glaucoma on Bimatoprost 0,03%. Meeting abstract
Parfenov IS, Petukhov VM. Effectiveness of trabeculectomy in primary glaucoma. Foreign language
Parihar JKS, Gupta RP, Sahoo PK, Misra RP, Vats DP, Kamath AP, Rodrigues FEA. Phacotrabeculectomy versus conventional combined technique in coexisting glaucoma and cataract. Med J Armed Forces India. 2005;61(2):139-142. It is not a RCT and has less than 100 patients
Paris G, Trigo Y, Pena M, Sanford D, Weber A, Sponsel WE. Pulsatile ocular blood flow responses to latanoprost or brimonidine, alone and in combination with oral indomethacin. Meeting abstract
Park HJ, Weitzman M, Caprioli J. Temporal corneal phacoemulsification combined with superior trabeculectomy. A retrospective case-control study. Arch Ophthalmol. 97 ;115(3):318-23. It is combined cataract/glaucoma surgery study published before April 2000
Park HY, Lee NY, Park CK. Risk factors of shallow anterior chamber other than hypotony after Ahmed glaucoma valve implant. J Glaucoma. 2009;18(1):44-8. [pmid: 19142134]. Other (specify):Mixed glaucoma
Park J, Cho HK, Moon JI. Changes to upper eyelid orbital fat from use of topical bimatoprost, travoprost, and latanoprost. Jpn J Ophthalmol. 2011;55:22-7. [pmid: 21331688]. It is not a RCT and has less than 100 patients
Park M, Hayashi K, Takahashi H, Tanito M, Chihara E. Phaco-viscocanalostomy versus phaco-trabeculotomy: a middle-term study. J Glaucoma. 2006;15(5):456-61. [pmid: 16988610]. Other (specify):Study design does not match KQ
Park M, Tanito M, Nishikawa M, Hayashi K, Chichara E. Combined viscocanalostomy and cataract surgery compared with cataract surgery in Japanese patients with glaucoma. J Glaucoma. 2004;13(1):55-61. [pmid: 14704545]. Other (specify):study design does not match KQ (3)
Park M, Tanito M, Takahashi H, Chihara E. Does the adjunctive peeling of juxtacanalicular tissue affect the outcome of two-site phaco-viscocanalostomy. J Glaucoma. 2005;14(3):224-9. [pmid: 15870606]. It is not a RCT and has less than 100 patients
Park M, Tanito M, Takahashi K, Chihara E. Combined cataract surgery and viscocanalostomy versus Combined cataract surgery and viscocanalostomy with nonpenetrating trabeculectomy. Meeting abstract
Parmaksiz S, Yuksel N, Karabas VL, Ozkan B, Demirci G, Caglar Y. A comparison of travoprost, latanoprost, and the fixed combination of dorzolamide and timolol in patients with pseudoexfoliation glaucoma. Medical KQ 3 only
Parravano M, Centofanti M, Palmieri M, Oddone F, Migliardi R, Bucci MG. Preservatives Free Non-Selective β-blockers in the Management of Glaucomatous and Ocular Hypertensive Patients. Meeting abstract
Parrish RA. Comparison of Latanoprost, Bimatoprost, and Travoprost in Patients with Elevated Intraocular Pressure: A 12-Week, Masked-Evaluator, Multicenter Study. Meeting abstract
Parrish R, Sheu WP. Post-hoc Analyses of the XLT Study Results. A Comparison of Latanoprost, Bimatoprost, and Travoprost in Patients with Elevated IOP: A 12-week Randomized, Masked-evaluator, Multicenter Study. Meeting abstract
Parrish RK 2nd, Schiffman JC, Feuer WJ, Heuer DK. Prognosis and risk factors for early postoperative wound leaks after trabeculectomy with and without 5-fluorouracil. Am J Ophthalmol. 2001;132(5):633-40. [pmid: 11704024]. Does not address any key questions
Parrish RK, Palmberg P, Sheu WP. A comparison of latanoprost, bimatoprost, and travoprost in patients with elevated intraocular pressure: a 12-week, randomized, masked-evaluator multicenter study. Medical KQ 3 or KQ 3 and KQ 6 only
Parrish R, Palmberg P. XLT Study Group. Latanoprost, Bimatoprost, and Travoprost in Patients With Elevated Intraocular Pressure: Results of a 12-Week, Masked-Evaluator, Multicenter Study. Meeting abstract
Partamian LG, Kass MA, Gordon M. A dose-response study of the effect of levobunolol on ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Passos Angelo Ferreira, Cardozo Alessandra Soares, Mendes Abraao Garcia, Batista Diusete Maria Pavan. RecuperagPo tardia de fÆstulas antiglaucomatosas pelo agulhamento episcleral associado a injegPo subconjuntival de mitomicina. Foreign language
Pastor Jimeno JC, Eder Labairu F. Effects of timolol maleate in open-angle glaucoma. Results of a double-blind trial against pilocarpine and a long term study (9 months). EFECTOS DEL MALEATO DE TIMOLOL EN EL GLAUCOMA DE ANGULO ABIERTO. RESULTADOS DE UN ESTUDIO DOBLE CIEGO CON LA PILOCARPINA Y ESTUDIO A LARGO PLAZO (9 MESES). Foreign language
Patel N. Cataract development after trabeculectomy with mitomycin C: a 1-year study, by L. ‘Daugeliene, T. Yamamoto, and Y. Kitazawa. Jpn J Ophthalmol. 2000;44:52-7. [pmid: 10698026]. Surv Ophthalmol. 2000;45(2):165. [pmid: 11033043]. Other (specify):No control group
Patelska B, Greenfield DS, Liebmann JM, Wand M, Kushnick H, Ritch R. Latanoprost for uncontrolled glaucoma in a compassionate case protocol. Am J Ophthalmol. 97 ;124(3):279-86. Data not abstractable
Paterson G. Effect of intravenous acetazolamide on relative arcuate scotomas and visual field in glaucoma simplex. Proc R Soc Med. 70 ;63(9):865-9. It is not a RCT and has less than 100 patients
Patil AJ, Vajaranant TS, Edward DP. Bimatoprost - a review. Expert Opin Pharmacother. 2009;10(16):2759-68. [pmid: 19874254]. No original data (e.g., systematic review, narrative review, editorial, letter)
Pavan J, Stambuk N, Curkovic T, Konjevoda P, Pavan-Jukic D, Gotovac M, Karaman K. Effectiveness of latanoprost (Xalatan) monotherapy in newly discovered and previously medicamentously treated primary open angle glaucoma patients. Coll Antropol. 2005;29(1):315-9. [pmid: 16117342]. Other (specify):No control group
Peace JH, Gross RL, Smith SE, Walters TR, Dubiner HB, Weiss MJ, Ochsner KI. Sustained Duration of Action of TRAVATAN ® Z. Meeting abstract
Pechereau A. An undesirable effect of a beta-blocker. Bull Soc Ophtalmol Fr. 87 ;87(4):517-8. [pmid: 3652366]. It is a case series
Pecori-Giraldi J. Computerized perimetric monitoring and study of scotomatous fluctuations in timolol-treated open-angle glaucoma patients. Surv Ophthalmol. 89 ;33(Suppl):423-5. discussion 435–6. It is not a RCT and has less than 100 patients
Pecori-Giraldi J, Collini S, Planner-Terzaghi A, Arrico L, Grechi G. Timolol, betaxolol and befunolol in the treatment of glaucoma. Study of their bronchopulmonary effects. Foreign language
Peeters A, Schouten JS, Webers CA, Prins MH, Hendrikse F, Severens JL. Cost-effectiveness of early detection and treatment of ocular hypertension and primary open-angle glaucoma by the ophthalmologist (Structured abstract). Eye. 2008;22:354-362. [pmid: 17128205]. No original data (e.g., systematic review, narrative review, editorial, letter)
Peeters A, Webers CA, Prins MH, Hendrikse F, Schouten JS. The clinical impact of 2 different strategies for initiating therapy in patients with ocular hypertension. J Glaucoma. 2011;20:30-6. [pmid: 21191272]. Does not address any key questions
Pei C-G, Zhou Y, Shao Y, Zhou Q. Clinical study on the application of anterior lens capsule in trabeculectomy combined with cataract surgery. Foreign language
Peng DW, Lu L, Tian X. Laser suture lysis following trabeculectomy. Foreign language
Peng D, Li S, Li M, Shao H, Sun X, Sheng Y, Yu K, Fu P, Guo W, Meng F, Xu C, Zhu Z. A comparison between latanoprost and timolol in treatment of patients with primary open-angle glaucoma and ocular hypertension. Foreign language
Peng D, Yu K, Tian X, Liu X, Yu M, Zhou W. A randomized control clinical trial of glaucoma filtering surgery with homoharringtonine. Foreign language
Pepys MB. Acetazolamide and renal stone formation. Lancet. 70 ;1(7651):837. It is a case series
Peralta J, Abelairas J, Fernandez-Guardiola J. Anaphylactic shock and death after oral intake of acetazolamide. Am J Ophthalmol. 92 ;114(3):367. It is a case series
Perasalo R, Flink T, Lehtosalo J, Ralli R, Sulonen J. Surgical outcome of phaco-emulsification combined with trabeculectomy in 243 eyes. Acta Ophthalmol Scand. 97 ;75(5):581-3. It is combined cataract/glaucoma surgery study published before April 2000
Perez Candelaria Eneida de la C, Coba Pena Maria Josefa, Vigoa Aranguren Lazaro, Capote Cabrera Armando. Correlacion Anatomoclinica en pacientes operados con Trabeculectomia y su estabilidad funcional. Foreign language
Perez-Lopez M, Nozal CC, Lopez MM, Garcia-Perez JL, Negrete FM. Central retinal vein occlusion after nonperforating sclerectomy without mitomycin. Can J Ophthalmol. 2009;44(6):718-9. [pmid: 20029501]. It is a case series
Pesin SR, Brandt JD. Paresthesia and numbness due to drugs: the special case of the blind. JAMA. 91 ;265(12):1527-8. It is a case series
Peterson MR, Skuta GL, Phelan MJ, Stanley SA. Striate melanokeratosis following trabeculectomy with 5-fluorouracil. Arch Ophthalmol. 90 ;108(9):1216-7. It is a case series
Petounis A, Mylopoulos N, Kandarakis A, Andreanos D, Dimitrakoulias N. Comparison of the additive intraocular pressure-lowering effect of latanoprost and dorzolamide when added to timolol in patients with open-angle glaucoma or ocular hypertension: a randomized, open-label, multicenter study in Greece. Medical KQ 3 or KQ 3 and KQ 6 only
Pfeiffer N. A comparison of the fixed combination of latanoprost and timolol with its individual components. Medical KQ 3 or KQ 3 and KQ 6 only
Pfeiffer N. German Latanopost Fixed Combination Study Group. A COMPARISON OF THE FIXED COMBINATION OF LATANOPROST AND TIMOLOL WITH IST INDIVIDUAL COMPONENTS IN PATIENTS WITH GLAUCOMA OR OCULAR HYPERTENSION. Meeting abstract
Pfeiffer N, Grehn F. Lowering the intraocular pressure by a combination of timolol with adrenergic agents. Fortschr Ophthalmol. 88 ;85(5):456-8. Other (specify):no rct. no harms
Pfeiffer N, Grehn F. Treatment of glaucoma chronicum simplex with a combination of 0.5 percent timolol with 0.5 percent adrenaline plus 0.3 percent guanethidine. Klin Monbl Augenheilkd. 89 ;194(3):161-3. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Pfeiffer N, Grehn F, Hennekes R, Garus H. Decrease in intraocular pressure following administration of the local carbonic anhydrase inhibitor (MK-927)--comparison of the effect with pilocarpine. Fortschr Ophthalmol. 90 ;87(2):128-30. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Pfeiffer N, Greve E, Bechetoille A, Lippa EA, Jaquet-Muller F, Gunning F, Gerling J, Grehn F. Additive effect of timolol and the local carbonic anhydrase inhibitor MK-417 (sezolamide). Fortschr Ophthalmol. 91 ;88(6):846-7. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Pfeiffer N, Hennekes R, Lippa EA, Grehn F, Garus H, Brunner-Ferber FL. A single dose of the topical carbonic anhydrase inhibitor MK-927 decreases IOP in patients. Br J Ophthalmol. 90 ;74(7):405-8. Does not address any key questions
Pfeiffer N, Scherzer ML, Maier H, Schoelzel S, Jasek MC, Stewart JA, Stewart WC. Safety and efficacy of changing to the travoprost/timolol maleate fixed combination (DuoTrav) from prior mono- or adjunctive therapy. Clin Ophthalmol. 2010:459-66. [pmid: 20505839]. Other (specify):not FDA approved, It is not a RCT and has less than 100 patients
Pfeiffer N, Yannoulis N, Mertz B, Cirkel C, Kapik B. The Unoprostone Study Group. Efficacy and safety of unoprostone isopropyl 0.15% and latanoprost 0.005% in adjunctive therapy to timolol maleate 0.5% in patients with primary open-angle glaucoma or ocular hypertension. Meeting abstract
Phelan MJ, Skuta GL. Reversible corneal keratinization following trabeculectomy and treatment with 5-fluorouracil. Ophthalmic Surg. 90 ;21(4):296-8. It is a case series
Philippin H, Wilmsmeyer S, Feltgen N, Ness T, Funk J. Combined cataract and glaucoma surgery: endoscope-controlled erbium:YAG-laser goniotomy versus trabeculectomy. Graefes Arch Clin Exp Ophthalmol. 2005;243(7):684-8. [pmid: 15688161]. Other (specify):applies to KQ3 but not RCT
Picht G, Mutsch Y, Grehn F. Follow-up of trabeculectomy. Complications and therapeutic consequences. Foreign language
Picht G, Mutsch Y, Grehn F. Postoperative complications and therapeutic consequences after trabeculectomy. Nachbetreuung von trabekulektomien: Komplikationen und therapeutische konsequenzen. Ophthalmologe. 2001;98(7):629-634. [pmid: 11490740]. It is a case series
Pillunat LE, Kamman J, Kohlhaas M. Clear cornea phacoemulsification as an intraocular pressure lowering procedure in glaucoma. Meeting abstract
Pillunat LE, Larsson LI. Intraocular pressure after replacement of current dual therapy with latanoprost monotherapy in patients with open angle glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Piltz JR, Bose S. EFFECT OF â1-SELECTIVE AND NON-SELECTIVE â-BLOCKERS ON MACULAR BLOOD FLOW AND CONTRAST SENSITIVITY. Meeting abstract
Pinheiro Renato Klingelfus, Mandia Carmo, Betinjane Alberto, Kasahara Niro, Paollera MaurÆcio, Umbelino Cristiano, Flank MaurÆcio, Eliezer Ricardo, Crosta Fernando. RevisPo interna de Simmons: anblise preliminar de seus resultados clÆnicos. Foreign language
Pisella PJ, Lala E, Parier V, Brignole F, Baudouin C. Effect of preservatives on the conjunctiva: a comparative study of beta-blocker eye drops with and without preservatives in glaucoma patients. Foreign language
Pitrova S, Kalvodova B. General symptoms following administration of isopto-carbachol. Foreign language
Plane C. First clinical impressions of metipranolol eyedrops in open-angle glaucoma. Bull Soc Ophtalmol Fr. 85 ;85(10):1105-9. [pmid: 2875806]. It is not a RCT and has less than 100 patients
Plane C, Sansorgne R, Renaud C, Jouan JP. 2-year long-term treatment of chronic glaucoma with timolol eyedrops. Foreign language
Plane C, Sole P, Hamard H. Results of a double blind study comparing timolol and pilocarpine in 110 patients with chronic open-angle glaucoma. RESULTATS D’UNE ETUDE EN DOUBLE OBSERVATEUR COMPARANT LE TIMOLOL A LA PILOCARPINE CHEZ 110 PATIENTS ATTEINTS DE GLAUCOME CHRONIQUE A ANGLE OUVERT. Foreign language
Plane C, Sole P, Hamard H, Vidal R, Ourgaud AG, Chagnon A. Results of a double-blind study comparing the effects of timolol and pilocarpine in 110 patients with chronic open-angle glaucoma. Foreign language
Plange N, Harris A, Wolter P, Huber K, Remky A, Arend O. Retinal hemodynamics, perimetry and contrast sensitivity in glaucoma therapy. Meeting abstract
Pliushko DG. Drug treatment of the initial stage of glaucoma. Foreign language
Pliushko DG, Kornienko VV. Late results of trabeculectomy in open-angle glaucoma. Foreign language
Pliushko DG, Sobko EG. Drug therapy of initial open-angle glaucoma. Foreign language
Plotnikov MB, Shilova OG, Khatminskii NIu, Zapuskalov IV, Fetisov AA, Filippova SV, Baliuk NA, Khatminskii IuF, Pronin MP, Fedorova NF. Preparation polyosm in the treatment of glaucoma. Foreign language
Podos SM, Serle JB. Topically active carbonic anhydrase inhibitors for glaucoma. Arch Ophthalmol. 91 ;109(1):38-40. No original data (e.g., systematic review, narrative review, editorial, letter)
Poinoosawmy D, Indar A, Bunce C, Garway-Heath DF, Hitchings RA. Effect of treatment by medicine or surgery on intraocular pressure and pulsatile ocular blood flow in normal-pressure glaucoma. Graefes Arch Clin Exp Ophthalmol. 2002;240(9):721-6. [pmid: 12271368]. Does not address any key questions
Polo V, Larrosa JM, Ferreras A, Honrubia FM. Latanoprost vs combined therapy with timolol plus dorzolamide in open-angle glaucoma: A 24-month study. Medical KQ 3 or KQ 3 and KQ 6 only-no true 24hours
Polo V, Larrosa JM, Ferreras A, Borque E, Pablo LE, Honrubia FM. Effect on diurnal intraocular pressure of the fixed combination of latanoprost 0.005% and timolol 0.5% administered in the evening in glaucoma. Ann Ophthalmol (Skokie). 2008;40(3–4):157-62. [pmid: 19230353]. Other (specify):No control group
Polo V, Larrosa JM, Gomez ML, Pablo L, Honrubia FM. Latanoprost versus combined therapy with timolol plus dorzolamide: IOP-lowering effect in open-angle glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Popa DP, Vasinca D, Mihalachi C, Mandroiu S, Dimancescu M. The efficacy of Cairns trabeculectomy in open-angle glaucoma. Foreign language
Popiela G, Muzyka M, Szelepin L, Cwirko M, Nizankowska MH. Use of YAG-Selecta laser and argon laser in the treatment of open angle glaucoma. Foreign language
Potocky M. The Slovak study of the travoprost treatment efficacy. Foreign language
Potocky M, Vodrazkova E. Beta-blockers in the treatment of open-angle glaucoma. Foreign language
Potocky M, Vodrazkova E. Betoptic, a new possibility in the treatment of glaucoma. Foreign language
Potocky M, Vodrazkova E. Factors influencing the effectiveness of argon laser trabeculoplasty. Foreign language
Potocky M, Vodrazkova E. Betablockers in the treatment of primary open-angle glaucoma. Duplicate
Potocky M. The Slovak study of the travoprost treatment efficacy. Slovenska studia efektivity liecby travoprostom. Duplicate 1546
Prakash C, Alexander C, Hussain P, Krishnan P, Venugopal NS, Sahasranam KV. Complete heart block after topical timolol. J Assoc Physicians India. 90 ;38(8):600. 603. It is a case series
Prasad N, Murthy S, Dagianis JJ, Latina MA. A comparison of the intervisit intraocular pressure fluctuation after 180 and 360 degrees of selective laser trabeculoplasty (SLT) as a primary therapy in primary open angle glaucoma and ocular hypertension. J Glaucoma. 2009;18(2):157-60. [pmid: 19225355]. It is not a RCT and has less than 100 patients
Prasad VN, Narain M, Sandeep G. Combined trabeculectomy and cataract extraction--a retrospective study. Indian J Ophthalmol. 88 ;36(4):156-7. It is not a RCT and has less than 100 patients
Prata Junior JA, Minckler DS, Baerveldt G, Lee PP, LaBree L, Heuer DK. Trabeculectomy in pseudophakic patients: postoperative 5-fluorouracil versus intraoperative mitomycin C antiproliferative therapy. Ophthalmic Surg. 95 ;26(1):73-7. It is not a RCT and has less than 100 patients
Prata Joåo Antonio Junior, Reyes Jose Carlos. Uso prolongado de colÆrios antiglaucomatosos e eficbcia da trabeculectomia. Foreign language
Prata JA Jr, Minckler DS, Baerveldt G, Lee PP, Heuer DK. Site of mitomycin-C application during trabeculectomy. J Glaucoma. 94 ;3(4):296-301. It is not a RCT and has less than 100 patients
Prata JA Jr, Seah SK, Minckler DS, Baerveldt G, Lee PP, Heuer DK. Postoperative complications and short-term outcome after 5-Fluorouracil or mitomycin-C trabeculectomy. J Glaucoma. 95(1):25-31. OAG can’t be analyzed separately
Prata TS, Palmiero PM, Angelilli A, Sbeity Z, De Moraes CG, Liebmann JM, Ritch R. Iris morphologic changes related to alpha(1)-adrenergic receptor antagonists implications for intraoperative floppy iris syndrome. Systematic review
Prell R. Successful pressure decrease and improved patient quality of life by Trusopt. Klin Monbl Augenheilkd. 96 ;208(4):11-2. It is a case series
Preoteasa D, Mocanu C. Efficacy of ophthalmic suspension of Brinzolamide (Azopt) in the primary or combined therapy for patients with hypertensive glaucomas. Foreign language
Pribylova E. Thromboses of retinal veins. Foreign language
Primrose J. Dangerous antihypertensive treatment. Br Med J. 79 ;2(6192):737. No subjects with open-angle glaucoma
Promesberger H, Junemann G. Results of treatment with timolol in problematic cases (author’s transl). Klin Monbl Augenheilkd. 81 ;179(6):426-7. It is not a RCT and has less than 100 patients
Prosdocimo G, Daniotti E, Rapizzi A. The triple procedure of ECCE, IOL implantation and trabeculectomy, long-term results and complications. EUR. J. IMPLANT REFRACTIVE SURG. 93(1):60-62. It is combined cataract/glaucoma surgery study published before April 2000
Prost M, Krwawicz L. Timolol in the treatment of uncontrolled glaucoma (author’s transl). Foreign language
Przydryga JT, Egloff C. Intraocular pressure lowering efficacy of travoprost. Eur J Ophthalmol. 2004;14(5):416-22. [pmid: 15506604]. OAG can’t be analyzed separately
Puig L, Goni FJ, Roque AM, Bordas FD, de Moragas JM. Psoriasis induced by ophthalmic timolol preparations. Am J Ophthalmol. 89 ;108(4):455-6. It is a case series
Puustjarvi TJ, Repo LP. Timolol-pilocarpine fixed-ratio combinations in the treatment of chronic open angle glaucoma. A controlled multicenter study of 48 weeks. Scandinavian Timpilo Study Group. Arch Ophthalmol. 92 ;110(12):1725-9. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Puustjarvi TJ, Repo LP, Aarnisalo E, Aitasalo K, Alme G, Brinek HP, Brodwall J, Disen T, Forsman E, Fostad P, Gedde-Dahl S, Granstrom PA, Guldsten H, Haugland KM, Hellum H, Henricson T, Heuer HE, Hoff T, Juhanen L. Timolol-pilocarpine fixed-ratio combinations in the treatment of chronic open angle glaucoma: A controlled multicenter study of 48 weeks. ARCH. OPHTHALMOL. 92 ;110(12):1725-1729. Other (specify):pilocarpine
Puustjarvi T, Aine E, Hakala T. The effect of timolol/pilocarpine combinations with a fixed ratio compared with 0.5% timolol in the treatment of open-angle glaucoma. Fortschr Ophthalmol. 88 ;85(1):76-8. It is not a RCT and has less than 100 patients
Puustjarvi T, Aine E, Hakala T. The effect of two timolol and pilocarpine combinations versus timolol 0.5% in the treatment of open-angle glaucoma. Unique comparators
Puy P, Arias-Puente A, Shafik M, gomez M, Kamel N, Benitez del Castillo J, Garcia-Sanchez J. EFFECT OF PILOCARPINE AND DIPIVALYL-EPINEPHRINE ON THE BLOOD AQUEOUS BARRIER IN GLAUCOMATOUS PATIENTS. Meeting abstract
Qu JM, Tang GL, Hou JP. Comparison of two ways for adjustable suture in complex trabeculectomy. Foreign language
Quaranta L, Hitchings RA, Quaranta CA. Ab-interno goniotrabeculotomy versus mitomycin C trabeculectomy for adult open-angle glaucoma: a 2-year randomized clinical trial. Ophthalmology. 99 ;106(7):1357-62. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Quaranta L, Miglior S, Floriani I, Pizzolante T, Konstas AG. Effects of the timolol-dorzolamide fixed combination and latanoprost on circadian diastolic ocular perfusion pressure in glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Quaranta L, Pasquini L, Cassamali M, Hauranieh N, Gandolfo E, Quaranta CA. Ocular hypotensive effect of sublingual administration of timolol. Int Ophthalmol. 96–97; 20(1–3):49-51. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Quentin CD, Dittmer K, Lauritzen K, Langer F, Vogel M. Combined phaco-trabeculectomy with implantation of foldable posterior chamber lens implantation Complications and long-term results. Kombinierte glaukom- und kataraktoperation mit faltbarer hinterkammerlinsenimplantation. Langzeitergebnisse und komplikationen. Ophthalmologe. 2000;97(11):753-757. [pmid: 11130163]. It is a case series
Quigley HA, Pollack IP. Intraocular pressure control with twice-daily pilocarpine in two vehicle solutions. Ann Ophthalmol. 77 ;9(4):427-30. Data not abstractable
Quigley H. A European Glaucoma Prevention Study. Ophthalmology. 2005;112(9):1642-3. author reply 1643–5. [pmid: 16139678]. No original data (e.g., systematic review, narrative review, editorial, letter)
Quigley HA, Pollack IP, Harbin TS Jr. Pilocarpine ocuserts. Long-term clinical trials and selected pharmacodynamics. Arch Ophthalmol. 75 ;93(9):771-5. [pmid: 5327793]. Other (specify):ocusert no longer sold
Quinones R, Severin T, Mundorf T. Efficacy of bimatoprost 0.03 percent in untreated glaucoma and ocular hypertension patients: results from a large community-based clinical trial. J Ocul Pharmacol Ther. 2004;20(2):115-22. [pmid: 15117567]. It is a case series
Quiralte J, Florido F, de San Pedro BS. Allergic contact dermatitis from carteolol and timolol in eyedrops. Contact Dermatitis. 2000;42(4):245. [pmid: 10750865]. It is a case series
Rachmiel R, Trope GE, Buys YM, Flanagan JG, Chipman ML. Intermediate-term outcome and success of superior versus inferior Ahmed Glaucoma Valve implantation. J Glaucoma. 2008;17(7):584-90. [pmid: 18854738]. It is a case series
Racz P, Ruzsonyi MR, Nagy ZT, Bito LZ. Maintained intraocular pressure reduction with once-a-day application of a new prostaglandin F2 alpha analogue (PhXA41). An in-hospital, placebo-controlled study. Arch Ophthalmol. 93 ;111(5):657-61. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Racz P, Ruzsonyi MR, Nagy ZT, Gaygi Z, Bito LZ. Around-the-clock intraocular pressure reduction with once-daily application of latanoprost by itself or in combination with timolol. Arch Ophthalmol. 96 ;114(3):268-73. [pmid: 629674]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Radcliffe NM, Musch DC, Niziol LM, Liebmann JM, Ritch R. Collaborative Initial Glaucoma Treatment Study Group. The effect of trabeculectomy on intraocular pressure of the untreated fellow eye in the collaborative initial glaucoma treatment study. Ophthalmology. 2010;117(11):2055-60. [pmid: 20570363]. It is a case series
Radcliffe NM, Musch DC, Niziol LM, Liebmann JM, Ritch R. The effect of trabeculectomy on intraocular pressure of the untreated fellow eye in the collaborative initial glaucoma treatment study. Systematic review
Radcliffe NM, Musch DC, Niziol LM, Liebmann JM, Ritch R. The effect of trabeculectomy on intraocular pressure of the untreated fellow eye in the collaborative initial glaucoma treatment study. Ophthalmology. 2010;117:2055-60. [pmid: 20570363]. Does not address any key questions
Radhakrishnan S, Quigley HA, Jampel HD, Friedman DS, Ahmad SI, Congdon NG, McKinnon S. Outcomes of surgical bleb revision for complications of trabeculectomy. Systematic review
Radhakrishnan S, Quigley HA, Jampel HD, Friedman DS, Ahmad SI, Congdon NG, McKinnon S. Outcomes of surgical bleb revision for complications of trabeculectomy. Ophthalmology. 2009;116(9):1713-8. [pmid: 19643490]. Does not address any key questions
Radian AB, Alupei L. Clinical observations on the local use of timolol maleate. Foreign language
Radian AB, Radian AL. Long-term treatment with acetazolamide in primary glaucoma. Foreign language
Radian AB, Chereches S, Alupei L. A comparative study of the ocular hypotonic action of collyria with oxprenolol and timolol maleate. Foreign language
Radius RL. Use of betaxolol in the reduction of elevated intraocular pressure. Arch Ophthalmol. 83 ;101(6):898-900. It is not a RCT and has less than 100 patients
Radzikhovskii BL. Effect of pilocarpine on the visual field of normal and galacomatous eyes. Foreign language
Rahman MQ, Montgomery DM, Lazaridou MN. Surveillance of glaucoma medical therapy in a Glasgow teaching hospital: 26 years’ experience. Br J Ophthalmol. 2009;93(12):1572-5. [pmid: 19628493]. It is a case series
Raina UK, Tuli D. Trabeculectomy with releasable sutures: a prospective, randomized pilot study. Arch Ophthalmol. 98 ;116(10):1288-93. OAG can’t be analyzed separately
Raina UK, Tuli D, Mehta DK. Polyglactin sutures versus nylon sutures for scleral flap suturing in trabeculectomy. Ophthalmic Surg Lasers. 99 ;30(7):554-9. Other (specify):Not a comparison of interest
Rait JL, Adena MA. Persistency rates for prostaglandin and other hypotensive eyedrops: population-based study using pharmacy claims data. Clin Experiment Ophthalmol. 2007;35(7):602-11. [pmid: 17894679]. Other (specify):study design does not match KQ (KQ2)
Raitta C, Setala K. Trabeculectomy with the use of sodium hyaluronate. A prospective study. Acta Ophthalmol (Copenh). 86 ;64(4):407-13. It is not a RCT and has less than 100 patients
Raitta C, Lehto I, Puska P, Vesti E, Harju M. A randomized, prospective study on the use of sodium hyaluronate (Healon) in trabeculectomy. Ophthalmic Surg. 94 ;25(8):536-9. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Raivio VE, Puska PM, Immonen IJ. Cyclophotocoagulation with the transscleral contact red 670-nm diode laser in the treatment of glaucoma. Acta Ophthalmol. 2008;86(5):558-64. [pmid: 18752529]. It is a case series
Rajan MS, Syam P, Liu C. Systemic side effects of topical latanoprost. Eye (Lond). 2003;17(3):442-4. [pmid: 12724721]. It is not a RCT and has less than 100 patients
Rakofsky SI, Lazar M, Almog Y, LeBlanc RP, Mann C, Orr A, Lee PF, Friedland BR, Novack GD, Kelley EP, et al. Efficacy and safety of once-daily levobunolol for glaucoma therapy. Medical KQ 3 or KQ 3 and KQ 6 only
Rakofsky SI, Melamed S, Cohen JS, Slight JR, Spaeth G, Lewis RA, Zbrowski-Gutman L, Eto CY, Lue JC, Novack GD. A comparison of the ocular hypotensive efficacy of once-daily and twice-daily levobunolol treatment. Unique comparators
Ramdas WD, van der Velde N, van der Cammen TJ, Wolfs RC. Evaluation of risk of falls and orthostatic hypotension in older, long-term topical beta-blocker users. Unique comparators
Rao HL, Babu GJ, Sekhar GC. Comparison of the diagnostic capability of the Heidelberg Retina Tomographs 2 and 3 for glaucoma in the Indian population. Systematic review
Rao MR, O’Brien J, Dening TR, Dober M. Systemic hazards of ocular timolol. Br J Hosp Med. 93 ;50(9):553. It is not a RCT and has less than 100 patients
Rasheed el-S. Initial trabeculectomy with intraoperative mitomycin-C application in primary glaucomas. Ophthalmic Surg Lasers. 99 ;30(5):360-6. It is not a RCT and has less than 100 patients
Rauscher FM, Gedde SJ, Schiffman JC, Feuer WJ, Barton K, Lee RK. Motility disturbances in the tube versus trabeculectomy study during the first year of follow-up. Am J Ophthalmol. 2009;147(3):458-66. [pmid: 19038375]. Data not abstractable
Ravinet E, Bovey E, Mermoud A. T-Flux implant versus Healon GV in deep sclerectomy. J Glaucoma. 2004;13(1):46-50. [pmid: 14704543]. OAG can’t be analyzed separately
Rayner SA, Bhikoo R, Gray T. Spherical implantable collamer lenses for myopia and hyperopia: 126 eyes with 1-year follow up. Systematic review
Razeghinejad MR. Glaucoma medications in the Tube versus Trabeculectomy Study. Am J Ophthalmol. 2010;150(2):290. author reply 290–1. [pmid: 20670744]. No original data (e.g., systematic review, narrative review, editorial, letter)
Razemon P, Dascotte JC, Leser C. Our experience with the tonometric effect of timolol. Foreign language
Realini T. Assessing the effectiveness of intraocular pressure-lowering therapy. Ophthalmology. 2010;117(11):2045-6. [pmid: 20970009]. No original data (e.g., systematic review, narrative review, editorial, letter)
Realini T. Assessing the effectiveness of intraocular pressure-lowering therapy. Ophthalmology. 2010;117(11):2045-6. [pmid: 20970009]. No original data (e.g., systematic review, narrative review, editorial, letter)
Realini TD. A Prospective, randomized, investigator-masked evaluation of the monocular trial in ocular hypertension or open-angle glaucoma. Ophthalmology. 2009;116(7):1237-42. [pmid: 19576495]. Does not address any key questions
Realini T, Charlton J, Hettlinger M. The impact of anti-inflammatory therapy on intraocular pressure reduction following selective laser trabeculoplasty. Ophthalmic Surg Lasers Imaging. 2010;41(1):100-3. [pmid: 20128578]. Other (specify):Prednisolone not a medication of interest, Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Reardon G, Schwartz GF, Kotak S. Persistence on prostaglandin ocular hypotensive therapy: an assessment using medication possession and days covered on therapy. Systematic review
Reardon G, Schwartz GF, Mozaffari E. Patient persistency with ocular prostaglandin therapy: a population-based, retrospective study. Clin Ther. 2003;25(4):1172-85. [pmid: 12809964]. OAG can’t be analyzed separately
Reardon G, Schwartz GF, Mozaffari E. Patient persistency with pharmacotherapy in the management of glaucoma. Eur J Ophthalmol. 2003;13(Suppl 4):S44-52. [pmid: 12948052]. Does not address any key questions
Reardon G, Schwartz GF, Mozaffari E. Patient persistency with topical ocular hypotensive therapy in a managed care population. Am J Ophthalmol. 2004;137(1 Suppl):S3-12. [pmid: 14697909]. Animal or in vitro data
Rebolleda G, Munoz-Negrete FJ. Comparison between phaco-deep sclerectomy converted into phaco-trabeculectomy and uneventful phaco-deep sclerectomy. Eur J Ophthalmol. 2005;15(3):343-6. [pmid: 15945002]. Other (specify):No control
Reeder J, Wallace MR. The effect of carbonic anhydrase inhibitors on urinary calcium and citrate. Trans Ophthalmol Soc N Z. 79 ; 31:51-2. Does not address any key questions
Rehman SU, Amoaku WMK, Doran RML, Menage MJ, Morrell AJ, Fox PD. Investigation into the Use of Beta Radiation as an Adjunct to Trabeculectomy in Glaucoma. Meeting abstract
Rehman SU, Tesha P, Merriman M, Amoaku WMK, Barnes R, Menage MJ, Mora J. Results of A Multi-Centered Randomized Controlled Trial of Beta Irradiation as an Adjunct to Trabeculectomy in Open-Angle Glaucoma. Meeting abstract
Rehman SU, Amoaku WM, Doran RM, Menage MJ, Morrell AJ. Randomized controlled clinical trial of beta irradiation as an adjunct to trabeculectomy in open-angle glaucoma. Kirwan 2009
Reibaldi A, Uva MG. Five-year follow-up of LSL trabeculectomies with low dosage mitomycin-C in primary open-angle glaucoma. Acta Ophthalmol Scand Suppl. 2002;236:61-2. [pmid: 12390150]. It is not a RCT and has less than 100 patients
Reibaldi A, Uva MG, Ott JP, Longo A, Chisan G, Franco L. COMBINED SURGERY VS TWO-STAGE PROCEDURE: A PERSPECTIVE RANDOMIZED STUDY USING MITOMYCIN-C. Meeting abstract
Reichert RW, Shields MB, Stewart WC. Intraocular pressure response to replacing pilocarpine with carbachol. Am J Ophthalmol. 88 ; 106(6):747-8. Does not address any key questions
Reichert R, Stewart W, Shields MB. Limbus-based versus fornix-based conjunctival flaps in trabeculectomy. Ophthalmic Surg. 87 ; 18(9):672-6. It is not a RCT and has less than 100 patients
Reichstein D, Kammer J, Recchia F. Combined 25-gauge vitrectomy and posterior tube shunt placement for advanced glaucoma. Systematic review
Reinthal EK, Denk PO, Grub M, Besch D, Bartz-Schmidt KU. Dose, timing and frequency of subconjunctival 5-fluorouracil injections after glaucoma filtering surgery. Graefes Arch Clin Exp Ophthalmol. 2007;245(3):369-75. [pmid: 17043809]. OAG can’t be analyzed separately
Reis R, dos Santos LC, Vila MP, Magacho L. Effects of travoprost 0.004% ophthalmic solution, six weeks after its laminated packaging had been removed, in primary open-angle glaucoma: a randomized, controlled, investigator-blinded study. Clin Ther. 2004;26(12):2121-7. [pmid: 15823775]. Does not address any key questions
Reis R, Queiroz CF, Santos LC, Avila MP, Magacho L. A randomized, investigator-masked, 4-week study comparing timolol maleate 0.5%, brinzolamide 1%, and brimonidine tartrate 0.2% as adjunctive therapies to travoprost 0.004% in adults with primary open-angle glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Reiter C, Wimmer S, Schultheiss A, Klink T, Grehn F, Geerling G. Corneal epitheliopathy following trabeculectomy with postoperative adjunctive 5-fluorouracil. Foreign language
Rekas M, Lewczuk K, Fuksinska B, Rudowicz J, Pawlik R, Stankiewicz A. Combined surgery for cataract and glaucoma: PDS with absorbable SK-gel implant compared with PDS with non-absorbable T-flux implant medium-term results. Curr Med Res Opin. 2010;26(5):1131-1137. [pmid: 20225997]. It is not a RCT and has less than 100 patients
Rekas M, Rudowicz J, Lewczuk K, Klus A, Pawlik B, Stankiewicz A. Phacoemulsification-deep sclerectomy modified by trabeculum microperforations and implantation of lens anterior capsule as autologous scleral implant. Curr Med Res Opin. 2010;26(8):2025-32. [pmid: 20590394]. It is a case series
Rekas M, Wierzbowska J, Lewczuk K, Siemiatkowska A, Stankiewicz A. The effectiveness of phacodeepsclerectomy performed with implantation sk-gel and T-flux--12 months observations. Klin Oczna. 2008;110(4–6):145-50. [pmid: 18655451]. Other (specify):study design does not match KQ (3)
Remky H. Extended sinusectomy (trabeculectomy with cyclodialysis effect). Late results and analysis of failures. Klin Monbl Augenheilkd. 86 ;188(4):278-82. Data not abstractable
Ren J, Shin DH, O’Grady JM, Kim YY, Juzych MS, Hughes BA, Kim C, Glover BK. Long-term outcome of primary glaucoma triple procedure with adjunctive 5-fluorouracil. Graefes Arch Clin Exp Ophthalmol. 98 ;236(7):501-6. It is combined cataract/glaucoma surgery study published before April 2000
Ren J, Tinoosh F, Chung HS, Birt CM, Glover B. Efficacy of Apraclonidine I % vs. Pilocarpine 4% for Prophylaxis of Intraocular Pressure Spike after Argon Laser Trabeculoplasty. Meeting abstract
Renard G, Louka B, Legeais JM, Pouliquen Y. Combined operation of glaucoma and cataract. Comparison between 2 operative techniques. Foreign language
Renard G, Valtot F, Giraud JP, Offret G. Is it possible to use 0.1% timolol in the treatment of chronic glaucoma?. Foreign language
Renieri G, Fuhrer K, Scheithe K, Lorenz K, Pfeiffer N, Thieme H. Efficacy and tolerability of preservative-free eye drops containing a fixed combination of dorzolamide and timolol in glaucoma patients. J Ocul Pharmacol Ther. 2010;26(6):597-603. [pmid: 20977366]. It is a case series
Rentiers PK, Johnston AC, Buskard N. Severe aplastic anemia as a complication of acetazolamide therapy. Can J Ophthalmol. 70 ; 5(4):337-42. It is a case series
Repass R, Eto CY, Lee PH, Sinclair L. AN EVALUATION OF THE DURATION OF ACTION AND SAFETY OF PILASITETM IN OCULAR HYPERTENSIVE PATIENTS. Meeting abstract
Reyes E, Izquierdo NJ, Blasini M. Adverse drugs reactions associated with glaucoma medications. Bol Asoc Med P R. 97; 89(4–6):51-5. It is a case series
Reyna M nica, Consigli Carlos A. Blefaroconjuntivitis de contacto alqrgica por timolol. Foreign language
Rhee DJ, Peace JH, Mallick S, Landry TA, Bergamini MV. A study of the safety and efficacy of travoprost 0.004%/timolol 0.5% ophthalmic solution compared to latanoprost 0.005% and timolol 0.5% dosed concomitantly in patients with open-angle glaucoma or ocular hypertension. Clin Ophthalmol. 2008;2(2):313-319. [pmid: 19668722]. Does not address any key questions
Ribeiro Breno Barreto, Roitberg Marcelo, Marigo Flbvio, Cronemberger SebastiPo, Torqueti Leonardo. Estudo do £stio interno da trabeculectomia pela biomicroscopia ultra-sónica. Foreign language
Richards RD. Long-term results of gonioplasty. Am J Ophthalmol. 70 ; 70(5):715-8. [pmid: 5477158]. It is a case series
Ridgway AE. Trabeculectomy. A follow-up study. Br J Ophthalmol. 74 ;58(7):680-6. It is not a RCT and has less than 100 patients
Ringvold A. Bilateral open-angle glaucoma. Acta Ophthalmol Scand. 99 ;77(1):114-6. It is a case series
Risk factors for suprachoroidal hemorrhage after filtering surgery. The Fluorouracil Filtering Surgery Study Group. Am J Ophthalmol. 92 ; 113(5):501-7. Data not abstractable
Rismanchian A, Eslami F, Moeini H, Attarzade H, Naderibeni A. Efficacy of the latanoprost versus timolol/dorzolamide combination therapy in patients with primary open angle glaucoma. Medical KQ 3 only
Ritch R. Initial treatment of exfoliative glaucoma. J Glaucoma. 98(2):137-40. No original data (e.g., systematic review, narrative review, editorial, letter)
Ritland JS, Egge K, Lydersen S, Juul R, Semb SO. Comparison of survival of exfoliative glaucoma patients and primary open-angle glaucoma patients: impact of acetazolamide use. Acta Ophthalmol Scand. 2004;82(4):397-400. [pmid: 15291931]. Does not address any key questions
Ritland JS, Egge K, Lydersen S, Juul R, Semb SO. Exfoliative glaucoma and primary open-angle glaucoma: associations with death causes and comorbidity. Acta Ophthalmol Scand. 2004;82(4):401-4. [pmid: 15291932]. \Data not abstractable
Rivalan J, Chevet D, Le Pogamp P, Charasse C, Joyeux V. Renal lithiasis, a logical complication of long-term treatment of glaucoma with a carbonic anhydrase inhibitor. Ann Med Interne (Paris). 89; 140(5):419-20. It is a case series
Rivero Reyes Reinaldo L, Rio Torres Marcelino, L£pez Pardo Cbndido M. Acci£n sobre la hidroconductancia del humor acuoso de medicamentos de acci£n hipotensora. Foreign language
Robin A. DECREASING THE FREQUENCY OF POSTOPERATIVE IOP RISE ASSOCIATED WITH COMBINED CATARACT EXTRACTION AND TRABECULECTOMY WITH TOPICAL APRACLONIDINE. 1 %. Meeting abstract
Robin AL, Krishnadas R, Sathyan P, Ramakrishnan R. A comparison of the additive effects of betaxolol 0.25% suspension and timolol maleate 0.5% when added to latanoprost 0.005% in patients with bilateral openangle glaucoma. Meeting abstract
Robin AL, Protzko EE, Visco DM, LaBorwit SE, Smearman SM, Khanna S, Seidenberg JA, Reed D, Stottlemyer J, Brummett M. Four-Week Double-Masked Comparison of Adverse Events Associated with Travoprost and Bimatoprost in Ocular Hypertension and Glaucoma. Meeting abstract
Robin AL. A six-month randomized clinical trial comparing the IOP-lowering efficacy of bimatoprost and latanoprost in patients with ocular hypertension or glaucoma. Am J Ophthalmol. 2003;135(6):921-2. author reply 922–3. [pmid: 12788149]. No original data (e.g., systematic review, narrative review, editorial, letter)
Robin AL. An accurate comparison of bimatoprost’s efficacy and adverse effects. Arch Ophthalmol. 2002;120(7):999-1000. author reply 1000. [pmid: 12096985]. No original data (e.g., systematic review, narrative review, editorial, letter)
Robin AL. Apraclonidine Reduces Intraocular Pressure Rises After Combined Extracapsular Cataract Surgery and Trabeculectomy. Meeting abstract
Robin AL. Ocular hypotensive efficacy and safety of a combined formulation of betaxolol and pilocarpine. Trans Am Ophthalmol Soc. 96 ; 94:89-101. discussion 101–3. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Robin AL, Novack GD, Covert DW, Crockett RS, Marcic TS. Adherence in glaucoma: objective measurements of once-daily and adjunctive medication use. Am J Ophthalmol. 2007;144(4):533-40. [pmid: 17686450]. It is not a RCT and has less than 100 patients
Robin AL, Protzko E, Visco D, Schwartz AL, LaBorwit S, Smearman SM, Seidenburg J, Reed D, Stottlemyer J, Weiss HS, Khanna S, Brummett M. Hyperemia and Myalgia: A 28-Day Prospective Double-Masked Comparison of Travoprost and Bimatoprost Therapy in Primary Open Angle Glaucoma and Ocular Hypertension. Meeting abstract
Robin AL, Ramakrishnan R, Krishnadas R, Smith SD, Katz JD, Selvaraj S, Skuta GL, Bhatnagar R. A long-term dose-response study of mitomycin in glaucoma filtration surgery. Arch Ophthalmol. 97 ; 115(8):969-74. Data not abstractable
Robin AL, Ritch R, Shin DH, Smythe B, Mundorf T, Lehmann RP. Short-term efficacy of apraclonidine hydrochloride added to maximum-tolerated medical therapy for glaucoma. Apraclonidine Maximum-Tolerated Medical Therapy Study Group. Am J Ophthalmol. 95 ;120(4):423-32. [pmid: 6837684]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Robin AL, Ritch R, Shin DH, Smythe B, Mundorf T, Lehmann RP, Brotherman D, Camras C, Derick R, Garrett DT, Gross R, Kapetansky F, Katz LJ, Kaufman P, Lehmann R, Mandell A, McCulley J, Olander K, Roberts A. Short-term efficacy of apraclonidine hydrochloride added to maximum- tolerated medical therapy for glaucoma. Duplicate
Robin AL, Ritch R, Shin D, Smythe B, Mundorf T, Lehmann RP. Topical apraclonidine hydrochloride in eyes with poorly controlled glaucoma. The Apraclonidine Maximum Tolerated Medical Therapy Study Group. Trans Am Ophthalmol Soc. 95 ;93:421-38. discussion 439–41. Other (specify):excluded drug
Robin AL, Ritch R, Shin D, Smythe B, Mundorf T, Lehmann RP, Spaeth GL. Topical apraclonidine hydrochloride in eyes with poorly controlled glaucoma. TRANS. AM. OPHTHALMOL. SOC. 95 ; 93:421-441. Other (specify):apraclonidine
Robin A, Ritch R, Shin D, Smythe B, McCarty G, Taylor B, Silver L, DeFaller J, Godio L. DELAY OF SURGERY BY APRACLONIDINE IN PATIENTS ON MAXIMALLY TOLERATED MEDICAL THERAPY FOR GLAUCOMA. Meeting abstract
Robinson DI, Lertsumitkul S, Billson FA, Robinson LP. Long-term intraocular pressure control by trabeculectomy: a ten-year life table. Aust N Z J Ophthalmol. 93 ;21(2):79-85. Data not abstractable
Robison M, Gamero G, Harmon H, Goldsmith L, Fechtener R, Zimmerman T. THE EFFECT OF NASOLACRIMAL OCCLUSION ON THE DURATION OF ACTION OF DORZOLAMIDE 2%. Meeting abstract
Rockwood EJ, Larive B, Hahn J. Outcomes of combined cataract extraction, lens implantation, and trabeculectomy surgeries. Am J Ophthalmol. 2000;130(6):704-11. [pmid: 11124287]. Does not address any key questions
Rodriguez Bermejo C, Montero P, Perez Santonja JJ, Meza J, Gasco JL, Zato Gomez De Liano MA. Comparative study of quimiotherapic agents as contribution in chronic simple glaucoma surgery. Duplicate
Rodriguez-Bermejo C, Montero P, Perez-Santonja JJ, Meza J, Gasco JL, Zato GDLMA. Comparative study of quimiotherapic agents as contribution in chronic simple glaucoma surgery. ESTUDIO COMPARATIVO DE AGENTES QUIMIOTERAPICOS COMO COADYUVANTES A LA CIRUGIA DEL GLAUCOMA CRONICO SIMPLE. Duplicate
Rodriguez-Prats JL, Alio JL, Galal A. Milling trabeculoplasty for nonpenetrating glaucoma surgery. J Cataract Refract Surg. 2004;30(7):1507-16. [pmid: 15210230]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Rojanapongpun P. Comparison of Separate-Site to Same-Site Approach in Combined Phaco-Trabeculectomy with Mitomycin-C. Meeting abstract
Rolle T, Cipullo D, Vizzeri GM, Triggiani A, Brogliatti B. Evaluation and comparison between the effects on intraocular pressure and retinal blood flow of two antiglaucomatous drugs administered in monotherapy: brimonidine and latanoprost. Preliminary results. Acta Ophthalmol Scand Suppl. 2000;(232):50-2. [pmid: 11235536]. Other (specify):kq 1 and 3 other trial
Rolle T, Tofani F, Brogliatti B, Grignolo FM. The effects of dorzolamide 2% and dorzolamide/timolol fixed combination on retinal and optic nerve head blood flow in primary open-angle glaucoma patients. Unique comparators
Rom M, Schwartz B, Bealka N. Enhanced acute ocular hypotensive response to timolol with dexamethasone treatment. J Glaucoma. 97 ;6(2):111-6. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Romaguera C, Grimalt F, Vilaplana J. Contact dermatitis by timolol. Contact Dermatitis. 86 ;14(4):248. It is a case series
Romanova TB, Abakumova LIa. Reaction of the pupil in patients with glaucoma following long-time treatment with pilocarpine. Foreign language
Ros FE, Dake CL, Innemee HC, van Zwieten PA. Beta-receptor blocking agents and glaucoma; timolol in eye drops. Foreign language
Rosenberg LF, Krupin T, Tang LQ, Hong PH, Ruderman JM. Combination of systemic acetazolamide and topical dorzolamide in reducing intraocular pressure and aqueous humor formation. Ophthalmology. 98; 105(1):88-92. discussion 92–3. It is not a RCT and has less than 100 patients
Rosenlund EF. The intraocular pressure lowering effect of timolol in gel-forming solution. Medical KQ 3 or KQ 3 and KQ 6 only
Rosenthal AR. Pressure cup and tonography in chronic simple glaucoma before and during pilocarpine therapy. Am J Ophthalmol. 69 ; 67(5):713-23. Other (specify):No control
Rosenthal A, Walters T, Berg E, Safyan E, Batoosingh A. A COMPARISON OF THE SAFETY AND EFFICACY OF BRIMONIDINE 0.2%, BID VERSUS TID, IN SUBJECTS WITH ELEVATED INTRAOCULAR PRESSURE. Meeting abstract
Rosentreter A, Mellein AC, Konen WW, Dietlein TS. Capsule excision and Ologen(trademark) implantation for revision after glaucoma drainage device surgery. Duplicate of 148
Ross AH, Jackson TE, Wertheim MS, Spry PG, Sparrow JM, Diamond JP. Analysis of the diurnal intraocular pressure profile pre and post trabeculectomy using 24-hour monitoring of intraocular pressure. Eur J Ophthalmol. 2010. It is not a RCT and has less than 100 patients
Rossert J, Rondeau E, Jondeau G, Ronco P, Mougenot B, Kanfer A, Sraer JD. Tamm-Horsfall protein accumulation in glomeruli during acetazolamide-induced acute renal failure. Am J Nephrol. 89(1):56-7. It is a case series
Rossetti L, Barbieri P, Velati P, Bujtar E, Orzalesi N. The efficacy of the combination of l-moprolol and dipivefrin in reducing the intraocular pressure in primary open-angle glaucoma or in ocular hypertension. Graefes Arch Clin Exp Ophthalmol. 94 ;232(11):670-4. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Rossetti L, Bucci L, Miglior S, Orzalesi N. Temporal corneal phacoemulsification combined with separate-incision superior trabeculectomy vs standard phacotrabeculectomy. A comparative study. Acta Ophthalmol Scand Suppl. 97(224):39. It is combined cataract/glaucoma surgery study published before April 2000
Rossetti L, Karabatsas CH, Topouzis F, Vetrugno M, Centofanti M, Boehm A, Viswanathan A, Vorwerk C, Goldblum D. Comparison of the effects of bimatoprost and a fixed combination of latanoprost and timolol on circadian intraocular pressure. Ophthalmology. 2007;114(12):2244-51. [pmid: 17459480]. Other (specify):not FDA approved combination
Rossi GC, Pasinetti GM, Bracchino M, Bucarelli M, Franchin S, Cerqueti P, Bellini R, Caravati C, Celesia L, Clemente A, Tinelli C. Switching from concomitant latanoprost 0.005% and timolol 0.5% to a fixed combination of travoprost 0.004%/timolol 0.5% in patients with primary open-angle glaucoma and ocular hypertension: a 6-month, multicenter, cohort study. Expert Opin Pharmacother. 2009;(11):1705-11. [pmid: 19601697]. Other (specify):No concurrent control
Rossmann M, Harrer S, Rigal K. T-cut in the bottom of the scleral pocket in combined cataract and glaucoma surgery. J Cataract Refract Surg. 2000;26(5):702-8. [pmid: 10831900]. It is combined cataract/glaucoma surgery study published before April 2000
Rotchford AP, King AJ. Moving the goal posts definitions of success after glaucoma surgery and their effect on reported outcome. Systematic review
Rotchford AP, Murphy KM. Compliance with timolol treatment in glaucoma. Eye (Lond). 98 ;12(Pt 2):234-6. Does not address any key questions
Rotchford AP, Vernon SA. Phaco-microtrabeculectomy: technique and intraocular pressure control in comparison with microtrabeculectomy. Clin Experiment Ophthalmol. 2007;35(9):812-7. [pmid: 18173408]. It is not a RCT and has less than 100 patients
Roth SM, Spaeth GL, Starita RJ, Birbillis EM, Steinmann WC. The effects of postoperative corticosteroids on trabeculectomy and the clinical course of glaucoma: five-year follow-up study. Ophthalmic Surg. 91 ;22(12):724-9. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Rothman RF, Liebmann JM, Ritch R. Low-dose 5-fluorouracil trabeculectomy as initial surgery in uncomplicated glaucoma: long-term followup. Ophthalmology. 2000;107(6):1184-90. [pmid: 10857841]. It is not a RCT and has less than 100 patients
Rouhiainen H, Terasvirta M. Repeated 50 burn/180 degree argon laser trabeculoplasty. Acta Ophthalmol (Copenh). 88 ;66(1):83-6. Other (specify):Not a comparison of interest
Rouhiainen HJ, Terasvirta ME, Tuovinen EJ. Laser power and postoperative intraocular pressure increase in argon laser trabeculoplasty. Arch Ophthalmol. 87 ;105(10):1352-4. It is not a RCT and has less than 100 patients
Rouhiainen HJ, Terasvirta ME, Tuovinen EJ. Peripheral anterior synechiae formation after trabeculoplasty. Arch Ophthalmol. 88 ; 106(2):189-91. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Rouland JF, Le Pen C. Naturalistic, prospective study of glaucoma and ocular hypertension treatment in France: strategies, clinical outcomes, and costs at 1 year. Eur J Ophthalmol. 2003;13(Suppl 4):S5-20. [pmid: 12948049]. It is a case series
Rouland JF, Le Pen C, Benhaddi H, Piriou E, Lilliu H, Kenigsberg PA. Naturalistic, prospective study of glaucoma and ocular hypertension treatment in France: Strategies, clinical outcomes, and costs at 2 years. Eur J Ophthalmol. 2005;15(5):562-80. [pmid: 16167287]. Does not address any key questions
Rouland JF, Morel-Mandrino P, Elena PP, Polzer H, Sunder Raj P. Timolol 01% gel (Nyogel 01% once daily versus conventional timolol 0.5% solution twice daily: a comparison of efficacy and safety. Medical KQ 3 or KQ 3 and KQ 6 only
Rouland JF, Peigne G, Sellem E, Renard JP, Williamson W, Filippi JM, Cohn H, Hamard P, Abellan P, Chagnon A, Malet F, Haye I. An observational, retrospective two-year cost study in primary open-angle glaucoma and ocular hypertension in newly diagnosed patients. Foreign language
Rouland J-F, Morel-Mandrino P, Elena P-P, Polzer H, Sunder Raj P. Timolol 01% gel (nyogel 01%(registered trademark)) once daily versus conventional timolol 0.5% solution twice daily: A comparison of efficacy and safety. Medical KQ 3 or KQ 3 and KQ 6 only
Rouxel AM, Roguedas-Contios AM, Misery L. Malar and ciliary hypertrichosis induced by bimatoprost. Foreign language
Rowe TO. Acetazolamide delirium. Am J Psychiatry. 77 ;134(5):587-8. It is a case series
Royer J, Roth A, Montard M. Results of our experience with the use of timolol maleate eyedrops. Foreign language
Rozovskaia SB. Problems of drug therapy of initial glaucoma and the atypical reaction to pilocarpine. Foreign language
Ruiz Mesa R, Benitez Del, Castillo Sanchez J, Jimenez-Alfaro Morote I, Benitez Del, Castillo JM. Mitomycin-C in primary normal glaucomas surgery. La mitomicina-C en la cirugia de los glaucomas primarios normales. Foreign language
Rulo AH, Greve EL, Hoyng PF. Additive effect of latanoprost, a prostaglandin F2 alpha analogue, and timolol in patients with elevated intraocular pressure. Br J Ophthalmol. 94 ; 78(12):899-902. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Rulo AH, Greve EL, Hoyng PF. Additive ocular hypotensive effect of latanoprost and acetazolamide. A short-term study in patients with elevated intraocular pressure. Ophthalmology. 97 ;104(9):1503-7. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Rulo AH, Greve EL, Geijssen HC, Hoyng PF. Reduction of intraocular pressure with treatment of latanoprost once daily in patients with normal-pressure glaucoma. Ophthalmology. 96 ;103(8):1276-82. [pmid: 2797731]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Rulo A, Greve E, Hoyng P, Alm A. A STUDY OF THE E1+hCT OF LATANOPROST ON THE INTRAOCULAR PRESSURE AND RETINAL VASCULATURE IN PSEUDOPHAKIC PATIENTS. Meeting abstract
Rusk C, Laurence J, Polis A, Adamsons I. COMPARISON OF THE EFFICACY AND SAFETY OF DORZOLAMIDE ARID BETAXOLOL. Meeting abstract
Rusk C, Liss R, Clineschmidt C, Getson A, Shedden A, Adamsons I. Comparison of the Efficacy and Safety of Preservative-Free Dorzolamide and Dorzolamide with Preservative. Meeting abstract
Rusk C, Sharpe E, Laurence J, Polis A, Adamsons I. Comparison of the efficacy and safety of 2% dorzolamide and 0.5% betaxolol in the treatment of elevated intraocular pressure. Medical KQ 3 or KQ 3 and KQ 6 only
Rusk C, Sharpe E, Laurence J, Polis A, Adamsons I. Comparison of the efficacy and safety of 2% dorzolamide and 0.5% betaxolol in the treatment of elevated intraocular pressure. Dorzolamide Comparison Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
Rusk C, Snyder E, Adamsons I. A CLINICAL TRIAL COMPARING PATIENT PREFERENCE AND IMPACT ON DAILY LIFE OF THE DORZOLAMIDE/TIMOLOL COMBINATION TO PILOCARPINE PLUS TIMOLOL. Meeting abstract
Rynne MV. Timolol toxicity: ophthalmic medication complicating systemic disease. J Maine Med Assoc. 80 ;71(3):82. It is a case series
Saari M, Koskela P, Masar SE. Effect of vehicle on pilocarpine-induced ocular hypotension. Acta Ophthalmol (Copenh). 78 ;56(4):489-95. Does not address any key questions
Sadiq SA, Vernon SA. Sublingual timolol--an alternative to topical medication in glaucoma?. Br J Ophthalmol. 96 ;80(6):532-5. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Sadiq SA, Fielding K, Vernon SA. The effect of timolol drops on respiratory function. Eye (Lond). 98 ;12(Pt 3a):386-9. Does not address any key questions
Sagara H, Iida T, Suzuki K, Fujiwara T, Koizumi H, Yago K. Sodium hyaluronate eye drops prevent late-onset bleb leakage after trabeculectomy with mitomycin C. Eye. 2008;22(4):507-514. [pmid: 17173009]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Sagdic Yalvac I, Eksioglu U, Karagoz Y, Akgun U, Kasim R, Duman S. Prophylactic use of apraclonidine for intraocular pressure increase after 180-degree argon laser trabeculoplasty. ANN. OPHTHALMOL. GLAUCOMA. 96 ;28(4):240-243. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Sahouri M, Shin D, Hughes B, Kim C. COMPARATIVE STUDY OF PMMA VS SILICONE IOL THROUGH SMALL INCISION IN GLAUCOMA TRIPLE PROCEDURE. Meeting abstract
Saito M, Takano R, Shirato S. Effects of latanoprost and unoprostone when used alone or in combination for open-angle glaucoma. Am J Ophthalmol. 2001;132(4):485-9. [pmid: 11589867]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Saito Y, Higashide T, Takeda H, Ohkubo S, Sugiyama K. Beneficial effects of preoperative intravitreal bevacizumab on trabeculectomy outcomes in neovascular glaucoma. Systematic review
Sakai T, Yamashita S. Choroidal detachment after glaucoma surgery. Foreign language
Salach L, Uher M, Ogielska E. Timoptic in the treatment of glaucoma. Foreign language
Sall KN, Johnson-Pratt L, Skobieranda F, Polis A, DeLucca P, Kolodny A, Fletcher C, Cassel D. A comparison of the ocular hypotensive effect of dorzolamide hydrochloride/timolol maleate to that of the concomitant therapy with brimonidine tartate and timolol maleate in patients with ocular hypertension or primary open-angle glaucoma. Meeting abstract
Sall KN, Greff LJ, Johnson-Pratt LR, DeLucca PT, Polis AB, Kolodny AH, Fletcher CA, Cassel DA, Boyle DR, Skobieranda F. Dorzolamide/timolol combination versus concomitant administration of brimonidine and timolol: six-month comparison of efficacy and tolerability. Medical KQ 3 or KQ 3 and KQ 6 only
Sall K. The efficacy and safety of brinzolamide 1% ophthalmic suspension (Azopt((registered trademark))) as a primary therapy in patients with open-angle glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Sall K. The efficacy and safety of brinzolamide 1% ophthalmic suspension (Azopt) as a primary therapy in patients with open-angle glaucoma or ocular hypertension. Brinzolamide Primary Therapy Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
Sall K, Assil KK, Beehler CC, Cacioppo L, Caine R, DiGaetano M, Friedlaender M, Friedland B, Greenidge K, Gross RL, Higginbortham E, Horwitz B, Iwach A, Kantor RL, Keates EU, Lopatynsky M, Lowry GM, Morris JB, Sall K, Samples J, Stevenson OD, Terry SA, Tubbs CB, Walters TR, Weiss MJ. The efficacy and safety of brinzolamide 1% ophthalmic suspension (Azopt((TM))) as a primary therapy in patients with open-angle glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Samuels SI, Maze M. Beta-receptor blockade following the use of eye drops. Anesthesiology. 80 ;52(4):369-70. It is a case series
Samuelson TW, Simmons ST. Efficacy and tolerability of Alphagan versus Xalatan as adjunct therapy in chronic open-angle glaucoma or ocular hypertension patients uncontrolled on beta-blockers alone. Meeting abstract
Sanchez E, Schnyder CC, Mermoud A. Comparative results of deep sclerectomy transformed to trabeculectomy and classical trabeculectomy. Foreign language
Sanchez E, Schnyder CC, Sickenberg M, Chiou AG, Hediguer SE, Mermoud A. Deep sclerectomy: results with and without collagen implant. Int Ophthalmol. 96–97; 20(1–3):157-62. OAG can’t be analyzed separately
Sanchez JG. Efficacy and side effects of latanoprost monotherapy compared to adding dorzolamide to timolol in patients with glaucoma and ocular hypertension - A three-month randomised study. Duplicate
Sanders S, Chaudhuri R. INITIAL SUCCESS OF COMBINED CATARACT SURGERY AND ENDOCYCLOPHOTOCOAGULATION IN REDUCING THE NEED FOR TOPICAL THERAPY IN GLAUCOMA. Meeting abstract
Sanders SP, Cantor LB, Hoop JS. MITOMYCIN C IN PRIMARY TRABECULECTOMY: A COMPARISON OF 0.1 TO 0.2 MG/CC. Meeting abstract
Sanders SP, Cantor LB, Dobler AA, Hoop JS. Mitomycin C in higher risk trabeculectomy: a prospective comparison of 0.2- to 0.4-mg/cc doses. Unique comparators
Sanders SP, Cantor LB, Dobler AA, Hoop J, Sponsel WE, Shoemaker J. MITOMYCIN C IN COMPLICATED TRABECULECTOMY: A COMPARISON OF 0.2 TO 0.4 MG/CC. Meeting abstract
Sanfelici G, Rolando M, Calabria G, Murialdo U. Timolol and dapiprazole combination in patients with glaucoma. Foreign language
Santos HD, Fernandes TA, Souza CA, Cronemberger S, Calixto N. Efficacy of latanoprost versus travoprost assessed by daily intraocular pressure curve. Foreign language
Santos Hqrika Danielle de Miranda, Fernandes Thatiana Almeida Pereira, Souza Camila Ara jo de, Cronemberger SebastiPo, Calixto Nassim. Eficbcia do latanoprosta x travoprosta avaliada pela curva dibria de pressPo intraocular. Efficacy of latanoprost versus travoprost assessed by daily intraocular pressure curve. Foreign language
Satterfield D, Mannis MJ, Glover AT. Unilateral corneal vesicles secondary to dipivefrin therapy. Am J Ophthalmol. 92 ;113(3):339-40. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Savelsbergh-Fillette MP, Demailly P. Comparative study of levobunolol and timolol in the treatment of chronic open-angle glaucoma and chronic ocular hypertension. Foreign language
Scafidi AF, Stewart WC, Ropo AM. the Timolol Hemihydrate Study Group. SAFETY AND EFFICACY OF TIMOLOL HEMIHYDRATE (0.25 AND 0.5% OPHTHALMIC SOLUTION) IN OPEN-ANGLE GLAUCOMA AND OCULAR HYPERTENSION. Meeting abstract
Scharrer A, Ober M. Metipranolol 0.1% and pilocarpine 2% as a fixed combination compared to each substance alone in the treatment of glaucoma. A controlled, randomized clinical study comparing the intraindividual effects and tolerance. Klin Monbl Augenheilkd. 86; 189(6):450-5. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Scharrer A, Ober M. Timolol and acetazolamide in the treatment of increased intraocular pressure (author’s transl). Albrecht Von Graefes Arch Klin Exp Ophthalmol. 79 ;212(2):129-34. It is not a RCT and has less than 100 patients
Scharrer A, Ober M. Fixed combination of metipranolol 0.1% and pilocarpine 2% compared with the individual drugs in glaucoma therapy. A controlled, randomized clinical study for intraindividual comparison of efficacy and tolerance. 189(6):450-455. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Schenker HI, Silver LH. Long-term intraocular pressure-lowering efficacy and safety of timolol maleate gel-forming solution 0.5% compared with Timoptic XE 0.5% in a 12-month study. Medical KQ 3 or KQ 3 and KQ 6 only
Schenker HI, Williams L, Goode SM, Gross RD, Mathis JA, Mallick S, Dickerson JE, Andrew R, Silver L, Landry T. Iris Pigmentation Changes Following Treatment With Travoprost Or Latanoprost In Patients With Open-angle Glaucoma Or Ocular Hypertension. Meeting abstract
Schenker H, Maloney S, Liss C, Gormley G, Hartenbaum D. Patient preference, efficacy, and compliance with timolol maleate ophthalmic gel-forming solution versus timolol maleate ophthalmic solution in patients with ocular hypertension or open-angle glaucoma. Not an RCT Just KQ 2 and/or 5
Scherer WJ. Effect of topical prostaglandin analog use on outcome following selective laser trabeculoplasty. J Ocul Pharmacol Ther. 2007;23(5):503-12. [pmid: 17941809]. It is not a RCT and has less than 100 patients
Schiffer HP. Comparative study between timolol and pilocarpine in the treatment of open-angle glaucoma (author’s transl). Foreign language
Schiffman J, Alward WLM, Farrell T, Hayreh S, Kolder H, Carney B, Phelps C, Gressel M, Costin J, Craven P, Zgrabik M, Schremp P, Simashkevich B, Heuer DK, Baerveldt G, Minckler D, Irvine J, Green R, McDonnell P. Five-year follow-up of the fluorouracil filtering surgery study. Duplicate
Schiffman RM, Javitt JC. The Success Rate Quality of Life of Brimonidine 0.2% BID vs. Timolol 0.5% BID, in Previously Untreated OAG or OHT Patients. Meeting abstract
Schild AM, Jordan JF, Konen W, Krieglstein GK, Dietlein TS. Midterm patient satisfaction following mitomycin C-assisted trabeculectomy. Patientenzufriedenheit nach filtrierender glaukomchirurgie mit mitomycin C. Foreign language
Schlote T, Derse M, Rassmann K, Nicaeus T, Dietz K, Thiel HJ. Efficacy and safety of contact transscleral diode laser cyclophotocoagulation for advanced glaucoma. J Glaucoma. 2001;(4):294-301. [pmid: 11558814]. OAG can’t be analyzed separately
Schlote T, Tzamalis A, Kynigopoulos M. Central corneal thickness during treatment with travoprost 0.004% in glaucoma patients. J Ocul Pharmacol Ther. 2009;25(5):459-62. [pmid: 19857108]. It is a case series, Does not address any key questions
Schmidt CM Jr, Wilson RP, Steinmann WC, Spaeth GL. SUTURE TYPE AFFECTS TENON’S CYST INCIDENCE IN LIMBAL-BASED TRABECULECTOMY. Meeting abstract
Schmidt KG, Stegman DY, Serle JB, Garrett DT, Camras CB, Mittag TW, Podos SM. OCULAR PULSE AMPLITUDE (OPA) IN PRIMARY OPEN ANGLE GLAUCOMA, LOW TENSION GLAUCOMA, AND IN OCULAR HYPERTENSIVE PATIENTS BEFORE AND AFTER DRUG TREATMENT. Meeting abstract
Schmidt KG, von Ruckmann A, Pillunat LE. Topical carbonic anhydrase inhibition increases ocular pulse amplitude in high tension primary open angle glaucoma. Br J Ophthalmol. 98 ;82(7):758-62. Data not abstractable
Schmidt-Erfurth U, Wetzel W, Droge G, Haring G, Behrendt S, Birngruber R. Progress in laser sclerostomy ab externo: Expanding the sclerostomy channels and administration of local mitomycin. 95 ;92(4):536-541. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Schmier JK, Halpern MT, Covert DW, Robin AL. Travoprost versus latanoprost combinations in glaucoma: economic evaluation based on visual field deficit progression (Structured abstract). Current Medical Research and Opinion. 2006;22(9):1737-1743. [pmid: 16968577]. Does not address any key questions
Schmier JK, Covert DW, Robin AL. First-year treatment patterns among new initiators of topical prostaglandin analogs. Systematic review
Schmitz-Valckenberg P, Kessler C. LOW-DOSE COMBINATION OR HIGH-DOSE SEPARATE SOLUTIONS IN GLAUCOMA ?. Meeting abstract
Schmutz JL, Barbaud A, Trechot P. Toxic epidermal necrolysis following eyedrop treatment for glaucoma. Ann Dermatol Venereol. 2007;134(4 Pt 1):417. [pmid: 17483771]. It is a case series
Schnarr KD. Comparative multicenter study of carteolol eyedrops with other beta blockers in 768 patients under normal conditions. Foreign language
Schnyder CC, Bernasconi O, Mermoud A, Faggioni R. Comparative study of administration time of mitomycin C in trabeculectomy: 2.5 or 5 minutes?. Foreign language
Schoene RB, Martin TR, Charan NB, French CL. Timolol-induced bronchospasm in asthmatic bronchitis. JAMA. 81 ; 245(14):1460-1. No subjects with open-angle glaucoma
Schrems W, Hofmann G, Krieglstein GK. Therapy of open-angle glaucoma with the argon and neodymium laser. Fortschritte der Ophthalmologie : Zeitschrift der Deutschen Ophthalmologischen Gesellschaft. 88 ;85(1):119-23. Other (specify):no rct and no harms
Schroder H. Increased intraocular pressure in asthma patients. Med Monatsschr Pharm. 2005;28(8):286-7. [pmid: 16128540]. No original data (e.g., systematic review, narrative review, editorial, letter)
Schuhr J, Stewart JA, Day DG, Leech JN, Stewart WC. The Safety and Efficacy of Unoprostone Isopropyl 0.15% Versus Brimonidine 0.2%. Meeting abstract
Schultheiss E. Hypersensitivity to levobunolol. Derm Beruf Umwelt. 89 ;37(5):185-6. It is a case series
Schultz JS, Hoenig JA, Charles H. Possible bilateral anterior uveitis secondary to metipranolol (optipranolol) therapy. Arch Ophthalmol. 93 ;111(12):1606-7. It is a case series
Schulzer M. Intraocular pressure reduction in normal-tension glaucoma patients. Duplicate of 5281
Schulzer M. Intraocular pressure reduction in normal-tension glaucoma patients. The Normal Tension Glaucoma Study Group Maier 2005 and Burr 2004.
Schulzer M, Drance SM, Anderson DR. Successful Intraocular Pressure Reduction in Normal Tension Glaucoma. Meeting abstract
Schulzer M, Drance SM, Douglas GR. A comparison of treated ad untreated glaucoma suspects. Maier, 2005
Schuman JS, Pettigrew SC, Mallick S, Wells DT, Andrew RM, Sullivan EK, Landry TA, Bergamini MVW, Robertson SM. Travoprost 0.004%/Timolol 0.5% Study Group. A Comparison of Travoprost 0.004%/Timolol 0.5% Ophthalmic Solution to the Concomitant Administration of Travoprost 0.004% and Timolol 0.5% Ophthalmic Solutions and to Timolol 0.5% Ophthalmic Solution Alone. Meeting abstract
Schuman JS. AGN 192024 Study Groups, I. & II. 6-MONTH COMPARISON OF AGN 192024 QD AND BID WITH TIMOLOL BID IN PATIENTS WITH ELEVATED IOP. Meeting abstract
Schuman JS. Effects of systemic (beta)-blocker therapy on the efficacy and safety of topical brimonidine and timolol. Ophthalmology. 2000;107(6):1171-1177. [pmid: 10857839]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Schuman JS. Effects of systemic beta-blocker therapy on the efficacy and safety of topical brimonidine and timolol. Brimonidine Study Groups 1 and 2. Excluded drug
Schuman JS, Hersh P, Kylstra J. Vitreous hemorrhage associated with pilocarpine. Am J Ophthalmol. 89 ;108(3):333-4. It is a case series
Schuman JS, Horwitz B, Choplin NT, David R, Albracht D, Chen K. A 1-year study of brimonidine twice daily in glaucoma and ocular hypertension. A controlled, randomized, multicenter clinical trial. Chronic Brimonidine Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
Schuman JS, Katz GJ, Lewis RA, Henry JC, Mallick S, Wells DT, Sullivan EK, Landry TA, Bergamini MV, Robertson SM. Efficacy and safety of a fixed combination of travoprost 0004%/timolol 05% ophthalmic solution once daily for open-angle glaucoma or ocular hypertension. Non-FDA-approved drug combination
Schuman JS, Mallick S, Wells DT, Sullivan EK, Landry TA, Robertson SM. A Comparison of Travoprost 0.004%/Timolol 0.5% Ophthalmic Solution to the Concomitant Administration of Travoprost 0.004% and Timolol 0.5% Ophthalmic Solutions. Meeting abstract
Schuman JS, Mallick S, Wells D, Sullivan EK, Landry TA, Bergamini MVW, Wax MB, Robertson SM. Evaluation of Travoprost 0.004%/Timolol 0.5% Fixed Combination Ophthalmic Solution vs. Concomitant Use of Travoprost 0.004% and Timolol 0.5%. Meeting abstract
Schwartz B. Reversibility by timolol of optic nerve disc cupping and pallor in ocular hypertensives. Surv Ophthalmol. 89 ;33(Suppl):419-20. discussion 421–2. No original data (e.g., systematic review, narrative review, editorial, letter)
Schwartz B, Lavin P, Takamoto T, Araujo DF, Smits G. Decrease of optic disc cupping and pallor of ocular hypertensives with timolol therapy. Acta Ophthalmol Scand Suppl. 95(215):5-21. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Schwartz B, Lavin P, Takamoto T, Araujo D, Smits G. Reversal of optic disc cupping and pallor in patients with ocular hypertension using timolol therapy. J Glaucoma. 93 ;2(Suppl A):20-1. Data not abstractable
Schwartz B, Takamoto T, Lavin P. Retinal nerve fiber layer thickness measurements in ocular hypertensive patients with timolol treatment. Journal of Glaucoma. 93 ;2 (A):S22-23. Does not address any key questions
Schwartz B, Takamoto T, Lavin P, Smits G. Increase of retinal nerve fiber layer thickness in ocular hypertensives with timolol therapy. Vass 2007
Schwartz B, Takamoto T, Nagin P, Lavin P, Rosa DA, Barton JA. Optic disc measurements after timolol therapy in ocular hypertensives. CHIBRET INT. J. OPHTHALMOL. 87 ;5(3):29-30. Other (specify):abstract
Schwartz GF. Clinical and economic outcomes of latanoprost, bimatoprost, or travoprost. Asian J. Ophthalmol. 2003;5(2):15. No original data (e.g., systematic review, narrative review, editorial, letter)
Schwartz GF. Patient persistence with topical prostaglandin therapy. Asian J Ophthalmol. 2003;5(2):16-17. No original data (e.g., systematic review, narrative review, editorial, letter)
Schwartz GF. Persistency and tolerability of ocular hypotensive agents: population-based evidence in the management of glaucoma. Am J Ophthalmol. 2004;137(1 Suppl):S1-2. [pmid: 14697908]. Does not address any key questions
Schwartz GF, Reardon G, Mozaffari E. Persistency with latanoprost or timolol in primary open-angle glaucoma suspects. Am J Ophthalmol. 2004;137(1 Suppl):S13-6. [pmid: 14697910]. Does not address any key questions
Schwartz LW, Spaeth GL, Traverso C, Greenidge KC. Variation of techniques on the results of argon laser trabeculoplasty. Ophthalmology. 83 ;90(7):781-4. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Schwenn O, Heckmann B, Guzy C, Miller PJ. Long-term effect of latanoprost/timolol fixed combination in patients with glaucoma or ocular hypertension: a prospective, observational, noninterventional study. BMC Ophthalmol. 2010:21. [pmid: 20825668]. It is a case series
Schwenn O, Springer C, Troost A, Yun SH, Pfeiffer N. Deep sclerectomy using a hyaluronate implant versus trabeculectomy. A comparison of two glaucoma operations using mitomycin C. Foreign language
Schwenn O, Springer C, Troost A, Yun SH, Pfeiffer N. Deep sclerectomy using a hyaluronate implant versus trabeculectomy A comparison of two glaucoma operations using mitomycin C. Tiefe sklerektomie mit hyaluronatimplantat vs. trabekulektomie. Zwei glaukomoperationen unter verwendung von mitomycin C. foreign language- german
Scorgia G, Niutta A, Librando A, Gambescia TD, Bruzzichessi D, Palombi E, Balaceo Gabrieli C. A clinical valuation and comparison of the ocular-hypotensive efficacy of befunolol versus timolol levobunolol and placebo in the treatment of the open angle glaucoma. CLIN. OCUL. PATOL. OCUL. 90(6):424-426. It is not a RCT and has less than 100 patients
Scott A, Kotecha A, Bunce C, Balidis M, Garway-Heath DF, Miller MH, Wormald R. YAG laser peripheral iridotomy for the prevention of pigment dispersion glaucoma a prospective, randomized, controlled trial. Ophthalmology. 2011;118(3):468-73. [pmid: 21035866]. Does not address any key questions
Scott A, Kotecha A, Bunce C, Balidis M, Garway-Heath DF, Miller MH, Wormald R. YAG laser peripheral iridotomy for the prevention of pigment dispersion glaucoma a prospective, randomized, controlled trial. Ophthalmology. 2011;118:468-73. [pmid: 21035866]. Does not address any key questions
Seah SK, Gazzard G, Aung T. Intermediate-term outcome of Baerveldt glaucoma implants in Asian eyes. Ophthalmology. 2003;110(5):888-94. [pmid: 12750085]. OAG can’t be analyzed separately
Seah SL, Khaw PT, Minassian D, Foster PJ, Husain R, Gazzard G, Oen FTS, Chew PTK, Machin D, Aung T. The Singapore 5-FU Study: A Prospective Randomized Masked Trial of Intra-Operative 5-Fluorouracil vs Placebo- Effect on Long-Term Pressure Control and Glaucoma Progression. Meeting abstract
Seamone C, LeBlanc R, Saheb N, Novack G. Efficacy of twice-daily levobunolol in the treatment of elevated intraocular pressure. Medical KQ 3 or KQ 3 and KQ 6 only
Sebastiani A, Parmeggiani F, Costagliola C, Ciancaglini M, D’Oronzo E, Mastropasqua L. Effects of acute topical administration of clonidine 0.125%, apraclonidine 1.0% and brimonidine 0.2% on visual field parameters and ocular perfusion pressure in patients with primary open-angle glaucoma. Acta Ophthalmol Scand Suppl. 2002;236:29-30. [pmid: 12390124]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Sehi M, Grewal DS, Feuer WJ, Greenfield DS. The impact of intraocular pressure reduction on retinal ganglion cell function measured using pattern electroretinogram in eyes receiving latanoprost 0.005% versus placebo. Medical KQ 3 only
Sehi M, Grewal DS, Goodkin ML, Greenfield DS. Reversal of Retinal Ganglion Cell Dysfunction after Surgical Reduction of Intraocular Pressure. Ophthalmology. 2010. It is not a RCT and has less than 100 patients
Seider N, Miller B, Beiran I. Topical glaucoma therapy as a risk factor for nasolacrimal duct obstruction. Unique comparators
Sellem E, Rouland JF, Baudouin C, Bron A, Denis P, Nordmann JP, Renard JP. Predictors of additional intraocular pressure reduction in patients changed to latanoprost/timolol fixed combination. BMC Ophthalmol. 2010;10:10. [pmid: 20346127]. Other (specify):Inadequate control
Sen E, Nalcacioglu P, Yazici A, Aksakal FN, Altinok A, Tuna T, Koklu G. Comparison of the effects of latanoprost and bimatoprost on central corneal thickness. J Glaucoma. 2008;17(5):398-402. [pmid: 18703951]. Other (specify):Study design does not match KQ
Seong GJ, Rho SH, Kim CS, Moon JI, Kook MS, Kim YY, Ma KT, Hong YJ, Nelson LA, Kruft B, Stewart JA, Stewart WC. Potential benefit of intraocular pressure reduction in normal-tension glaucoma in South Korea. J Ocul Pharmacol Ther. 2009;25(1):91-6. [pmid: 19232005]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Serguhn S, Spiegel D. Comparison of postoperative recovery after trabeculectomy for pseudoexfoliation glaucoma and chronic primary open angle glaucoma. Klin Monbl Augenheilkd. 99 ;215(5):281-6. It is a case series
Serle JB. A comparison of the safety and efficacy of twice daily brimonidine 0.2% versus betaxolol 0.25% in subjects with elevated intraocular pressure. Medical KQ 3 or KQ 3 and KQ 6 only
Serle JB. A comparison of the safety and efficacy of twice daily brimonidine 0.2% versus betaxolol 0.25% in subjects with elevated intraocular pressure. Duplicate of 9552
Serle JB. A comparison of the safety and efficacy of twice daily brimonidine 0.2% versus betaxolol 0.25% in subjects with elevated intraocular pressure. The Brimonidine Study Group II. Medical KQ 3 or KQ 3 and KQ 6 only
Serle JB, Lustgarten JS, Podos SM. A clinical trial of metipranolol, a noncardioselective beta-adrenergic antagonist, in ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Serle JB, Lustgarten JS, Lippa EA, Camras CB, Panebianco DL, Podos SM. MK-927, a topical carbonic anhydrase inhibitor. Dose response and reproducibility. Arch Ophthalmol. 90 ;108(6):838-41. Does not address any key questions
Serle JB, Lustgarten J, Lippa EA, Camras CB, Framm L, Payne JE, Deasy D, Podos SM. Six week safety study of 2% MK-927 administered twice daily to ocular hypertensive volunteers. J Ocul Pharmacol. 92 ;8(1):1-9. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Serle JB, Piltz JR, Rosenberg LF, Wright M, Gagliuso DJ. COMPARISON OF EFFICACY & TOLERABILITY OF 0.5% APRACLONIDINE T.I.D. AND 0.2% BRIMONIDINE B.I.D. IN PATIENTS WITH ELEVATED INTRAOCULAR PRESSURE (IOP). Meeting abstract
Serle J, Johnson-Pratt L, Polis A, DeLucca P, Kolodny A, Fletcher C, Cassel D, Boyle D, Skobieranda F. A COMPARISON OF THE INTRAOCULAR PRESSURE LOWERING EFFECT OF COSOPT® TO THE CONCOMITANT ADMINISTRATION OF ALPHAGAN® AND TIMOLOL. Meeting abstract
Serpa Junior E, Wishart PK. Comparison of PMMA, foldable silicone and foldable acrylic hydrophobic intraocular lenses in combined phacoemulsification and trabeculectomy. Arq Bras Oftalmol. 2005;68(1):29-35. [pmid: 15824800]. It is a case series
Shaarawy T, Flammer J, Smits G, Mermoud A. Low first postoperative day intraocular pressure as a positive prognostic indicator in deep sclerectomy. Br J Ophthalmol. 2004;88(5):658-61. [pmid: 15090419]. OAG can’t be analyzed separately
Shaarawy T, Karlen M, Schnyder C, Achache F, Sanchez E, Mermoud A. Five-year results of deep sclerectomy with collagen implant. J Cataract Refract Surg. 2001;27(11):1770-8. [pmid: 11709250]. Other (specify):Study design does not match KQ
Shaarawy T, Mansouri K, Schnyder C, Ravinet E, Achache F, Mermoud A. Long-term results of deep sclerectomy with collagen implant. J Cataract Refract Surg. 2004;30(6):1225-31. [pmid: 15177596]. It is a case series
Shaarawy T, Nguyen C, Schnyder C, Mermoud A. Comparative study between deep sclerectomy with and without collagen implant: long term follow up. Br J Ophthalmol. 2004;88(1):95-8. [pmid: 14693783]. Animal or in vitro data
Shah P, O’Donnell B, Pochkhanawala F, Tan CY. Severe exacerbation of rosacea by oral acetazolamide. Br J Dermatol. 93 ;129(5):647-8. It is not a RCT and has less than 100 patients
Shaikh MH, Mars JS. The acute effect of pilocarpine on pulsatile ocular blood flow in ocular hypertension. Eye (Lond). 2001;15(Pt 1):63-6. [pmid: 11318298]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Shaivitz SA. Timolol and myasthenia gravis. JAMA. 79 ;242(15):1611-2. It is a case series
Shammas HJ. Anterior intraocular lens dislocation after combined cataract extraction trabeculectomy. J Cataract Refract Surg. 96 ; 22(3):358-61. It is combined cataract/glaucoma surgery study published before April 2000
Shao H, Sun XY, Bai FG. Comparison of 0.1% dipivalyl epinephrine and 1% epinephrine in patients with glaucoma or ocular hypertension. Foreign language
Shapiro S, Fraunfelder FT. Acetazolamide and aplastic anemia. Am J Ophthalmol. 92 ;113(3):328-30. [pmid: 7294092]. No original data (e.g., systematic review, narrative review, editorial, letter)
Sharir M, Zimmerman TJ, del Negro RG, Ball SF, Kooner KS. A comparison of the efficacy of various metipranolol-pilocarpine combinations in patients with ocular hypertension and primary open-angle glaucoma. J Ocul Pharmacol. 94 ;10(2):411-20. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Sharma A, Gupta A. Primary argon laser trabeculoplasty vs pilocarpine 2% in primary open angle glaucoma: two years follow-up study. Indian J Ophthalmol. 97 ;45(2):109-13. Data not abstractable
Sharma GK, Nepalia LK, Garg AS. Pressure dynamics following trabeculectomy. A critical analysis. Indian J Ophthalmol. 86 ;34:202-5. Data not abstractable
Sharma OD, Gupta NC, Sing Parmar IP, Khurana AK. Evaluation of pilocarpine vs timolol and their combined efficacy in primary open angle glaucoma. Afro-Asian Journal of Ophthalmology. 90 ; 9(2):58-60. Other (specify):pilo out
Sharma R, Kohli K, Kapoor B, Mengi RK, Sadhotra P. The cardio-vascular effects of topical timolol, levobunolol and betaxolol in patients of chronic simple glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Sharma R, Kohli K, Kapoor B, Mengi RK, Sadotra P, Verma U. Comparative effect of timolol, levobunolol and betaxolol on IOP in patients of chronic simple glaucoma. Meeting abstract
Sharpe ED, Kapik B, Reaves A, Haque R, Shams N. Comparison of the effect of different concentrations of the cocosanoid unoprostone isopropyl on intraocular pressure in patients with primary open-angle glaucoma or ocular hypertension. Meeting abstract
Sharpe ED, Day DG, Beischel CJ, Rhodes JS, Stewart JA, Stewart WC. Brimonidine purite 0.15% versus dorzolamide 2% each given twice daily to induce intraocular pressure in subjects with open angle glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Sharpe ED, Henry CJ, Mundorf TK, Day DG, Stewart JA, Jenkins JN, Stewart WC. Brimonidine 0.2% vs unoprostone 0.15% both added to timolol maleate 0.5% given twice daily to patients with primary open-angle glaucoma or ocular hypertension. Eye (Lond). 2005;19(1):35-40. [pmid: 15094733]. Other (specify):Unoprostone
Sharpe ED, Williams RD, Stewart JA, Nelson LA, Stewart WC. A comparison of dorzolamide/timolol-fixed combination versus bimatoprost in patients with open-angle glaucoma who are poorly controlled on latanoprost. Medical KQ 3 only
Shaya FT, Mullins CD, Wong W, Cho J. Discontinuation rates of topical glaucoma medications in a managed care population. Am J Manag Care. 2002;8(10 Suppl):S271-7. [pmid: 12188170]. OAG can’t be analyzed separately
Shayegan MR, Boloorian AA, Kianoush S. Comparative study of topical application of timolol and verapamil in patients with glaucoma within 6 months. J Ocul Pharmacol Ther. 2009;25(6):551-3. [pmid: 20028263]. Other (specify):Verapamil not a medication of interest
Shedden A, Adamsons IA, Getson AJ, Laurence JK, Lines CR, Hewitt DJ, Ho TW. Comparison of the efficacy and tolerability of preservative-free and preservative-containing formulations of the dorzolamide/timolol fixed combination (COSOPT) in patients with elevated intraocular pressure in a randomized clinical trial. Unique comparators
Shedden A, Laurence J, Tipping R. Efficacy and tolerability of timolol maleate ophthalmic gel-forming solution versus timolol ophthalmic solution in adults with open-angle glaucoma or ocular hypertension: a six-month, double-masked, multicenter study. Medical KQ 3 or KQ 3 and KQ 6 only
Sheha H, Kheirkhah A, Taha H. Amniotic membrane transplantation in trabeculectomy with mitomycin C for refractory glaucoma. J Glaucoma. 2008;17(4):303-7. [pmid: 18552616]. No subjects with open-angle glaucoma
Shen ZM. Preliminary report of clinical observation on reduction in intraocular pressure by timolol (author’s transl). Foreign language
Sheng X-L, Xia M-H, Wang J, Zhang L. Comparison of two methods for glaucoma combined with a cataract. Foreign language
Sherwood M, Brandt J. Six-month comparison of bimatoprost once-daily and twice-daily with timolol twice-daily in patients with elevated intraocular pressure. Medical KQ 3 only
Sherwood MB, Craven ER, Chou C, DuBiner HB, Batoosingh AL, Schiffman RM, Whitcup SM. Twice-daily 0.2% brimonidine-0.5% timolol fixed-combination therapy vs monotherapy with timolol or brimonidine in patients with glaucoma or ocular hypertension: a 12-month randomized trial. Arch Ophthalmol. 2006;124(9):1230-8. [pmid: 16966616]. OAG can’t be analyzed separately
Sherwood MB, Lattimer J, Hitchings RA. Laser trabeculoplasty as supplementary treatment for primary open angle glaucoma. Rolim de Moura 2009
Sherwood M. for the Brimonidine Study Group. A Comparison of the Safety and Ocular Hypotensive Efficacy of Twice Daily Brimonidine 0.2% versus Betaxolol 0.25% Suspension in Patients with Open-Angle Glaucoma or Ocular Hypertension. Meeting abstract
Shibuya T, Kashiwagi K, Tsukahara S. Comparison of efficacy and tolerability between two gel-forming timolol maleate ophthalmic solutions in patients with glaucoma or ocular hypertension. Ophthalmologica. 2003;217(1):31-8. [pmid: 12566870]. Other (specify):timolol vs timolol
Shields MB, Shields SE. Noncontact transscleral Nd:YAG cyclophotocoagulation: a long-term follow-up of 500 patients. Trans Am Ophthalmol Soc. 94 ;92:271-83. discussion 283–7. Data not abstractable
Shields MB, Wilkerson MH, Echelman DA. A comparison of two energy levels for noncontact transscleral neodymium-YAG cyclophotocoagulation. Arch Ophthalmol. 93 ;111(4):484-7. Data not abstractable
Shiew MMF, O’Brart DPS. Comparison of Trabeculectomy with Viscocanulostomy with Adjunctive Anti-metabolite Usage: A Randomised, Prospective Study. Meeting abstract
Shigeeda T, Tomidokoro A, Chen YN, Shirato S, Araie M. Long-term follow-up of initial trabeculectomy with mitomycin C for primary open-angle glaucoma in Japanese patients. J Glaucoma. 2006;15(3):195-9. [pmid: 16778640]. It is a case series
Shimazaki J, Hanada K, Yagi Y, Yamagami J, Ishioka M, Shimmura S, Tsubota K. Changes in ocular surface caused by antiglaucomatous eyedrops: prospective, randomised study for the comparison of 0.5% timolol v 0. 12% unoprostone. Br J Ophthalmol. 2000;84(11):1250-4. [pmid: 11049949]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Shimazaki J, Yagi Y, Hanada K, Fujishima H, Shinmura S, Tsubota K. CHANGES IN OCULAR SURFACE AND TEARS CAUSED BY ANTI-GLAUCOMA EYEDROPS. Meeting abstract
Shimmyo M. Central corneal thickness and measured IOP response to topical ocular hypotensive medication in the Ocular Hypertension Treatment Study. Am J Ophthalmol. 2005;139(6):1148. author reply 1148–9. [pmid: 15953471]. No original data (e.g., systematic review, narrative review, editorial, letter)
Shin D. Adjunctive therapy with brinzolamide 1% ophthalmic suspension (Azopt((registered trademark))) in patients with open-angle glaucoma or ocular hypertension maintained on timolol therapy. Medical KQ 3 or KQ 3 and KQ 6 only
Shin DH. The Brinzolamide Adjunctive Theraphy Study Group. A TRIPLE-MASKED, PLACEBO-CONTROLLED, ADJUNCTIVE THERAPY STUDY OF THE EFFICACY AND SAFETY OF TID-DOSED BRINZOLAMIDE 1.0% COMPARED TO TID-DOSED PLACEBO WHEN USED ADJUNCTIVELY TO TIMOLOL 0.5%. Meeting abstract
Shin DH. THE EFFICACY AND SAFETY OF BRINZOLAMIDE AS PRIMARY THERAPY FOR OPEN-ANGLE GLAUCOMA AND OCULAR HYPERTENSION. Meeting abstract
Shin DH, Feldman RM, Sheu WP. Efficacy and safety of the fixed combinations latanoprost/timolol versus dorzolamide/timolol in patients with elevated intraocular pressure. Non-FDA-approved drug combination
Shin DH, Frenkel RE, David R, Cheetham JK. Effect of topical anti-inflammatory treatment on the outcome of laser trabeculoplasty. The Fluorometholone-Laser Trabeculoplasty Study Group. Am J Ophthalmol. 96 ;122(3):349-54. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Shin DH, Garadi R. The Timolol Gel Forming Solution 0.5% Study Group. THE IOP-LOWERING EQUIVALENCE OF TIMOLOL MALEATE 0.5% GEL FORMING SOLUTION, QD, TO TIMOLOL 0.5% OPHTHALMIC SOLUTION, BID, IN PATIENTS WITH POAG OR OHT. Meeting abstract
Shin DH, Hughes BA, Song MS, Kim C, Yang KJ, Shah MI, Juzych MS, Obertynski T. Primary glaucoma triple procedure with or without adjunctive mitomycin. Prognostic factors for filtration failure. Ophthalmology. 96 ;103(11):1925-33. It is combined cataract/glaucoma surgery study published before April 2000
Shin DH, Iskander NG, Ahee JA, Singal IP, Kim C, Hughes BA, Eliassi-Rad B, Kim YY. Long-term filtration and visual field outcomes after primary glaucoma triple procedure with and without mitomycin-C. Ophthalmology. 2002;109(9):1607-11. [pmid: 12208706]. Does not address any key questions
Shin DH, Kardasis CT, Kim C, Bsee Juzych MS, Mhsa Hughes BA, Keole NS. Topical verapamil in glaucoma filtration surgery. J Glaucoma. 2001;10(3):211-4. [pmid: 11442185]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Shin DH, Ren J, Juzych MS, Hughes BA, Kim C, Song MS, Yang KJ, Glover KB. Primary glaucoma triple procedure in patients with primary open-angle glaucoma: the effect of mitomycin C in patients with and without prognostic factors for filtration failure. Duplicate
Shin DH, Ren J, Juzych MS, Hughes BA, Kim C, Song MS, Yang KJ, Glover KB. Primary glaucoma triple procedure in patients with primary open-angle glaucomas: The effect of mitomycin C in patients with and without prognostic factors for filtration failure. Am. J. Ophthalmol. 98 ;125(3):346-352. It is combined cataract/glaucoma surgery study published before April 2000
Shin DH, Simone PA, Song MS, Reed SY, Juzych MS, Kim C, Hughes BA. Adjunctive subconjunctival mitomycin C in glaucoma triple procedure. Ophthalmology. 95 ;102(10):1550-8. It is combined cataract/glaucoma surgery study published before April 2000
Shin DH, Vandenbelt SM, Kim PH, Gross JP, Keole NS, Lee SH, Birt CM, Reed SY. Comparison of long-term incidence of posterior capsular opacification between phacoemulsification and phacotrabeculectomy. Am J Ophthalmol. 2002;133(1):40-7. [pmid: 11755838]. Does not address any key questions
Shin IH, Nah YS, Hong YJ, Kim CY. Comparison of surgical outcomes between small collagen and chromic catgut implants in deep sclerectomy. Korean J Ophthalmol. 2002;16(2):75-81. [pmid: 12546443]. It is not a RCT and has less than 100 patients
Shingleton BJ, Campbell CA, O’Donoghue MW. Effects of pupil stretch technique during phacoemulsification on postoperative vision, intraocular pressure, and inflammation. J Cataract Refract Surg. 2006;32(7):1142-5. [pmid: 16857500]. Does not address any key questions
Shingleton BJ, Chaudhry IM, O’Donoghue MW, Baylus SL, King RJ, Chaudhry MB. Phacotrabeculectomy: limbus-based versus fornix-based conjunctival flaps in fellow eyes. Ophthalmology. 99 ; 106(6):1152-5. It is not a RCT and has less than 100 patients
Shingleton BJ, Distler JA, Baker BH. Filtration surgery in black patients: early results in a West Indian population. Ophthalmic Surg. 87 ;18(3):195-9. It is not a RCT and has less than 100 patients
Shingleton BJ, Jacobson LM, Kuperwaser MC. Comparison of combined cataract and glaucoma surgery using planned extracapsular and phacoemulsification techniques. Ophthalmic Surg Lasers. 95 ;26(5):414-9. It is combined cataract/glaucoma surgery study published before April 2000
Shingleton BJ, Price RS, O’Donoghue MW, Goyal S. Comparison of 1-site versus 2-site phacotrabeculectomy. J Cataract Refract Surg. 2006;32(5):799-802. [pmid: 16765798]. It is not a RCT and has less than 100 patients
Shingleton BJ, Richter CU, Bellows AR, Hutchinson BT, Glynn RJ. Long-term efficacy of argon laser trabeculoplasty. Ophthalmology. 87 ;94(12):1513-8. It is a case series
Shingleton BJ, Richter CU, Dharma SK, Tong L, Bellows AR, Hutchinson BT, Glynn RJ. Long-term efficacy of argon laser trabeculoplasty. A 10-year follow-up study. Ophthalmology. 93 ;100(9):1324-9. It is not a RCT and has less than 100 patients
Shiose Y. Clinical trial of timolol maleate ophthalmic solution for glaucoma (author’s transl). Foreign language
Shirakashi M, Yaoeda K, Funaki S, Nakatsue T, Ohta A, Suda K, Hara H, Fukichi T, Abe H. LONG-TERM EFFECT OF TRABECULECTOMY USING AN ANTIMETABOLITE ON VISUAL FIELD DETERIORATION IN NORMAL-TENSION GLAUCOMA. Meeting abstract
Shirato S, Kitazawa Y, Mishima S. A critical analysis of the trabeculectomy results by a prospective follow-up design. Jpn J Ophthalmol. 82 ;26(4):468-80. It is not a RCT and has less than 100 patients
Shmeleva OA. Comparative efficiency of the effects of conservative and surgical methods of treating primary open-angle glaucoma on blood supply of the optic nerve and retina. Foreign language
Shmeleva VV, Mukhina ZA, Nikol’skaia GM. Analysis of the effectiveness of trabeculectomy. Foreign language
Shoji N, Araie M, Shirato S, Nakano Y. A five-year follow-up of the effect of postoperative 5-fluorouracil subconjunctival injections on the surgical outcome of trabeculectomy. Foreign language
Shoji T, Tanito M, Takahashi H, Park M, Hayashi K, Sakurai Y, Nishikawa S, Chihara E. Phacoviscocanalostomy versus cataract surgery only in patients with coexisting normal-tension glaucoma: midterm outcomes. J Cataract Refract Surg. 2007;33(7):1209-16. [pmid: 17586377]. It is not a RCT and has less than 100 patients
Shoji Y. Side effects of opthalmic drugs. Foreign language
Shrader CE, Thomas JV, Simmons RJ. Relationship of patient age and tolerance to carbonic anhydrase inhibitors. Am J Ophthalmol. 83 ;96(6):730-3. Does not address any key questions
Shroff AC. Timolol for treatment of glaucoma. (One year follow up). Indian J Ophthalmol. 82 ;30(4):253-6. It is not a RCT and has less than 100 patients
Shuster J, Kass MA. Timolol and acetazolamide. Ann Ophthalmol. 83 ;15(5):400. No original data (e.g., systematic review, narrative review, editorial, letter)
Siamak NM, Camejo L, Noecker RJ. Comparison of Short-Term Hyperemia and Comfort between Travoprost Solutions Containing Benzalkonium Chloride and No Benzalkonium Chloride. Meeting abstract
Sicakova S, Vyborny P. Selective laser trabeculoplasty in glaucoma treatment--results during three years follow-up. Foreign language
Sidorov EG. Clinical and drug treatment characteristics of glaucoma in young persons. Foreign language
Siegel MJ, Camras CB, Lustgarten JS, Podos SM. EFFECT OF FLURBIPROFEN (FL) ON THE REDUCTION OF INTRAOCULAR PRESSURE (IOP) FOLLOWING PARA-AMINOCLONIDINE (PAC) 1% IN GLAUCOMA PATIENTS. Meeting abstract
Siegner SW, Netland PA, Urban RC Jr, Williams AS, Richards DW, Latina MA, Brandt JD. Clinical experience with the Baerveldt glaucoma drainage implant. Ophthalmology. 95 ;102(9):1298-307. Data not abstractable
Siesky B, Harris A, Brizendine E, Marques C, Loh J, Mackey J, Overton J, Netland P. Literature review and meta-analysis of topical carbonic anhydrase inhibitors and ocular blood flow. Systematic review
Siesky B, Harris A, Cantor LB, Kagemann L, Weitzman Y, McCranor L, Marques C, Werne A, Stefansson E. A comparative study of the effects of brinzolamide and dorzolamide on retinal oxygen saturation and ocular microcirculation in patients with primary open-angle glaucoma. Br J Ophthalmol. 2008;92(4):500-4. [pmid: 18369067]. Data not abstractable
Siesky B, Harris A, Kagemann L, Stefansson E, McCranor L, Miller B, Bwatwa J, Regev G, Ehrlich R. Ocular blood flow and oxygen delivery to the retina in primary open-angle glaucoma patients: the addition of dorzolamide to timolol monotherapy. Medical KQ 3 only
Siesky B, Harris A, Sines D, Rechtman E, Malinovsky VE, McCranor L, Yung CW, Zalish M. A comparative analysis of the effects of the fixed combination of timolol and dorzolamide versus latanoprost plus timolol on ocular hemodynamics and visual function in patients with primary open-angle glaucoma. Unique comparators
Sihota R, Agarwal HC, Rajashekar YL. A comparative evaluation of pilocarpine 1% and clonidine 0.125% versus timolol 0.5%. Indian J Ophthalmol. 96 ;44(2):87-9. Data not abstractable
Sihota R, Agarwal H, Saigal D, Garudadri CS. Comparative Evaluation of Daunorubicin and Mitomycin in High-Risk Glaucomas. Meeting abstract
Sihota R, Rajashekhar YL, Venkatesh P, Agarwal H. A prospective, long-term, randomized study of the efficacy and safety of the drug combination pilocarpine 1% with clonidine 0.06% or clonidine 0.125% versus timolol 0.25%. J Ocul Pharmacol Ther. 2002;18(6):499-506. [pmid: 12537676]. Other (specify):pilo and clonidine
Sihota R, Saxena R, Agarwal HC, Gulati V. Crossover comparison of timolol and latanoprost in chronic primary angle-closure glaucoma. Arch Ophthalmol. 2004;122(2):185-9. [pmid: 14769594]. OAG can’t be analyzed separately
Sihota R, Saxena R, Agarwal HC, Pandey RM, Gulati V. Peak pressures: crossover study of timolol and latanoprost. Medical KQ 3 only
Sihota R, Sharma T, Agarwal HC. Intraoperative mitomycin C and the corneal endothelium. Acta Ophthalmol Scand. 98 ;76(1):80-2. OAG can’t be analyzed separately
Silver LH. Clinical efficacy and safety of brinzolamide (azopt(TM)), a new topical carbonic anhydrase inhibitor for primary open-angle glaucoma and ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Silver LH. Clinical efficacy and safety of brinzolamide (Azopt), a new topical carbonic anhydrase inhibitor for primary open-angle glaucoma and ocular hypertension. Brinzolamide Primary Therapy Study Group. Unique comparators
Silver LH. Ocular comfort of brinzolamide 1.0% ophthalmic suspension compared with dorzolamide 2.0% ophthalmic solution: results from two multicenter comfort studies. Brinzolamide Comfort Study Group. Surv Ophthalmol. 2000;44(Suppl 2):S141-5. [pmid: 10665516]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Silver LH, Brotherman D, Caine R, Smith S, Stewart R, Walters T, Wasserstrom J. Ocular comfort of brinzolamide 1.0% ophthalmic suspension compared with dorzolamide 2.0% ophthalmic solution: Results from two multicenter comfort studies. Survey of Ophthalmology. 2000;44(SUPPL 2):141-145. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Silver LH, Garadi R. Timolol Gel Folding Solution Study Group. THE LONG-TERM SAFETY AND EFFICACY OF TIMOLOL MALEATE GEL FORMING SOLUTION IN PATIENTS WITH OPEN-ANGLE GLAUCOMA OR OCULAR HYPERTENSION. Meeting abstract
Silver LH, Martin W, Hall K, Turner FD. The Brinzolamide Long-Term Therapy Study. AN ASSESSMENT OF CORNEAL HEALTH FOLLOWING LONG-TERM THERAPY WITH BRINZOLAMIDE (AZOPT) IN PATIENTS WITH OPEN-ANGLE GLAUCOMA AND OCULAR HYPERTENSION. Meeting abstract
Silver LH, Von Tress M, Garadi R, McCarty G. The Levobetaxolol Dose-Response Study Group. A Dose-Response Evaluation of the Ocular Hypotensive Effect of Levobetaxolol Ophthalmic Suspension in Patients with Open-Angle Glaucoma or Ocular Hypertension. Meeting abstract
Silverstone BZ, Marcus T. Hypoglycemia due to ophthalmic timolol in a diabetic. Foreign language
Silverstone D, Zimmerman T, Choplin N, Mundorf T, Rose A, Stoecker J, Kelley E, Lue J. Evaluation of once-daily levobunolol 0.25% and timolol 0.25% therapy for increased intraocular pressure. Medical KQ 3 or KQ 3 and KQ 6 only
Silvestre JF, Carnero L, Ramon R, Albares MP, Botella R. Allergic contact dermatitis from apraclonidine in eyedrops. Contact Dermatitis. 2001;45(4):251. [pmid: 11683848]. Does not address any key questions
Simmons RB, Shields MB, Blasini M, Wilkerson M, Stern RA. Transscleral Nd:YAG laser cyclophotocoagulation with a contact lens. Am J Ophthalmol. 91 ;112(6):671-7. Other (specify):Not a comparison of interest
Simmons ST, Brown MM. Comparison of Brimonidine with Latanoprost as Second-Line Therapy in Patients with Glaucoma or Ocular Hypertension. Meeting abstract
Simmons ST, Earl M. COMPARISON OF LATANOPROST AND BRIMONIDINE AT TROUGH DRUG EFFECT IN PATIENTS UNCONTROLLED ON TOPICAL BETA-BLOCKERS. Meeting abstract
Simmons ST, Mehta N. Safety and Efficacy of Brimonidine and Dorzolamide as Adjunctive Therapy in Glaucoma. Meeting abstract
Simmons ST. Alphagan/Xalatan Study Group. THE SAFETY AND EFFICACY OF BRIMONIDINE AND LATANOPROST AS ADJUNCTIVE THERAPY IN GLAUCOMA. Meeting abstract
Simmons ST, Earl ML. Three-month comparison of brimonidine and latanoprost as adjunctive therapy in glaucoma and ocular hypertension patients uncontrolled on beta-blockers: tolerance and peak intraocular pressure lowering. Medical KQ 3 only
Simmons ST, Samuelson TW. Comparison of brimonidine with latanoprost in the adjunctive treatment of glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Simmons ST, Samuelson TW. Comparison of brimonidine with latanoprost in the adjunctive treatment of glaucoma. ALPHAGAN/XALATAN Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
Simmons ST, Samuelson TW. SAFETY AND EFFICACY OF BRIMONIDINE, DORZOLAMIDE AND LATANOPROST AS ADJUNCTIVE THERAPY IN THE TREATMENT OF GLAUCOMA. Meeting abstract
Simmons ST. Efficacy of brimonidine 0.2% and dorzolamide 2% as adjunctive therapy to beta-blockers in adult patients with glaucoma or ocular hypertension. Unique comparators
Simmons ST, Bernstein P, Hollander DA. A comparison of long-term intraocular pressure fluctuation in patients treated with bimatoprost or latanoprost. Medical KQ 3 only
Simon G, Melamed S, Lowery JA. Randomized Clinical Study Results Comparing Titanium:Sapphire Laser. Meeting abstract
Simone PA, Reed SY, Júzych MS, Shin DH, Song MS, Kim C, Sotolongo LB. Adjunctive Subconjunctival Mitomycin C in Glaucoma Triple Procedure. Meeting abstract
Simpson AJ, Gray TB, Ballantyne C. A controlled clinical trial of dorzolamide: a single-centre subset of a multicentre study. Medical KQ 3 or KQ 3 and KQ 6 only
Simsek S, Yulek F, Cakmak HB, Midillioglu IK. Long-term effects of prostaglandin analogues on the anterior chamber depth of patients with primary open-angle glaucoma. Cutan Ocul Toxicol. 2009;28(3):125-8. [pmid: 19653869]. Does not address any key questions (see below for questions), It is not a RCT and has less than 100 patients
Simsek T, Citirik M, Batman A, Mutevelli S, Zilelioglu O. Efficacy and complications of releasable suture trabeculectomy and standard trabeculectomy. Int Ophthalmol. 2005;26(1–2):9-14. [pmid: 16779569]. OAG can’t be analyzed separately
Singer L, Romen M, Isakov I. Rare general side-effects after timolol eyedrops in glaucoma. Foreign language
Singh and Primary Trabeculectomy Antimetabolite Study Group. Intraoperative 5-Fluorouracil (5FU) vs Mitomycin C(MMC): The Primary. Trabeculectomy Antimetabolite Study. Meeting abstract
Singh D. Timolol for glaucoma. Indian J Ophthalmol. 82 ;30(4):227-8. It is not a RCT and has less than 100 patients
Singh K. Primary Trabeculectomy Antimetabolite Study Group. Randomized Clinical Trial of Trabeculectomy with Intraoperative Mitomycin C versus 5-Fluorouracil: Internediate Tests Results. Meeting abstract
Singh K, Egbert PR, Byrd S, Budenz DL, Williams AS, Decker JH, Dadzie P. Trabeculectomy with Intraoperative 5-Flourouracil (5FU) vs. Mitomycin C (MMC): Randomized Clinical. Meeting abstract
Singh K, Egbert PR, Byrd S, Williams AS, Decker JH, Foster RS, Dadzie P. Randomized Clinical Trial of Trabeculectomy with Adjunctive Intraoperative 5-Fluorouracil (5-FU) vs. Mitomycin-C (MMC). Meeting abstract
Singh K, Egbert PR, Byrd S, Budenz DL, Williams AS, Decker JH, Dadzie P. Trabeculectomy with intraoperative 5-fluorouracil vs mitomycin C. Am J Ophthalmol. 97 ;123(1):48-53. [pmid: 6696020]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Singh K, Egbert p, Budenz D, Dadzie P. RISK OF HYPOTONY FOLLOWING ANTIMETABOLITE TRABECULECTOMY IN A BLACK WEST AFRICAN POPULATION. Meeting abstract
Singh K, Mehta K, Shaikh NM, Tsai JC, Moster MR, Budenz DL, Greenfield DS, Chen PP, Cohen JS, Baerveldt GS, Shaikh S. Trabeculectomy with intraoperative mitomycin C versus 5-fluorouracil. Prospective randomized clinical trial. Ophthalmology. 2000;107(12):2305-9. [pmid: 11097613]. OAG can’t be analyzed separately
Singh RP, Goldberg I, Mohsin M. The efficacy and safety of intraoperative and/or postoperative 5-fluorouracil in trabeculectomy and phacotrabeculectomy. Clin Experiment Ophthalmol. 2001;29(5):296-302. [pmid: 11720155]. Data not abstractable
Sirbat D, Charlin JF, Cohn H, Dascotte JC, George JL, Lesure P, Massin M, Massin G, Maurin JF, Renard JP, et al. Efficacy and tolerability of 2 presentations of eyedrops combining carteolol 2% and pilocarpine 2% in primary open-angle glaucoma and simple ocular hypertension. Foreign language
Sirbat D, George JL, Mayeux D, Saudax E, Kohler C, Levan D, Grilliat JP. Effects of systemic blockade of beta-blockers eyedrops. Foreign language
Sirbat D, Kohler C, George JL, Mayeux D, Grilliat JP. Evaluation of the systemic cardiovascular and bronchial effects of beta-blocking eyedrops. Value of isoprenaline and carbachol tests. Therapeutic consequences. Ophtalmologie. 88 ;2(3):213-8. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Siriwardena D, Cordeiro MF, King AJ, Donaldson ML, Wells A, Levin S, Migdal CS, Khaw PT. Human anti-TGFâ2 antibody (CAT-152)as a new modulator of wound healing in glaucoma filtration surgery: longer term follow up data. Meeting abstract
Siriwardena D, Khaw PT, Donaldson ML, King AJ, Migdal C, Cordeiro MF. A randomized placebo-controlled trial of human anti-TGFâ2monoclonal antibody (CAT-152): a new modulator of wound healing following trabeculectomy. Meeting abstract
Siriwardena D, Khaw PT, King AJ, Donaldson ML, Overton BM, Migdal C, Cordeiro MF. Human antitransforming growth factor beta(2) monoclonal antibody--a new modulator of wound healing in trabeculectomy: a randomized placebo controlled clinical study. Ophthalmology. 2002;109(3):427-31. [pmid: 11874742]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Siriwardena D, Khaw PT, King AJ, Donaldson ML, Overton BM, Migdal C, Cordeiro MF. Human antitransforming growth factor beta2 monoclonal antibody - A new modulator of wound healing in trabeculectomy: A randomized placebo controlled clinical study. Ophthalmology. 2002;109(3):427-431. [pmid: 11874742]. Other (specify):ineligible drug
Sirois FJ. Pilocarpine psychosis. Psychosomatics. 2005;46(1):88. [pmid: 15765828]. No original data (e.g., systematic review, narrative review, editorial, letter)
Skorkovska K. Comparison of intraocular pressure lowering efficacy of bimatoprost / timolol fixed combination and other glaucoma medications in the treatment of glaucoma. Foreign language
Skripka VK. Late reseults of trabeculectomy in primary glaucoma taking into account the trophic coefficient. Foreign language
Skuta GL, Beeson CC, Higginbotham EJ, Lichter PR, Musch DC, Bergstrom TJ, Klein TB, Falck FY Jr. Intraoperative mitomycin versus postoperative 5-fluorouracil in high-risk glaucoma filtering surgery. Ophthalmology. 92 ;99(3):438-44. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Slavina TM. Pilocarpine test and the dynamics of daily intraocular pressure fluctuations in open-angle glaucoma. Foreign language
Sleath BL, Krishnadas R, Cho M, Robin AL, Mehta R, Covert D, Tudor G. Patient-reported barriers to glaucoma medication access, use, and adherence in southern India. Indian J Ophthalmol. 2009;57(1):63-8. [pmid: 19075417]. Does not address any key questions
Sleep T. Trabeculectomy and the use of antimetabolites. Insight. 2010;35(1):10-2. [pmid: 20218262]. No original data (e.g., systematic review, narrative review, editorial, letter)
Smith J. Argon laser trabeculoplasty: comparison of bichromatic and monochromatic wavelengths. Ophthalmology. 84 ;91(4):355-60. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Smith JP, Weeks RH, Newland EF, Ward RL. Betaxolol and acetazolamide. Combined ocular hypotensive effect. Arch Ophthalmol. 84 ;102(12):1794-5. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Smith MF, Sherwood MB. A COMPARISON OF THE MOLTENO IMPLANT TO THE ACTSEB (SCHOCKET) PROCEDURE IN THE TREATMENT OF REFRACTORY GLAUCOMAS. Meeting abstract
Smith MF, Doyle JW, Sherwood MB. Comparison of the Baerveldt glaucoma implant with the double-plate Molteno drainage implant. Arch Ophthalmol. 95 ;113(4):444-7. It is not a RCT and has less than 100 patients
Smith MF, Sherwood MB, McGorray SP. Comparison of the double-plate Molteno drainage implant with the Schocket procedure. Arch Ophthalmol. 92 ;110(9):1246-50. Data not abstractable
Smith RJH, Blamires T, Nagasubramanian S. Addition of pindolol to routine medical therapy: A clinical trial. BR. J. OPHTHALMOL. 82 ;66(2):102-108. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Smith RJ, Nagasubramanian S, Watkins R, Poinoosawmy D. Addition of timolol maleate to routine medical therapy: a clinical trial. Unique comparators
Smith SL, Pruitt CA, Sine CS, Hudgins AC, Stewart WC. Latanoprost 0.005% and anterior segment uveitis. Acta Ophthalmol Scand. 99 ;77(6):668-72. Animal or in vitro data
Smith SL, Sine CS, Pruitt CA, Stewart WC. The use of latanoprost 0005% once daily and its effect on intraocular pressure as primary or adjunctive therapy. Unique comparators
Soderstrom MB, Wallin O, Granstrom PA, Thorburn W. Timolol-pilocarpine combined vs timolol and pilocarpine given separately. Am J Ophthalmol. 89 ;107(5):465-70. Other (specify):pilocarpine
Soderstrom M. Medical vs surgical therapy in preventing visual field loss. Ophthalmology. 2003;110(2):249. author reply 249. [pmid: 12578760]. No original data (e.g., systematic review, narrative review, editorial, letter)
Sodhi PK, Pandey RM, Ratan SK. Efficacy and safety of brimonidine, dorzolamide and latanoprost as adjunctive therapy in primary open angle glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Sodhi PK, Verma L, Ratan SK. Increased periocular pigmentation with ocular hypotensive lipid use in African Americans. Am J Ophthalmol. 2004;137(4):783. No original data (e.g., systematic review, narrative review, editorial, letter)
Solish A. Bimatoprost and Travoprost in Clinical Practice of Glaucoma. Meeting abstract
Solish AM, DeLucca PT, Cassel DA, Kolodny AH, Hustad CM, Skobieranda F. Dorzolamide/Timolol fixed combination versus concomitant administration of brimonidine and timolol in patients with elevated intraocular pressure: a 3-month comparison of efficacy, tolerability, and patient-reported measures. Just KQ 2 and/or 5
Soll DB. Evaluation of timolol in chronic open-angle glaucoma Once a day vs twice a day. Arch Ophthalmol. 80 ;98(12):2178-81. It is not a RCT and has less than 100 patients
Song Y-P, Zhu L, Ding Q, Zhao X, Huang P-C. Long-term effect of transscleral diode laser cyclophotocoagulation in treatment of refractory glaucoma. Foreign language
Sonnsjo B, Holmin C, Krakau CE. Occurrence of disc haemorrhages in open-angle glaucoma treated with pilocarpine or timolol. Acta Ophthalmol (Copenh). 91 ;69(2):217-24. Does not address any key questions
Sonntag JR, Brindley GO, Shields MB. Timolol and epinephrine. Comparison of efficacy and side effects. ARCH. OPHTHALMOL. 79 ;97(2):273-277. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Sonty SP, Sonty S, Viana MAG. THE COMPARATIVE OCULAR HYPOTENSIVE EFFECTS OF TIMOLOL, BETAXOLOL AID OPTIPRANOLOL. Meeting abstract
Sonty S, Henry JC, Sharpe ED, Weiss MJ, Stewart JA, Nelson LA, Stewart WC. Success rates for switching to dorzolamide/timolol fixed combination in timolol responders who are insufficiently controlled by latanoprost monotherapy. Acta Ophthalmol. 2008;86(4):419-23. [pmid: 18039347]. It is not a RCT and has less than 100 patients
Sonty S, Mundorf TK, Stewart JA, Stewart WC. Short-term tolerability of once-daily timolol hemihydrate 0.5%, timolol maleate in sorbate 0.5%, and generic timolol maleate gel-forming solution 0.5% in glaucoma and/or ocular hypertension: a prospective, randomized, double-masked, active-controlled, three-period crossover pilot study. Clin Ther. 2009;31(10):2063-71. [pmid: 19922877]. Other (specify):Inadequate control groups, Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Sood S, Wilensky J. Comparative Efficacy of Travoprost vs Latanoprost in Lowering Intraocular Pressure in African Americans. Meeting abstract
Sorensen SJ, Abel SR. Comparison of the ocular beta-blockers (Brief record). Duplicate
Soro-Martinez MI, Villegas-Perez MP, Sobrado-Calvo P, Ruiz-Gomez JM, Miralles de Imperial Mora-Figueroa J. Corneal endothelial cell loss after trabeculectomy or after phacoemulsification, IOL implantation and trabeculectomy in 1 or 2 steps. Graefes Arch Clin Exp Ophthalmol. 2010;248(2):249-56. [pmid: 19834730]. It is not a RCT and has less than 100 patients
Soser M, Ogriseg M, Kessler B, Zirm H. New findings on the effect of azetazolamide (Diamox) on intraocular pressure and acid-base metabolism of the blood following oral administration. Klin Monbl Augenheilkd. 80 ;176(1):88-92. It is not a RCT and has less than 100 patients
Soto J, Diaz S. Does the fixed combination of bimatoprost/timolol really produce a better benefit/risk balance than the fixed combination of latanoprost/timolol. Eur J Ophthalmol. 2010;20(1):246-7. author reply 247–8. [pmid: 20047180]. No original data (e.g., systematic review, narrative review, editorial, letter)
Spaeth GL. Allergic contact dermatitis caused by topical eye drops. Am J Ophthalmol. 2006;142(4):706. [pmid: 17011880]. No original data (e.g., systematic review, narrative review, editorial, letter)
Spaeth GL, Baez KA. Argon laser trabeculoplasty controls one third of cases of progressive, uncontrolled, open angle glaucoma for 5 years. Arch Ophthalmol. 92 ;110(4):491-4. Data not abstractable
Spaeth GL. Potassium, acetazolamide, and intraocular pressure. Arch Ophthalmol. 67 ;78(5):578-82. [pmid: 13911000]. Does not address any key questions
Spaeth GL. The management of patients with conjoint cataract and glaucoma. Ophthalmic Surgery. 80 ;11(11):780-3. It is combined cataract/glaucoma surgery study published before April 2000
Spaeth GL, Bernstein P, Caprioli J, Schiffman RM. Control of Intraocular Pressure and Fluctuation With Fixed-Combination Brimonidine-Timolol Versus Brimonidine or Timolol Monotherapy. Am J Ophthalmol. 2010. other (specify): IOP <18mmHg
Spiegel D. the European Latanoprost Study Group. A comparison of the safety and efficacy of lantanoprost (Xalatan®) versus the fixed combination of dorzolamide and timolol (Cosopt®) in patients with open angle glaucoma. Meeting abstract
Spiegel D, Wegscheider E, Lund OE. Argon laser trabeculoplasty: long-term follow-up of at least 5 years. Ger J Ophthalmol. 92; 1(3–4):156-8. Other (specify):No control
Spiegel D, Wetzel W, Birngruber R. Ab externo erbium YAG laser sclerostomy versus conventional trabeculectomy. Treatment of glaucoma patients. Ophthalmologe. 98 ;95(8):537-41. It is not a RCT and has less than 100 patients
Spiegel D, Wetzel W, Birngruber R. Comparison of the efficacy of ER-YAG laser sclerostomy ab externo versus trabeculectomy in the treatment of patients with primary open - Angle glaucoma. Ab externo-Erbium-YAG-lasersklerostomie versus konventionelle trabekulektomie: Die behandlung von glaukompatienten. Ophthalmologe. 98 ;95(8):537-541. It is not a RCT and has less than 100 patients
Spiegel D, Wetzel W, Neuhann T, Stuermer J, Hoeh H, Garcia-Feijoo J, Martinez-De-La-Casa JM, Garcia-Sanchez J. Coexistent primary open-angle glaucoma and cataract: interim analysis of a trabecular micro-bypass stent and concurrent cataract surgery. Eur J Ophthalmol. 2009;19(3):393-9. [pmid: 19396784]. It is not a RCT and has less than 100 patients
Spinelli D, Curatola MR, Faroni E. Comparison between deep sclerectomy with reticulated hyaluronic acid implant and trabeculectomy in glaucoma surgery. Acta Ophthalmol Scand Suppl. 2000;(232):60-2. [pmid: 11235543]. It is a case series
Sponsel WE, Paris GR, Trigo Y, Weber A, Pena M, Sanford DK. THERAPEUTIC AND PHYSIOLOGIC ALTERATIONS WITH ORAL NSAID USE DURING LATANOPROST AND BRIMONIDINE THERAPY. Meeting abstract
Sponsel WE. Glaucoma suspect treatment trial. Ophthalmology. 90 ;97(4):397. No original data (e.g., systematic review, narrative review, editorial, letter)
Sponsel WE. Quantification and monitoring of visual field defects and a prospective, randomized comparison of pilocarpine and timolol using computerized perimetry. Surv Ophthalmol. 89 ;33(Suppl):427-8. discussion 435–6. Data not abstractable
Sponsel WE. Quantification and monitoring of visual field defects and prospective, randomized comparison of pilocarpine and timolol using computerized perimetry (17). Journal of Glaucoma. 93 ;2(A):S15-19. Data not abstractable
Sponsel WE. Timolol Vs pilocarpine in open angle glaucoma: The observation of significant differences in visual field response in patients with clinically equivalent IOP control. CHIBRET INT. J. OPHTHALMOL. 87 ;5(3):50-56. Other (specify):pilocarpine
Sponsel WE, Paris G, Trigo Y, Pena M. Comparative effects of latanoprost (Xalatan) and unoprostone (Rescula) in patients with open-angle glaucoma and suspected glaucoma. Am J Ophthalmol. 2002;134(4):552-9. [pmid: 12383812]. Other (specify):unoprostone
Sponsel WE, Trigo Y, Pena M, Paris GR, Sanford DK, McKinnon SR. Oral NSAID Effects on Latanoprost and Brimonidine. Meeting abstract
Spooner JJ, Bullano MF, Ikeda LI, Cockerham TR, Waugh WJ, Johnson T, Mozaffari E. Rates of discontinuation and change of glaucoma therapy in a managed care setting. Am J Manag Care. 2002;8(10 Suppl):S262-70. [pmid: 12188169]. OAG can’t be analyzed separately
Sporn A, Scothorn DM, Terry JE. Metabolic acidosis induced by acetazolamide. J Am Optom Assoc. 91 ;62(12):934-7. It is a case series
Sporova NA. Results of the protracted use of prolonged action meiotics in primary glaucoma. Foreign language
Sporova NA, Kozlova LP, Zubareva TV, Cherkasova IN. Effectiveness of treatment of primary glaucoma with prolonged-action pilocarpine. Foreign language
Spratt A, Ogunbowale L, Franks W. Fixed Combination Timolol/Dorzolamide versus Timolol/Brimonidine: A Randomized Clinical Trial. Meeting abstract
Sreckovic S, Petrovic MJ, Petrovic N, Vukosavljevic M. Comparison of primary medicament therapy effects and primary argon laser trabeculoplasty on regulation of intraocular pressure and stability of perimetry findings in open angle glaucoma. Foreign language
Stack RR, McKellar MJ. Black eye drop bottle tips improve compliance. Clin Experiment Ophthalmol. 2004;32(1):39-41. [pmid: 14746589]. Does not address any key questions
Stamper RL, McMenemy MG, Lieberman MF. Hypotonous maculopathy after trabeculectomy with subconjunctival 5-fluorouracil. Am J Ophthalmol. 92 ;114(5):544-53. It is not a RCT and has less than 100 patients
Crisanti Stangogiannis D, Rafael Romero Q, Naranjo Tackman Ram n, Ozorno Zarate Jorge, Gil Carrasco Fqlix. Inducci£n de cambio en el patr£n topogrbfico en la cirugÆa filtrante de glaucoma. Foreign language
Stangos AN, Mavropoulos A, Leuenberger PM, Sunaric-Megevand G. The Effect of Learning Curve on the Surgical Outcome of Viscocanalostomy. J Glaucoma. 2011. Other (specify):Testing physician learning curve only
Stankiewicz A, Wierzbowska J. A multicentre, observative, non-invasive study of the tolerance of NYOLOL gel 0,1% in ocular hypertensive patients. Foreign language
Starita RJ, Fellman RL. Glaucoma treatment with once-daily levobunolol. Am J Ophthalmol. 86 ;102(4):544-7. [pmid: 707601]. No original data (e.g., systematic review, narrative review, editorial, letter)
Starita RJ, Fellman RL, Spaeth GL, Poryzees EM. Effect of varying size of scleral flap and corneal block on trabeculectomy. Ophthalmic Surg. 84 ; 15(6):484-7. OAG can’t be analyzed separately
Starita RJ, Fellman RL, Spaeth GL, Poryzees EM, Greenidge KC, Traverso CE. Short- and long-term effects of postoperative corticosteroids on trabeculectomy. Ophthalmology. 85 ;92(7):938-46. OAG can’t be analyzed separately
Stark WJ, Goyal RK, Awad O, Vito E, Kouzis AC. The safety and efficacy of combined phacoemulsification and trabeculectomy with releasable sutures. Br J Ophthalmol. 2006;90(2):146-9. [pmid: 16424522]. It is a case series
Stawska M. Comparative analysis of the results of modified sinusectomy and trabeculectomy in patients with primary open angle glaucoma. Foreign language
Stead RE, King AJ. Outcome of trabeculectomy with mitomycin C in patients with advanced glaucoma. Br J Ophthalmol. 2011:960-5. [pmid: 21169269]. OAG can’t be analyzed separately
Stecchi G, Saccucci S, Molinari S, De Gregorio F. Eyelash hypertrichosis induced by topical latanoprost: 6-month follow-up study. Acta Ophthalmol Scand Suppl. 2002;236:56-7. [pmid: 12390146]. It is not a RCT and has less than 100 patients
Stefan C, Dumitrica DM. Ocular surface disfunction in glaucoma. Foreign language
Stefan C, Cucea R, Urena-Saenz JM. Pseudoexfoliative glaucoma. Foreign language
Stefan C, Neacsu A, Balas M, Nenciu A, Lascu L. Trabeculectomy and nonpenetrating surgery in glaucoma. Foreign language
Stefanescu-Dima AS, Mocanu C, Manescu R, Sfanescu-Dima MA. Laser trabeculoplasty--a prospective study. Foreign language
Stefaniu I, Zemba M, Nitulescu C, Nita N. A comparative study of the results of 2 technical variants of protective trabeculectomy. Foreign language
Stefaniu I, Zemba M, Nitulescu C, Nita N. Comparison between two therapeutic approaches in patients with cataract and glaucoma. Foreign language
Stefansson E, Guomundsdottir E, Sigurjonsdottir J, Bjarnadottir G, Masson M. Cyclodextrin drug delivery group. Methazolamide 1% in cyclodextrin aqueous eye drops lowers intraocular pressure in ocular hypertensive humans. Meeting abstract
Stegmann R, Pienaar A, Miller D. Viscocanalostomy for open-angle glaucoma in black African patients. J Cataract Refract Surg. 99 ; 25(3):316-22. It is not a RCT and has less than 100 patients
Steigerwalt RD Jr, Belcaro G, Morazzoni P, Bombardelli E, Burki C, Schonlau F. Mirtogenol(registered trademark) potentiates latanoprost in lowering intraocular pressure and improves ocular blood flow in asymptomatic subjects. Duplicate of 117
Steigerwalt RD, Belcaro G, Morazzoni P, Bombardelli E, Burki C, Schonlau F. Mirtogenol potentiates latanoprost in lowering intraocular pressure and improves ocular blood flow in asymptomatic subjects. Clin Ophthalmol. 2010;4:471-6. [pmid: 20505841]. other (specify):not FDA approved, Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Stein JD, McCoy AN, Asrani S, Herndon LW, Lee PP, McKinnon SJ, Allingham RR, Challa P. Surgical management of hypotony owing to overfiltration in eyes receiving glaucoma drainage devices. J Glaucoma. 2009;18(8):638-41. [pmid: 19826394]. It is a case series
Stein JD, Ruiz D Jr, Belsky D, Lee PP, Sloan FA. Longitudinal rates of postoperative adverse outcomes after glaucoma surgery among medicare beneficiaries 1994 to 2005. Ophthalmology. 2008;115(7):1109-1116. e7. [pmid: 18598818]. OAG can’t be analyzed separately
Stepanik J. Timolol versus Diamox (author’s transl). Klin Monbl Augenheilkd. 81 ;179(4):280-2. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Steurich F, Theis FR. Bronchial obstruction caused by eyedrops. Prax Klin Pneumol. 85 ;39(4):122-6. It is a case series
Stewart JA, Cvenkel B, Nelson LA, Stewart WC. Dorzolamide/Timolol Maleate Fixed Combination Given Twice Daily versus Latanoprost/Timolol Maleate Fixed Combination Given Once Every Morning in Patients With Primary Open-Angle Glaucoma or Ocular Hypertension. Meeting abstract
Stewart JA, Day DG, Sharpe ED, Stewart WC. Efficacy and Safety of Latanoprost/Timolol Maleate Fixed Combination Verses Timolol Maleate and Brimonidine Given Twice Daily. Meeting abstract
Stewart JA, Kent AR, Dubiner HB, Whitaker R, Mundorf TK, Stewart WC. THE EFFICACY AND SAFETY OF DICLOFENAC 0.1 % VERSUS PREDNISOLONE ACETATE 1 % FOLLOWING TRABECULECTOMY WITH ADJUNCTIVE MITOMYCIN-C. Meeting abstract
Stewart JA, Koester J, Kapik B, Pugh S, Stewart WC. THE IOP DIURNAL CURVE IN COAG OR OHT PATIENTS TREATED WITH RESCULA 0.12% OR TIMOLOL MALEATE 0.5%. Meeting abstract
Stewart JA, Stewart WC, Day DG, Sharpe ED, Leech JN. Efficacy and Safety of Latanoprost/timolol Maleate Fixed Combination versus Brimonidine Given Twice Daily and Latanoprost Given Each Evening. Meeting abstract
Stewart R. The Brinzolamide Comfort Study Group. THE OCULAR COMFORT OF TID-DOSED BRINZOLAMIDE 1.0% COMPARED TO TID-DOSED DORZOLAMIDE 2.0% IN PATIENTS WITH PRIMARY OPEN-ANGLE GLAUCOMA OR OCULAR HYPERTENSION. Meeting abstract
Stewart RH, Kimbrough RL, Ward RL. Betaxolol vs timolol. A six-month double-blind comparison. Medical KQ 3 or KQ 3 and KQ 6 only
Stewart WC, Harasymowycz P, Hutnik CML, Nicolela M. The Efficacy and Safety of Latanoprost 0005% versus Timolol Maleate 05% Gel Forming Solution Each Given Once Every Evening in Primary Open-Angle Glaucoma or Ocular Hypertension. Meeting abstract
Stewart WC, Mundorf T, Haque R, Brown A, Kapik B, Shams N. The Unoprostone Study Group. Comparison of the IOP-lowering efficacy and safety of the docosanoid unoprostone isopropyl 0.15% versus timolol maleate 0.5% dosed twice daily for 6 months in patients with primary open-angle glaucoma or ocular hypertension. Meeting abstract
Stewart WC, Pitts RA. Postoperative prognostic indicators following trabeculectomy. Acta Ophthalmol (Copenh). 93 ;71(6):733-8. Does not address any key questions
Stewart WC. THE USE OF SUBCONJUNCTIVAL 5-FLUOROURACIL FOLLOWING COMBINED TRABECULECTOMY AND CATARACT EXTRACTION. Meeting abstract
Stewart WC. Timolol hemihydrate: a new formulation of timolol for the treatment of glaucoma. J Ocul Pharmacol Ther. 96(2):225-37. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Stewart WC, Cohen JS, Netland PA, Weiss H, Nussbaum LL. Efficacy of carteolol hydrochloride 1% vs timolol maleate 0.5% in patients with increased intraocular pressure. Nocturnal Investigation of Glaucoma Hemodynamics Trial Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
Stewart WC, Cohen JS, Netland PA, Weiss H, Nussbaum LL, Abrams D, Schwartz G, Hughes P, Adelson A, Brink M, Myers M, Bahr R, Dowling JL Jr, Richards F, Geltzer A, Hofmann RJ, Snady-McCoy L, Bartnik LA, Beneke J, Barr L, Muroski D, Neal J, Clevenger C, Summitt B, Lee A, Cohen J, Riccio KA, Luechauer A, DuBiner H, Cribbs S, Laibovitz R, Neck K, Mundorf T, Otero D, Netland PA, Vivolo DA, Schwartz L, Carmichael P, Conner R, Nowinski T, Keselring J, Bollenbach A, Foley A, Stewart W, Stewart J, Chase C, Weiss H, Schwartz A, Latham BD. Efficacy of carteolol hydrochloride 1% vs timolol maleate 0.5% in patients with increased intraocular pressure. Duplicate
Stewart WC, Crinkley CM, Carlson AN. Fornix- vs. limbus-based flaps in combined phacoemulsification and trabeculectomy. Doc Ophthalmol. 94 ;88(2):141-51. It is combined cataract/glaucoma surgery study published before April 2000
Stewart WC, Crinkley CM, Carlson AN. Results of combined phacoemulsification and trabeculectomy in patients with elevated preoperative intraocular pressures. J Glaucoma. 95 ;4(3):164-9. It is not a RCT and has less than 100 patients
Stewart WC, Crinkley CM, Carlson AN. Results of trabeculectomy combined with phacoemulsification versus trabeculectomy combined with extracapsular cataract extraction in patients with advanced glaucoma. Ophthalmic Surg. 94;25(9):621-7. It is combined cataract/glaucoma surgery study published before April 2000
Stewart WC, Day DG, Holmes KT, Stewart JA. Effect of timolol 0.5% gel and solution on pulmonary function in older glaucoma patients. J Glaucoma. 2001;10(3):227-32. [pmid: 11442188]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Stewart WC, Day DG, Sharpe ED, Dubiner HB, Holmes KT, Stewart JA. Efficacy and safety of timolol solution once daily vs timolol gel added to latanoprost. Unique comparators
Stewart WC, Day DG, Stewart JA, Holmes KT, Jenkins JN. Short-term ocular tolerability of dorzolamide 2% and brinzolamide 1% vs placebo in primary open-angle glaucoma and ocular hypertension subjects. Eye (Lond). 2004;18(9):905-10. [pmid: 15002017]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Stewart WC, Day DG, Stewart JA, Holmes KT, Leech JN, Rowan CT, Schwartz GF. Therapeutic success of latanoprost 0.005% compared to brimonidine 0.2% in patients with open-angle glaucoma or ocular hypertension. J Ocul Pharmacol Ther. 2000;16(6):557-64. [pmid: 11132902]. Other (specify):study design does not match KQ (KQ3)
Stewart WC, Day DG, Stewart JA, Schuhr J, Latham KE. The efficacy and safety of latanoprost 0005% once daily versus brimonidine 0.2% twice daily in open-angle glaucoma or ocular hypertension. Medical KQ 3 only
Stewart WC, Dubiner HB, Mundorf TK, Laibovitz RA, Sall KN, Katz LJ, Singh K, Shulman DG, Siegel LI, Hudgins AC, Nussbaum L, Apostolaros M. Effects of carteolol and timolol on plasma lipid profiles in older women with ocular hypertension or primary open-angle glaucoma. Am J Ophthalmol. 99;127(2):142-7. Data not abstractable
Stewart WC, Halper LK, Johnson-Pratt L, Polis A, Hartenbaum D. Tolerability and efficacy of dorzolamide versus acetazolamide added to timolol. Unique comparators
Stewart WC, Halper LK, Najarian D, Johnson-Pratt L, Hartenbaum D. TOLERABILITY AND EFFICACY OF DORZOLAMIDE VERSUS ACETAZOLANIIDE IN PATIENTS WITH OCULAR HYPERTENSION OR OPEN-ANGLE GLAUCOMA. Meeting abstract
Stewart WC, Hollo G, Passmore CL. The Efficacy of Timolol Maleate 0.5% versus Brinzolamide 1% Each Given Twice Daily Added to Travoprost 0.004% in Patients With Ocular Hypertension or Open-angle Glaucoma. Meeting abstract
Stewart WC, Konstas AGP, Kozobolis VP, Tersis I, Leech JN. The Efficacy and Safety of the Timolol/dorzolamide Fixed Combination Versus Latanoprost in Exfoliation Glaucoma. Meeting abstract
Stewart WC, Konstas AG, Kruft B, Mathis HM, Stewart JA. Meta-analysis of 24-h intraocular pressure fluctuation studies and the efficacy of glaucoma medicines. Systematic review
Stewart WC, Kristoffersen CJ, Demos CM, Fsadni MG, Stewart JA. Incidence of conjunctival exposure following drainage device implantation in patients with glaucoma. Systematic review
Stewart WC, Laibovitz R, Horwitz B, Stewart RH, Ritch R, Kottler M. A 90-day study of the efficacy and side effects of 0.25% and 0.5% apraclonidine vs 0.5% timolol. Apraclonidine Primary Therapy Study Group. Arch Ophthalmol. 96;114(8):938-42. Data not abstractable
Stewart WC, Laibovitz R, Horwitz B, Stewart RH, Ritch R, Kottler M. A 90-day study of the efficacy and side effects of 0.25% and 0.5% apraclonidine vs 0.5% timolol. ARCH. OPHTHALMOL. 96; 114(8):938-942. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Stewart WC, Leland TM, Cate EA, Stewart JA. Efficacy and safety of timolol solution once daily versus timolol gel in treating elevated intraocular pressure. Medical KQ 3 or KQ 3 and KQ 6 only
Stewart WC, Pfeiffer N, Mathis HM. Meta-analysis of articles evaluating routine intraocular pressure control in monotherapy in the United States and Germany. Systematic review
Stewart WC, Ritch R, Shin DH, Lehmann RP, Shrader CE, van Buskirk EM. The efficacy of apraclonidine as an adjunct to timolol therapy. Apraclonidine Adjunctive Therapy Study Group. Arch Ophthalmol. 95;113(3):287-92. Data not abstractable
Stewart WC, Ritch R, Shin DH, Lehmann RP, Shrader CE, Van Buskirk EM. The efficacy of apraclonidine as an adjunct to timolol therapy. ARCH. OPHTHALMOL. 95;113(3):287-292. Other (specify):apraclonidine
Stewart WC, Sharpe ED, Day DG, Kolker AE, Konstas AG, Lee WH, Rieser JC, Chopra H, Holmes KT. Comparison of the efficacy and safety of latanoprost 0.005% compared to brimonidine 0.2% or dorzolamide 2% when added to a topical beta-adrenergic blocker in patients with primary open-angle glaucoma or ocular hypertension. J Ocul Pharmacol Ther. 2000;16(3):251-9. [pmid: 10872922]. It is a case series
Stewart WC, Sharpe ED, Harbin TS Jr, Pastor SA, Day DG, Holmes KT, Stewart JA. Brimonidine 0.2% versus dorzolamide 2% each given three times daily to reduce intraocular pressure. Medical KQ 3 or KQ 3 and KQ 6 only
Stewart WC, Sharpe ED, Stewart JA, Hott CE. The safety and efficacy of timolol 0.5% in xanthan gum versus timolol gel forming solution 0.5%. Unique comparators
Stewart WC, Sharpe ED, Stewart JA, Holmes KT, Latham KE. Additive efficacy of unoprostone isopropyl 0.12% (rescula) to latanoprost 0.005%. Am J Ophthalmol. 2001;131(3):339-44. [pmid: 11239866]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Stewart WC, Sharpe ED, Williams RD, Nelson LA, Stewart JA. A Comparison of Dorzolamide/Timolol Maleate Fixed Combination versus Bimatoprost in Primary Open-Angle Glaucoma Patients Who Are Insufficiently Controlled on Latanoprost. Meeting abstract
Stewart WC, Shields MB, Allen RC, Lewis RA, Cohen JS, Hoskins HD, Hetherington JN, Bahr RL, Noblin JE, Delehanty JT. A 3-month comparison of 1% and 2% carteolol and 0.5% timolol in open-angle glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Stewart WC, Sine CS, Carlson AN. Three-millimeter versus 6-mm incisions in combined phacoemulsification and trabeculectomy. Ophthalmic Surg Lasers. 96;27(10):832-8. It is combined cataract/glaucoma surgery study published before April 2000
Stewart WC, Sine CS, LoPresto C. Surgical vs medical management of chronic open-angle glaucoma. Am J Ophthalmol. 96; 122(6):767-74. Does not address any key questions
Stewart WC, Stewart JA, Day DG, Jenkins J. The safety and efficacy of unoprostone 0.15% versus brimonidine 0.2%. Acta Ophthalmol Scand. 2004;82(2):161-5. [pmid: 15043534]. ther (specify):Unoprostone
Stewart WC, Stewart JA, Day DG, Sharpe ED, Jenkins JN. Efficacy and safety of the latanoprost/timolol maleate fixed combination vs concomitant brimonidine and latanoprost therapy. Eye (Lond). 2004;18(10):990-5. [pmid: 15037890]. Other (specify):combination not FDA approved
Stewart WC, Stewart JA, Day D, Sharpe ED. Efficacy and safety of timolol maleate/latanoprost fixed combination versus timolol maleate and brimonidine given twice daily. Non-FDA-approved drug combination
Stewart WC, Stewart JA, Demos CM, Turner M. Serious adverse event reporting. Ophthalmology. 2009;116(12):2485-2485. e1. [pmid: 19948292]. No original data (e.g., systematic review, narrative review, editorial, letter)
Stewart W, Beehler C, McDonald D, Croyle T, Ostrov C, Rosanelli E, Crandall A. THE EFFICACY OF LEVOBUNOLOL 0.25% BID IN PATIENTS SWITCHED FROM TIMOLOL 0.5% BID THERAPY. Meeting abstract
Stillitano Iane Gongalves, Ribeiro Marco Polo, Brandt Carlos Teixeira, Cabral Juliana. Impaacto economico do custo de colÆrios no tratamento da Glaucoma. Foreign language
Stilma JS. Trabeculectomy with 5-fluorouracil in complicated glaucoma. Klin Oczna. 93;95(2):81-3. OAG can’t be analyzed separately
Stodtmeister R, Brenner J, Baur MP. The action of stabilised pilocarpine drops on the human eye (author’s transl). Klin Monbl Augenheilkd. 77;170(5):750-3. Does not address any key questions
Storr-Paulsen A, Pedersen JH, Laugesen C. A prospective study of combined phacoemulsification-trabeculectomy versus conventional phacoemulsification in cataract patients with coexisting open angle glaucoma. Acta Ophthalmol Scand. 98;76(6):696-9. It is not a RCT and has less than 100 patients
Stoudemire A, Houpt JL. Carbonic anhydrase inhibitors: an underrecognized cause of psychiatric symptoms. Psychiatr Med. 83;1(3):353-5. No original data (e.g., systematic review, narrative review, editorial, letter)
Strahlman ER, Barber BL, Laibovitz RB. A COMPARISON OF QUALITY OF LIFE AND PATIENT PREFFERENCE OF DORZOLAMIDE AND PILOCARPINE AS ADJUNCTIVE THERAPY TO TIMOLOL IN THE TREATMENT OF GLAUCOMA. Meeting abstract
Strahlman ER, Deasy D, Panebianco D. A TWO-WEEK PILOT ACTIVITY STUDY OF A FIXED COMBINATION OF TIMOLOL AND DORZOLAMIDE HYDROCHLORIDE. Meeting abstract
Strahlman ER, Lippa EA, Tipping R, Smith B, Strohmaier K. Dorzolamide/Beta-Blocker Comparison Study Group. A CONTROLLED CLINICAL TRIAL OF 2.0% DORZOLAMIDE (MK-507) COMPARED TO TIMOLOL AND BETAXOLOL. Meeting abstract
Strahlman ER, Vogel R, Tipping R, Clineschmidt CM. The use of dorzolamide and pilocarpine as adjunctive therapy to timolol in patients with elevated intraocular pressure. OPHTHALMOLOGY. 96; 103(8):1283-1293. Other (specify):pilocarpine
Strahlman ER, Vogel R, Tipping R, Clineschmidt CM. The use of dorzolamide and pilocarpine as adjunctive therapy to timolol in patients with elevated intraocular pressure. The Dorzolamide Additivity Study Group. Duplicate 8395
Strahlman E, Tipping R, Vogel R. A double-masked, randomized 1-year study comparing dorzolamide (Trusopt), timolol, and betaxolol. Medical KQ 3 or KQ 3 and KQ 6 only
Strahlman E, Tipping R, Vogel R. A double-masked, randomized 1-year study comparing dorzolamide (Trusopt), timolol, and betaxolol. International Dorzolamide Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
Strahlman E, Tipping R, Vogel R. A six-week dose-response study of the ocular hypotensive effect of dorzolamide with a one-year extension. Dorzolamide Dose-Response Study Group. Duplicate 8392
Strahlman E, Tipping R, Vogel R, Abrantes P, Alm A, Airaksinen PJ, Barnebey H, Borgeois A, Cohen JS, Collignon-Brach J, Cyrlin MN, Demailly P, Ehinger B, George JL, Greve E, Gross RL, Higginbotham EJ, Kass MA, Laibovitz RA, et al. A six-week dose-response study of the ocular hypotensive effect of dorzolamide with a one-year extension. Unique comparators
Strempel I. Immediate effect of a topical beta-blocker on breakup time. Ophthalmologica. 86;192(1):11-6. short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Strempel I. Long-term results in the treatment of glaucoma with beta-adrenergic blocking agents. Trans Ophthalmol Soc N Z. 81;33:21-3. It is not a RCT and has less than 100 patients
Strempel I. The influence of topical beta-blockers on the breakup time. Ophthalmologica. 84;189(3):110-5. No subjects with open-angle glaucoma
Strohmaier K, Snyder E, Adamsons I. A multicenter study comparing dorzolamide and pilocarpine as adjunctive therapy to timolol: patient preference and impact on daily life. J Am Optom Assoc. 98;69(7):441-51. Other (specify):pilocarpine
Strohmaier K, Snyder E, DuBiner H, Adamsons I. The efficacy and safety of the dorzolamide-timolol combination versus the concomitant administration of its components. Medical KQ 3 or KQ 3 and KQ 6 only
Strohmaier K, Snyder E, DuBiner H, Adamsons I. The efficacy and safety of the dorzolamide-timolol combination versus the concomitant administration of its components. Dorzolamide-Timolol Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
Strouthidis NG, Demirel S, Asaoka R, Cossio-Zuniga C, Garway-Heath DF. The Heidelberg retina tomograph Glaucoma Probability Score: reproducibility and measurement of progression. Systematic review
Stryz JR, Merte HJ. Pressure lowering effect and side effects of 0.5% and 1.0% levobunolol eyedrops, compared with 0.5% timolol eyedrops in patients with open-angle glaucoma. Foreign language
Stryz JR, Merte HJ. Results of 1-year use of local pindolol in open-angle glaucoma. Klin Monbl Augenheilkd. 85;186(1):43-5. It is not a RCT and has less than 100 patients
Sturm A, Vogel R, Binkowitz B. The Timolol-Pilocarpine Clinical Study Groups. A fixed combination of Timolol and Pilocarpine: double-masked comparisons with timolol and with pilocarpine. Excluded drug
Subrez Pqrez Juana Caridad, La Rosa Chibbs Teresa. Uso del 5-fluoracilo en la trabeculectomÆa y escleroctomÆa profunda perforante durante cinco a±os. Foreign language
Sud RN, Grewal SS, Stevens Johnson. syndrome due to Diamox. Indian J Ophthalmol. 81;29(2):101-3. It is a case series
Suda K. Our investigations on glaucoma studies at the department of ophthalmology, Kumamoto University. Foreign language
Sudesh S, Cohen EJ, Rapuano CJ, Wilson RP. Corneal toxicity associated with latanoprost. Arch Ophthalmol. 99;117(4):539-40. It is a case series
Sugimoto R, Kuwayama Y, Hashitani T, Tanaka Y. COMPARISON OF TIMOLOL AND UNOPROSTONE IN CIRCADIAN VARIATION OF HYPOTENSIVE EFFECT. Meeting abstract
Sugiyama T, Kojima S, Ishida O, Ikeda T. Changes in optic nerve head blood flow induced by the combined therapy of latanoprost and beta blockers. Acta Ophthalmol. 2009;87(7):797-800. [pmid: 19053956]. Does not address any key questions
Sugiyama T, Shibata M, Kojima S, Ueki M, Ikeda T. The first report on intermediate-term outcome of Ex-PRESS glaucoma filtration device implanted under scleral flap in Japanese patients. Clin Ophthalmol. 2011:1063-6. [pmid: 21847337]. It is not a RCT and has less than 100 patients
Suh MH, Park KH, Kim DM. Effect of travoprost on intraocular pressure during 12 months of treatment for normal-tension glaucoma. Jpn J Ophthalmol. 2009;53(1):18-23. [pmid: 19184304]. It is not a RCT and has less than 100 patients
Suic SP, Laus KN, Dosen VM, Ekert M, Mandic Z, Bojic L. Comparison of evening and morning dosing of travoprost 0.004%/timolol 0.5% fixed combination in 6 month period. Coll Antropol. 2010;34(3):847-52. [pmid: 20977071]. It is not a RCT and has less than 100 patients
Sullivan-Mee M, Pensyl D, Alldredge B, Halverson K, Gerhardt G, Qualls C. Brimonidine hypersensitivity when switching between 0.2% and 0.15% formulations. Systematic review
Sultan MB, Mansberger SL, Lee PP. Understanding the importance of IOP variables in glaucoma: a systematic review. Systematic review
Sun Y-B, Sun Z-S, Wang X-L. Clinical analysis of combined phacoemulsification, intraocular lens implantation and trabeculectomy for cataract patients withglaucoma. Foreign language
Sung VC, Butler TK, Vernon SA. Non-enhanced trabeculectomy by non-glaucoma specialists: are results related to risk factors for failure?. Eye (Lond). 2001;(Pt 1):45-51. [pmid: 11318294]. It is a case series
Suominen S, Valimaki J. Bilateral anterior uveitis associated with travoprost. Acta Ophthalmol Scand. 2006;84(2):275-6. [pmid: 16637856]. No original data (e.g., systematic review, narrative review, editorial, letter)
Susanna Junior Remo, Costa Vital Paulino. Estudo comparativo entre o maleato de timolol 0.5 e betaxolol 0.5 na redugåo da pressåo intra-ocular de pacientes submetidos a trabeculectomia. Foreign language
Susanna Junior Takahashi Walter Y. Estudo comparativo entre o uso do 5-fluoro-uracil e da mitomicina em olhos trabeculectomizados. Foreign language
Susanna R Jr, Sheu WP. Comparison of latanoprost with fixed-combination dorzolamide and timolol in adult patients with elevated intraocular pressure: an eight-week, randomized, open-label, parallel-group, multicenter study in Latin America. Medical KQ 3 or KQ 3 and KQ 6 only
Susanna R Jr, Giampani J Jr, Borges AS, Vessani RM, Jordao ML. A double-masked, randomized clinical trial comparing latanoprost with unoprostone in patients with open-angle glaucoma or ocular hypertension. Ophthalmology. 2001;108(2):259-63. [pmid: 11158796]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Susanna R Jr, Nicolela MT, Oga E. Additive effect of latanoprost to the combination of timolol and dorzolamide. J Glaucoma. 2000;9(2):183-6. [pmid: 10782630]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Sussman Adriana, Vives Patricia. Bolsa encapsulada en cirugÆa filtrante con base fornix y base limbo. Foreign language
Sutton B. Xalatan difficulties. J Am Optom Assoc. 97;68(4):214. It is a case series
Suzuki ER Jr, Franklin LM, da Silva LJ, Figueiredo CR, Netto JA, Batista WD. Comparison of the efficacy and safety of travoprost with a fixed-combination of dorzolamide and timolol in patients with open-angle glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Suzuki M, Mishima HK, Masuda K, Araie M, Kitazawa Y, Azuma I. Efficacy and safety of latanoprost eye drops for glaucoma treatment: a 1-year study in Japan. Jpn J Ophthalmol. 2000;44(1):33-8. [pmid: 10698023]. Other (specify):Study design does not match KQ (KQ3)
Svacinova J, Zouharova M. Electro-tonography study of patients treated with Timoptic. Foreign language
Svedbergh B, Sherwood M. Argon laser trabeculoplasty in exfoliation glaucoma. A retrospective analysis. Dev Ophthalmol. 85;11:116-23. It is not a RCT and has less than 100 patients
Svedbergh B, Bodin L, Bergea B. PRIMARY ARGON LASER TRABECULOPLASTY VERSUS PILOCARPINE. Meeting abstract
Sveinsson O, Sigurdsson T, Hovding G. Trabeculectomy and gelatin implants. A retrospective, long-term follow-up study. Acta Ophthalmol (Copenh). 92;70(5):645-50. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Sverrisson T, Gross R, Pearson J, Rusk C, Adamsons I, Gloor B, Goethals M, Kestelijn P, Ladenvall G, Mermoud A, Poland W, Sverrisson T, Thygesen J. The dorzolamide/timolol combination versus timolol plus pilocarpine: Patient preference and impact on daily life. J. Glaucoma. 99;8(5):315-324. Other (specify):pilocarpine
Sverrisson T, Gross R, Pearson J, Rusk C, Adamsons I. The dorzolamide/timolol combination versus timolol plus pilocarpine: patient preference and impact on daily life. United States Patient Preference Study Group. International Patient Preference Study Group. J Glaucoma. 99;8(5):315-24. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Swendris RP, Shin DH, Hong YJ. APRACLONIDINE VERSUS TIMOLOL PRETREATMENT IN THE PREVENTION OF INTRAOCULAR PRESSURE SPIKES FOLLOWING ARGON LASER TRABECULOPLASTY. Meeting abstract
Swendris R, Chou F, Shin D, Parrow K, Uhm K, Juzych M. TRABECULECTOMY WITH RELEASABLE SCLERAL FLAP SUTURES AND ADJUNCTIVE LOW DOSE 5-FLUOROURACIL VERSUS MOLTENO IMPLANT IN ADVANCED APHAKIC AND PSEUDOPHAKIC GLAUCOMA. Meeting abstract
Sycha T, Vass C, Findl O, Bauer P, Groke I, Schmetterer L, Eichler HG. WITHDRAWN: Interventions for normal tension glaucoma. Systematic review
Sycha T, Vass C, Findl O, Bauer P, Groke I, Schmetterer L, Eichler H. Interventions for normal tension glaucoma. Duplicate of 202
Szaflik J, Liberek I, Kaminska A, Chudzynska-Zawadzka D, Borucka AI, Sklodowska A. Phacoemulsification combined with trabeculectomy from personal material. Foreign language
Szaflik J, Zawadzka D, Zaleska-Zmijewska A. Diode laser cyclophotocoagulation--effect on intraocular pressure in comparison with cyclodiathermy under the scleral flap. Foreign language
Szymanski A, Brozyna-Zylka B, Sobieraj A, Otrzonsek D. Surgical treatment of low pressure glaucoma. Foreign language
Tabak S, de Waard PWT, Lemij HG, Remeijer L. Selective laser trabeculoplasty in glaucoma. Meeting abstract
Takahashi I, Tanaka M. Switching to latanoprost monotherapy for 24 weeks in glaucoma patients. Eur J Ophthalmol. 2004;(5):401-6. [pmid: 15506602]. It is not a RCT and has less than 100 patients
Takahashi N. Cytotoxic effects of antiglaucoma agents on cultured human conjunctival cells (author’s transl). Foreign language
Takihara Y, Inatani M, Seto T, Iwao K, Iwao M, Inoue T, Kasaoka N, Murakami A, Futa R, Tanihara H. Trabeculectomy with mitomycin for open-angle glaucoma in phakic vs pseudophakic eyes after phacoemulsification. Arch Ophthalmol. 2011;129:152-7. [pmid: 21320958]. Does not address any key questions
Takki KK, Klemetti A, Valle O. The IOP-lowering effect of timolol in simple and capsular glaucoma. A multicenter study in Finland. Graefes Arch Clin Exp Ophthalmol. 82;218(2):83-7. Other (specify):STudy design does not match KQ (KQ3)
Takmaz T, Asik S, Kurkcuoglu P, Gurdal C, Can I. Comparison of intraocular pressure lowering effect of once daily morning vs evening dosing of latanoprost/timolol maleate combination. Eur J Ophthalmol. 2008;18(1):60-5. [pmid: 18203086]. Other (specify):combination not FDA approved
Tamcelik N, Ozkiris A, Sarici AM. Long-term results of combined viscotrabeculotomy-trabeculectomy in refractory developmental glaucoma. Eye (Lond). 2010;24(4):613-8. [pmid: 19730447]. No subjects with open-angle glaucoma
Tamer C, Oksuz H. Circadian intraocular pressure control with dorzolamide versus timolol maleate add-on treatments in primary open-angle glaucoma patients using latanoprost. Unique comparator
Tan YL, Tsou PF, Tan GS, Perera SA, Ho CL, Wong TT, Aung T. Postoperative Complications After Glaucoma Surgery for Primary Angle-Closure Glaucoma vs Primary Open-Angle Glaucoma. Arch Ophthalmol. 2011;129:987-92. [pmid: 21482857]. Does not address any key questions
Tanaka GH, Vold SD, Ruderman JM. PRIMARY COMBINED PHACOEMULSIFICATION AND TRABECULECTOMY VERSUS PHACOEMULSIFICATION ALONE IN PATIENTS WITH WELL-CONTROLLED GLAUCOMA: EARLY OUTCOMES. Meeting abstract
Tanenbarm H, Connor C, Simmons ST. Alphagan/Trusopt Study Group. A PHARMACOECONOMIC ANALYSIS COMPARING BRIMONIDINE BID TO DORZOLAMIDE TID AS ADJUNCTIVE THERAPY IN GLAUCOMA. Meeting abstract
Taniguchi M, Kino H, Mori M, Nakahama M. A case of fatal asthma induced by timolol eye-drop. Foreign language
Taniguchi T, Kitazawa Y, Shimizu U. Long-term results of 5-fluorouracil trabeculectomy for primary open-angle glaucoma. Int Ophthalmol. 89; 13(1–2):145-9. It is not a RCT and has less than 100 patients
Tanihara H, Negi A, Akimoto M, Terauchi H, Okudaira A, Kozaki J, Takeuchi A, Nagata M. Surgical effects of trabeculotomy ab externo on adult eyes with primary open angle glaucoma and pseudoexfoliation syndrome. Arch Ophthalmol. 93;111(12):1653-61. \Other (specify):No control
Tanito M, Ohira A, Chihara E. Factors leading to reduced intraocular pressure after combined trabeculotomy and cataract surgery. J Glaucoma. 2002;11(1):3-9. [pmid: 11821682]. \It is a case series
Tanito M, Ohira A, Chihara E. Surgical outcome of combined trabeculotomy and cataract surgery. J Glaucoma. 2001;10(4):302-8. [pmid: 11558815]. It is a case series
Tanito M, Park M, Nishikawa M, Ohira A, Chihara E. Comparison of surgical outcomes of combined viscocanalostomy and cataract surgery with combined trabeculotomy and cataract surgery. Am J Ophthalmol. 2002;134(4):513-20. [pmid: 12383807]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Tanna AP, Rademaker AW, Stewart WC, Feldman RM. Meta-analysis of the efficacy and safety of alpha2-adrenergic agonists, beta-adrenergic antagonists, and topical carbonic anhydrase inhibitors with prostaglandin analogs. Systematic review
Tapaszto I, Boross F. Investigations of the efficacy and bio-availability of different pilocarpine eye drops. Graefes Arch Clin Exp Ophthalmol. 82;218(6):315-8. Does not address any key questions
Tarkkanen A, Karjalainen K. Cataract formation during miotic treatment for chronic open-angle glaucoma. Acta Ophthalmol (Copenh). 66;44(6):932-9. Does not address any key questions
Tattersall C, Vernon S, Singh R. Resting pulse rates in a glaucoma clinic: the effect of topical and systemic beta-blocker usage. Unique comparators
Taumer R, Gross G. Report on the application of chibro-timoptol after one year’s use in ophthalmological practice (author’s transl). Klin Monbl Augenheilkd. 80;177(3):384-9. It is a case series
Taverniti L, Di Staso S, Arrico L, Giuffre I, Recupero SM. Effect of brimonidine on patients undergoing uncontrolled IOP with beta-blockers. Acta Ophthalmol Scand Suppl. 2002;236:54. [pmid: 12390143]. It is not a RCT and has less than 100 patients
Taverniti L, Voccia L, Amoroso L, De Stefano C, Virno M. Ocular tension and pupil diameter effects of timolol 0.50% and pilocarpine 2% or 4% in association. Acta Ophthalmol Scand Suppl. 97(224):55-6. Does not address any key questions
Teekhasaenee C, Ritch R. The use of PhEA 34c in trabeculectomy. Ophthalmology. 86;93(4):487-91. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Tesha PE, Rehman SU, Amoaku WMK, Doran RML, Menage MJ, Morrell AJ. Investigation into the use of beta radiation as an adjunct to trabeculectomy in open angle glaucoma. Meeting abstract
Teus Guezala MA, Arranz Marquez E, Morales Bertrand J, Marcos De La Huerga A. Ocular hypotensive effect of pilocarpine in latanoprost treated eyes; a pilot study. Foreign language
Teus MA, Miglior S, Laganovska G, Volksone L, Romanowska-Dixon B, Gos R, Hollo G. Efficacy and safety of travoprost/timolol vs dorzolamide/timolol in patients with open-angle glaucoma or ocular hypertension. Clin Ophthalmol. 2009;3:629-36. [pmid: 19997566]. Other (specify):not FDA approved
Tezel G, Kolker AE, Kass MA, Wax MB. Comparative results of combined procedures for glaucoma and cataract: I. Extracapsular cataract extraction versus phacoemulsification and foldable versus rigid intraocular lenses. Ophthalmic Surg Lasers. 97;28(7):539-50. It is combined cataract/glaucoma surgery study published before April 2000
Tezel G, Kolker AE, Kass MA, Wax MB. Comparative results of combined procedures for glaucoma and cataract: II. Limbus-based versus fornix-based conjunctival flaps. Ophthalmic Surg Lasers. 97;28(7):551-7. It is combined cataract/glaucoma surgery study published before April 2000
Tham CC, Lai JS, Poon AS, Lai TY, Lam DS. Results of trabeculectomy with adjunctive intraoperative mitomycin C in Chinese patients with glaucoma. Ophthalmic Surg Lasers Imaging. 2006;37(1):33-41. [pmid: 16468549]. It is not a RCT and has less than 100 patients
Tham CC, Leung DY, Yick DW, Lam DS. Changes in the RNFL. Ophthalmology. 2005;112(7):1319-20. author reply 1320–1. [pmid: 15993244]. No original data (e.g., systematic review, narrative review, editorial, letter)
The Advanced Glaucoma Intervention Study (AGIS): 11. Risk factors for failure of trabeculectomy and argon laser trabeculoplasty. Am J Ophthalmol. 2002;134(4):481-98. [pmid: 12383805]. Other (specify):link with other AGIS articles Other (specify):AGIS
The Advanced Glaucoma Intervention Study (AGIS): 12. Baseline risk factors for sustained loss of visual field and visual acuity in patients with advanced glaucoma. Am J Ophthalmol. 2002;134(4):499-512. [pmid: 12383806]. Other (specify):linkTo other AGIS articles Other (specify):AGIS
The Advanced Glaucoma Intervention Study (AGIS): 4. Comparison ofTreatment outcomes within race. Seven-year results. Ophthalmology. 98;105(7):1146-64. Other (specify):AGIS
The Advanced Glaucoma Intervention Study (AGIS): 7. The relationship between control of intraocular pressure and visual field deterioration. The AGIS Investigators. Am J Ophthalmol. 2000;130(4):429-40. [pmid: 11024415]. Other (specify):AGIS
The Advanced Glaucoma Intervention Study (AGIS): 9. Comparison of glaucoma outcomes in black and white patients withinTreatment groups. Am J Ophthalmol. 2001;132(3):311-20. [pmid: 11530042]. Other (specify): Other (specify):AGIS
The Advanced Glaucoma Intervention Study: 8. Risk of cataract formation afterTrabeculectomy. Arch Ophthalmol. 2001;119(12):1771-9. [pmid: 11735786]. Other (specify): Other (specify):AGIS
The effectiveness of intraocular pressure reduction in the treatment of normal-tension glaucoma. Collaborative Normal-Tension Glaucoma Study Group. Maier 2005 and Burr 2004 Maier 2005 and Burr 2004
The European glaucoma prevention study (EGPS). Aims and methods. Acta Ophthalmol. Scand. Suppl. 99;77(229):12. No original data (e.g., systematic review, narrative review, editorial, letter). Other (specify): link to EGPS, No original data (e.g., systematic review, narrative review, editorial, letter)
The European glaucoma prevention study (EGPS). Aims and methods. Acta Ophthalmol. Scand. Suppl. 99;77(229):12. Other (specify): Rolim de Moura 2009
The Levobunolol Study Group. Levobunolol. A beta-adrenoceptor antagonist effective in the long-term treatment of glaucoma. The Levobunolol Study Group. Duplicate
The ocular effects of prostaglandins and other eicosanoids. Foreign language
Theeuwes F, Bayne W, McGuire J. Gastrointestinal therapeutic system for acetazolamide. Efficacy and side effects. Medical KQ 3 or KQ 3 and KQ 6 only
Thelen U, Buchholz P, Kimmich F. Treatment of patients with primary open-angle glaucoma with a fixed combination of brimonidine 0.2%/timolol 0.5%: multicenter, open-label, observational study in Germany. Curr Med Res Opin. 2009;25(4):1003-9. [pmid: 19275517]. Other (specify):Study design does not match KQ (KQ3)
Thelen U, Weiler W, Kirchhoff E, Fuchs HB, Stewart WC. Clinical experience in the treatment of normal tension glaucoma with latanoprost in Germany. J Ocul Pharmacol Ther. 2007;23(3):311-3. [pmid: 17593016]. It is a case series
Thomas R, Jacob P, Braganza A, Mermoud A, Muliyil J. Releasable suture technique for trabeculectomy. Indian J Ophthalmol. 97; 45(1):37-41. It is a case series
Thomas R, Parikh R, Muliyil J. Comparison between phacoemulsification and the Blumenthal technique of manual small-incision cataract surgery combined with trabeculectomy. J Glaucoma. 2003;12(4):333-9. [pmid: 12897578]. OAG can’t be analyzed separately
Thomas R, Parikh R, Muliyil J, George R, Paul P, Abraham LM. Comparison between latanoprost and brimonidine efficacy and safety in Indian eyes. Indian J Ophthalmol. 2003;51(2):123-8. [pmid: 12831141]. It is not a RCT and has less than 100 patients
Thomas R, Parikh R, Sood D, Vijaya L, Sekhar GC, Sood NN, Baskaran M, Prasad KK. Efficacy and safety of latanoprost for glaucoma treatment: a three-month multicentric study in India. Indian J Ophthalmol. 2005;53(1):23-30. [pmid: 15829743]. Does not address any key questions
Thorburn W. Comparison of timolol and pilocarpine combination versus concomitant therapy with separate components: A swedish multicenter study. Excluded drug
Thorne JE, Maguire AM, Lanciano R. CME and anterior uveitis with latanoprost use. Ophthalmology. 98;105(11):1981-3. It is a case series
Thyer HW, Wilson P. Trabeculectomy. Br J Ophthalmol. 72; 56(1):37-40. It is not a RCT and has less than 100 patients
Thyer HW. Timolol: corneal anaesthesia. Med J Aust. 80;1(1):34. No original data (e.g., systematic review, narrative review, editorial, letter)
Thygesen J. Betaxolol. A new beta blockader with beta-1-selectivity in glaucoma treatment. Foreign language
Ticho U, Nesher R. Laser trabeculoplasty in glaucoma. Ten-year evaluation. Arch Ophthalmol. 89;107(6):844-6. It is a case series
Ticho U, Ophir A. Late complications after glaucoma filtering surgery with adjunctive 5-fluorouracil. Am J Ophthalmol. 93;115(4):506-10. Data not abstractable
Ticho U, Blumenthal M, Zonis S, Gal A, Blank I, Mazor ZW. A clinical trial with Piloplex--a new long-acting pilocarpine compound: preliminary report. Ann Ophthalmol. 79;11(4):555-61. It is not a RCT and has less than 100 patients
Tingey D, Bernard LM, Grima DT, Miller B, Lam A. Intraocular pressure control and persistence on treatment in glaucoma and ocular hypertension. Can J Ophthalmol. 2005;40(2):161-9. [pmid: 16049529]. Other (specify):Study design does not match KQ
Titouamane S, Baudouin C. Use of brimonidine 0.2% in treatment of glaucoma or ocular hypertony after poorly tolerated beta-blocker treatment. Foreign language
Titouamane S, Baudouin C. Use of brimonidine 0.2% in treatment of glaucoma or ocular hypertony after poorly tolerated (beta)-blocker treatment. Interet de la brimonidine 0,2% dans le traitement du glaucome ou de l’hypertension intraoculaire apres intolerance a un traitement par (beta)-bloquant. Duplicate
Tomisaka S, Nakanishi T, Hashimoto A. Medical therapy of glaucoma with topical bupranolol hydrochloride. FOLIA OPHTHALMOL. JPN. 79;30(8):1167-1172. It is not a RCT and has less than 100 patients
Tomita G, Araie M, Kitazawa Y, Tsukahara S. A three-year prospective, randomized and open comparison between latanoprost and timolol in Japanese normal-tension glaucoma patients. Medical KQ 3 or KQ 3 and KQ 6 only
Tomono M, Nanba K. Long-term clinical trials of Pilocarpine Ocusert. (Second report). A further follow up study. FOLIA OPHTHALMOL. JPN. 81;32(10):2095-2099. It is not a RCT and has less than 100 patients
Toor A, Chanis RA, Polikoff LA, Fahim MM, Sinha AP, Serle JB. Additivity of pilocarpine to bimatoprost in ocular hypertension and early glaucoma. Non-FDA-approved drug combination
Toor A, Fahim MM, Polikoff LA, Chanis RA, Sinha AP, Serle JB. The Additivity of Pilocarpine to Bimatoprost in Early Glaucoma and Ocular Hypertension. Meeting abstract
Topical timolol and serum lipoproteins. Arch Ophthalmol. 91;109(10):1341-2. No original data (e.g., systematic review, narrative review, editorial, letter)
Topouzis F, Melamed S, Danesh-Meyer H, Wells AP, Kozobolis V, Wieland H, Andrew R, Wells D. A 1-year study to compare the efficacy and safety of once-daily travoprost 0.004%/timolol 0.5% to once-daily latanoprost 0.005%/timolol 0.5% in patients with open-angle glaucoma or ocular hypertension. Eur J Ophthalmol. 2007;(2):183-90. [pmid: 17415690]. Other (specify):not FDA approved combination
Topouzis F, Yu F, Coleman AL. Factors associated with elevated rates of adverse outcomes after cyclodestructive procedures versus drainage device procedures. Ophthalmology. 98;105(12):2276-81. OAG can’t be analyzed separately
Toris CB, Camras CB, Yablonski ME. Acute versus chronic effects of brimonidine on aqueous humor dynamics in ocular hypertensive patients. Am J Ophthalmol. 99;128(1):8-14. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Toris CB, Gleason ML, Camras CB, Yablonski ME. Effects of brimonidine on aqueous humor dynamics in human eyes. Arch Ophthalmol. 95;113(12):1514-7. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Toris CB, Zhan GL, Zhao J, Camras CB, Yablonski ME. Potential mechanism for the additivity of pilocarpine and latanoprost. Am J Ophthalmol. 2001;131(6):722-8. [pmid: 11384567]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Toris CB, Zhan G, Fan S, Dickerson JE, Landry TA, Bergamini MV, Camras CB. Effects of travoprost on aqueous humor dynamics in patients with elevated intraocular pressure. J Glaucoma. 2007;(2):189-95. [pmid: 17473728]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Tornqvist G, Drolsum LK. Trabeculectomies. A long-term study. Acta Ophthalmol (Copenh). 91;69(4):450-4. It is a case series
Torres-Suarez E, Rebolleda G, Munoz Negrete FJ, Cabarga C, Rivas L. Influence of deep scleral flap size on intraocular pressure after deep sclerectomy. Eur J Ophthalmol. 2007;(3):350-6. [pmid: 17534815]. Does not address any key questions
Tost M, Rasch V. Results of air impulse esthesiometry after administration of oftan-timolol. Fortschr Ophthalmol. 88;85(2):130-1. Does not address any key questions
Tost M, Herde J, Fincke S, Nook O. Tolerance and tachyphylaxis during the long-term local treatment of different forms of glaucoma with Arutimol. Foreign language
Tous HM, Nevarez J. Comparison between the outcomes of combined phaco/trabeculectomy by cataract incision site. P R Health Sci J. 2007;26(1):29-33. [pmid: 17674871]. OAG can’t be analyzed separately
Tran DH, Souza C, Ang MJ, Loman J, Law SK, Coleman AL, Caprioli J. Comparison of long-term surgical success of Ahmed Valve implant versus trabeculectomy in open-angle glaucoma. Br J Ophthalmol. 2009;93(11):1504-9. [pmid: 19574238]. Does not address any key questions
Traverso CE, Ropo A, Papadia M, Uusitalo H. A phase II study on the duration and stability of the intraocular pressure-lowering effect and tolerability of Tafluprost compared with latanoprost. Journal of ocular pharmacology and therapeutics: the official journal of the Association for Ocular Pharmacology and Therapeutics. 2010;26(1):97-104. [pmid: 20148656]. OAG can’t be analyzed separately
Traverso CE, Greenidge KC, Spaeth GL. Formation of peripheral anterior synechiae following argon laser trabeculoplasty. A prospective study to determine relationship to position of laser burns. Archives of ophthalmology. 84;102(6):861-3. Does not address any key questions
Traverso CE, Ropo A, Papadia M, Uusitalo H. A phase II study on the duration and stability of the intraocular pressure-lowering effect and tolerability of Tafluprost compared with latanoprost. J Ocul Pharmacol Ther. 2010;26(1):97-104. [pmid: 20148656]. Data not abstractable
Traverso CE, Tomey KF, Antonios S. Limbal- vs fornix-based conjunctival trabeculectomy flaps. Am J Ophthalmol. 87; 104(1):28-32. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Traverso CE, Walt JG, Stern LS, Dolgitser M. Pharmacotherapy compliance in patients with ocular hypertension or primary open-angle glaucoma. J Ocul Pharmacol Ther. 2009;25(1):77-82. [pmid: 19232009]. Does not address any key questions
Tredici TJ, Epstein DL. Ocular complications of drug therapy. Aerosp Med. 72;43(8):898-902. No original data (e.g., systematic review, narrative review, editorial, letter)
Trepsat C, Roussille M, Genoulaz L. Timolol maleate, a new beta-blocker in the treatment of chronic simple glaucoma. Foreign language
Treseder AS, Thomas TP. Sinus arrest due to timolol eye drops. Br J Clin Pract. 86;40(6):256-8. Other (specify):case report of harm
Tressler CS. Bimatoprost versus timolol and dorzolamide. Ophthalmology. 2005;112(2):357-8. author reply 358–9. [pmid: 15691575]. No original data (e.g., systematic review, narrative review, editorial, letter)
Tressler CS, Cyrlin MN, Fazio R. MITOMYCIN C IN GLAUCOMA FILTERING SURGERY A COMPARISON OF SUBCONJUNCTIVAL TO INTRASCLERAL ADMINISTRATION. Meeting abstract
Tressler CS, Susanna R Jr. Latin American Latanoprost Study Group. Latanoprost and Fixed Combination Dorzolamide + Timolol in Patients With Elevated Intraocular Pressure. An 8-week, Open-label, Multicenter Study in Latin America. Meeting abstract
Trinquand C, Romanet JP, Nordmann JP, Allaire C. Groupe d’étude. Efficacy and safety of long-acting carteolol 1% once daily. A double-masked, randomized study. Duplicate
Trinquand C, Romanet J-P, Nordmann J-P, Allaire C. Efficacy and safety of long-acting carteolol 1% once daily. A double-masked, randomized study. Efficacite et tolerance du carteolol 1% a liberation prolongee une fois par jour: Etude randomisee en double insu. Foreign language
Trocme S, Hwang LJ, Bean GW, Sultan MB. The role of benzalkonium chloride in the occurrence of punctate keratitis: a meta-analysis of randomized, controlled clinical trials. Systematic review
Troiano P, Cavallotti B, Iraci M, Galli L, Miglior M. Pressure-reducing efficacy and tolerability of betaxolol in ionic solution. Medical KQ 3 or KQ 3 and KQ 6 only
Troiano P, Oldani A, Gozzini C, Iraci M, Dalpozzo R, Baratta M, De Mattia M. Latanoprost 0.005%: evaluation of its effect on accommodative capacity. Acta Ophthalmol Scand Suppl. 2000;(232):52. [pmid: 11235537]. No subjects with open-angle glaucoma
Troutbeck R, Lee GA, Sanfilippo P, Fleming B. Trabeculectomy: a training dilemma. Eye (Lond). 2007;21(2):183-6. [pmid: 16327797]. Animal or in vitro data
Tsai JC. A comprehensive perspective on patient adherence to topical glaucoma therapy. Systematic review
Tsai JC, Johnson CC, Dietrich MS. The Ahmed shunt versus the Baerveldt shunt for refractory glaucoma: a single-surgeon comparison of outcome. Ophthalmology. 2003;110(9):1814-21. [pmid: 13129882]. OAG can’t be analyzed separately
Tsai JC, Johnson CC, Kammer JA, Dietrich MS. The Ahmed shunt versus the Baerveldt shunt for refractory glaucoma II: longer-term outcomes from a single surgeon. Ophthalmology. 2006;113(6):913-7. [pmid: 16751034]. Other (specify):Study design does not match KQ
Tsironi S, Konstas AGP, Pikilidou MI, Mikropoulos D, Kozobolis VP, Lasarides AN, Stewart WC. 24-Hour Intraocular Pressure and Blood Pressure Control With Latanoprost/Timolol Maleate Fixed Combination QPM and Timolol Maleate BID in Primary Open Angle Glaucoma Patients. Meeting abstract
Tsukamoto H, Mishima HK, Kitazawa Y, Araie M, Abe H, Negi A. A comparative clinical study of latanoprost and isopropyl unoprostone in Japanese patients with primary open-angle glaucoma and ocular hypertension. J Glaucoma. 2002;11(6):497-501. [pmid: 12483094]. Other (specify):unoprostone
Tsukamoto H, Noma H, Mishima HK. Correlation between the additive effect of bunazosin and the response to latanoprost on intraocular pressure in patients with glaucoma treated with bunazosin as adjunctive therapy to latanoprost. Jpn J Ophthalmol. 2006;50(1):65-7. [pmid: 16453191]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Tsukamoto H, Noma H, Matsuyama S, Ikeda H, Mishima HK. The efficacy and safety of topical brinzolamide and dorzolamide when added to the combination therapy of latanoprost and a beta-blocker in patients with glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Tsukamoto H, Noma H, Mukai S, Ikeda H, Mishima HK. The efficacy and ocular discomfort of substituting brinzolamide for dorzolamide in combination therapy with latanoprost, timolol, and dorzolamide. Medical KQ 3 or KQ 3 and KQ 6 only
Tsukamoto H, Yokoyama T, Okada K, Okada M, Mochizuki H, Mishima HK. Substituting latanoprost (Xalatan(TM)) for isopropyl unoprostone (Rescula(TM)) in monotherapy and combination therapy [1]. Acta Ophthalmol Scand. 2000;78(5):604-605. [pmid: 11037926]. Does not address any key questions
Tsuru T, Kitazawa Y, Usui M, Ueno S, Azuma I, Masuda K. The additive effects on intraocular pressure of combining nipradilol 0.25% and latanoprost 0.005% ophthalmic solutions: a prospective, randomized, multicenter study. Jpn J Ophthalmol. 2008;52(5):368-73. [pmid: 18991037]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Tsyganko TA. Immediate and late results of trabeculectomy in glaucoma. Foreign language
Tugushi OA, Shliapuzhnikova AV, Listopadova NA. Comparative analysis of life quality in patients receiving beta-blockers and xalathane (latanoprost). Foreign language
Tuli SS, WuDunn D, Ciulla TA, Cantor LB. Delayed suprachoroidal hemorrhage after glaucoma filtration procedures. Ophthalmology. 2001;108(10):1808-11. [pmid: 11581053]. Data not abstractable
Tumbocon JA, Latina MA, Frenkel REP, Gosengfiao D. THE EFFECTS OF TOPICAL DORZOLAMIDE AND BRIMONIDINE ON RETINAL CAPILLARY. BLOOD FLOW: A CROSSOVER STUDY IN PATIENTS WITH OPEN-ANGLE GLAUCOMA. Meeting abstract
Tuovinen E. Treatment of chronic glaucoma. Foreign language
Turacli E, Budak K, Kaur A, Mizrak B, Ekinci C. The effects of long-term topical glaucoma medication on conjunctival impression cytology. Int Ophthalmol. 97;21(1):27-33. OAG can’t be analyzed separately
Turacli E, Gunduz K, Aktan G, Tamer C. A comparative clinical trial of mitomycin C and cyclosporin A in trabeculectomy. Eur J Ophthalmol. 96;6(4):398-401. No subjects with open-angle glaucoma
Turacli ME, Gunduz K, Aktan G, Sencer H. Topical cyclosporine as a possible new antimetabolite in trabeculectomy. Ophthalmic Surg Lasers. 96;27(6):438-44. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Turacli ME, Gunduz K, Aktan G, Sencer H. Trabeculectomy with mitomycin C: an electron microscopic and clinical study. Int Ophthalmol. (6):95-96. 337. 46. Data not abstractable
Turgut B, Turkcuoglu P, Guler M, Akyol N, Celiker U, Demir T. Anosmia as an adverse effect of dorzolamid. Acta Ophthalmol Scand. 2007;85(2):228-9. [pmid: 17305746]. It is a case series
Tuulonen A. Economic considerations of the diagnosis and management for glaucoma in the developed world. Systematic review
Tuulonen A. Is more always better. Acta Ophthalmol Scand. 2004;82(4):377-9. [pmid: 15291927]. No original data (e.g., systematic review, narrative review, editorial, letter)
Tuulonen A. The effect of topical indomethacin on acute pressure elevation of laser trabeculoplasty in capsular glaucoma. Acta ophthalmologica. 85;63(2):245-9. Does not address any key questions
Tuulonen A, Niva AK, Alanko HI. A controlled five-year follow-up study of laser trabeculoplasty as primary therapy for open-angle glaucoma. Am J Ophthalmol. 87;104(4):334-8. It is not a RCT and has less than 100 patients
Twer A, Anand R, Kooner KS. LOW DOSE VS HIGH DOSE MITOMYCIN-C WITH GLAUCOMA FILTRATION SURGERY IN PATIENTS WITH PRIMARY OPEN ANGLE GLAUCOMA. Meeting abstract
Two new beta-blockers for glaucoma. Med Lett Drugs Ther. 86; 28(712):45-6. No original data (e.g., systematic review, narrative review, editorial, letter)
Uchida S, Suzuki Y, Araie M, Shigeeda T, Hara T, Shirato S. Long-term follow-up of initial 5-fluorouracil trabeculectomy in primary open-angle glaucoma in Japanese patients. J Glaucoma. 2001;10(6):458-65. [pmid: 11740215]. Other (specify):case series
Ulbig MW, McHugh DA, McNaught AI, Hamilton AM. Clinical comparison of semiconductor diode versus neodymium: YAG non-contact cyclo photocoagulation. Br J Ophthalmol. 95;79(6):569-74. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Ullman S, Fisher SJ, Lavine JB, Mandell AI, Ostrov CS. OCULAR HYPOTENSIVE EFFECT OF COMBINATION AGENT LEVOBUNOLOL 0.5%/DIPIVEFRIN 0.1%. Meeting abstract
Ung CT, Von Lany H, Claridge KG. Late bleb needling. Br J Ophthalmol. 2003;87(11):1430-1. [pmid: 14609856]. It is a case series
Urban V, Kammann MT, Sturmer JP. Glaucoma and cataract: combined operation or trabeculectomy first and cataract extraction later?. Foreign language
Uretmen O, Ates H, Guven S, Andac K. Comparison of outcomes of viscocanalostomy and phacoviscocanalostomy. Foreign language
Urner-Bloch U, Bucheli J, Eltz H, Gloor B, Aeschlimann J. Clinical trials of various glaucoma drugs acting on the adrenergic system (author's transl). Klin Monbl Augenheilkd. 80; 176(4):555-7. It is not a RCT and has less than 100 patients
Urtti A, Rouhiainen H, Kaila T, Saano V. Controlled ocular timolol delivery: Systemic absorption and intraocular pressure effects in humans. PHARM. RES. 94; 11(9):1278-1282. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Uusitalo H, Chen E, Pfeiffer N, Brignole-Baudouin F, Kaarniranta K, Leino M, Puska P, Palmgren E, Hamacher T, Hofmann G, Petzold G, Richter U, Riedel T, Winter M, Ropo A. Switching from a preserved to a preservative-free prostaglandin preparation in topical glaucoma medication. Tafluprost
Uusitalo H, Kahonen M, Ropo A, Maenpaa J, Bjarnhall G, Hedenstrom H, Turjanmaa V. Improved systemic safety and risk-benefit ratio of topical 0.1% timolol hydrogel compared with 0.5% timolol aqueous solution in the treatment of glaucoma. Graefes Arch Clin Exp Ophthalmol. 2006;244(11):1491-6. [pmid: 16628416]. Other (specify):T-gel not FDA approved
Uusitalo H, Pillunat LE, Ropo A. Efficacy and safety of tafluprost 0.0015% versus latanoprost 0.005% eye drops in open-angle glaucoma and ocular hypertension: 24-month results of a randomized, double-masked phase III study. Acta Ophthalmol. 2010;88(1):12-9. [pmid: 20420586]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Uusitalo RJ, Palkama A. Efficacy and safety of timolol/pilocarpine combination drops in glaucoma patients. Acta Ophthalmol (Copenh). 94; 72(4):496-504. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Uusitalo RJ, Palkama A. Long-term evaluation of timolol. Acta Ophthalmol (Copenh). 89; 67(5):573-81. Data not abstractable
Uusitalo RJ, Palkama A, Stjernschantz J. A study of the efficacy of two commercial preparations of timolol maleate with special reference to side effects. Medical KQ 3 or KQ 3 and KQ 6 only
Uva MG, Longo A, Reibaldi M. Pneumatic trabeculoplasty versus argon laser trabeculoplasty in primary open-angle glaucoma. Ophthalmologica. Journal international d'ophtalmologie. International journal of ophthalmology. Zeitschrift für Augenheilkunde. 2010;224(1):10-5. [pmid: 19684423]. Other (specify):Not a comparison we are interested in (pneumatic trabeculoplasty)
Uva MG, Avitabile T, Panta G, Cro M, Giuffrida S, Reibaidi A. A NEW ANTI-GLAUCOMA MUCOADHESIVE ASSOCIATION: 0.5% TIMOLOL - 2% PILOCARPINE IN SODIUM HYALURONATE VEHICLE AND ITS IOP LOWERING EFFECTS. Meeting abstract
Uva MG, Avitabile T, Panta G, Russo V, Reibaldi A. INTRAOPERATIVE 5-FU PLUS TITRATED TRABECULECTOMY: OUR PRELIMINARY RESULTS. Meeting abstract
Uva MG, Longo A, Reibaldi M. Pneumatic trabeculoplasty versus argon laser trabeculoplasty in primary open-angle glaucoma. Ophthalmologica. 2010;224(1):10-5. [pmid: 19684423]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Uva MG, Longo A, Reibaldi M. Pneumatic trabeculoplasty vs latanoprost as adjunctive therapy to timolol in primary open-angle glaucoma or ocular hypertension. Graefes Arch Clin Exp Ophthalmol. 2009;247(8):1103-9. [pmid: 19247684]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Uva MG, Russo V, Longo A, Ott JP, Reibaldi A. 2% dorzolamide and cornea: an ultrabiomicroscopic study. Acta Ophthalmol Scand Suppl. 97(224):23-4. It is not a RCT and has less than 100 patients
Uva M, Avitabile T, Russo V, Ott J, D'Agata V, Reibaldi A. IS YAG LASER IRIDOTOMY USEFUL IN CASE OF PIGMENTARY GLAUCOMA?. Meeting abstract
Vahidassr MD, Foy CJ, O'Malley T, Passmore AP. Eye drops and lethargy. J R Soc Med. 97; 90(3):155. It is a case series
Vaidergorn Paulo Gelman, Susanna J·nior Remo, Borges Adriana Silva, Giampani J·nior Jair. Tempo de terapWutica propiciado por frasco de colÆrios hipotensores oculares. Foreign language
Vaidergorn Paulo Gelman, Susanna Remo Jr, Oliveira Cleriston Lucena de, Sakata Lisandro, Zacharias Leandro Cabral, Barreto Jackson Jr. Prova de sobrecarga hÆdrica em pacientes submetidos a trabeculoplastia. Foreign language
Vainio-Jylha E, Vuori ML, Nummelin K. Progression of retinal nerve fibre layer damage in betaxolol- and timolol-treated glaucoma patients. Acta Ophthalmol Scand. 2002;80(5):495-500. [pmid: 12390160]. No subjects with open-angle glaucoma
Vajaranant TS, Price MO, Price FW, Gao W, Wilensky JT, Edward DP. Visual acuity and intraocular pressure after Descemet's stripping endothelial keratoplasty in eyes with and without preexisting glaucoma. Systematic review
Vajaranant TS, Price MO, Price FW, Gao W, Wilensky JT, Edward DP. Visual acuity and intraocular pressure after Descemet's stripping endothelial keratoplasty in eyes with and without preexisting glaucoma. Ophthalmology. 2009;116(9):1644-50. [pmid: 19643499]. Does not address any key questions (see below for questions), It is a case series
Valimaki J, Airaksinen PJ, Tuulonen A, Risteli J. Postoperative systemic corticosteroid treatment and Molteno implant surgery: a randomized clinical trial. Acta Ophthalmol Scand. 99; 77(1):50-6. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Val'kova IV, Petukhova MS. A modified glaucoma operation with incisions. Foreign language
Valle MJ, MartÆnez A, MarÆa R. Eficacia de la mitomicina C vs 5 fluoracilo en trabeculectomÆa de pacientes con diagn£stico de glaucoma primario de bngulo abierto atendidos en el Centro Nacional de OftalmologÆa de noviembre del 2001-noviembre del 2002 Welsh unable to locate PDF.
Valle O, Klemetti A, Takki KK. Timolol maleate in the treatment of chronic open-angle glaucoma. Foreign language
Valnickova J. Results of long-term treatment of glaucoma with timolol. Foreign language
Van Beek LM, De Keizer RJW, Polak BGP, Elzenaar PR, Van Haeringen NJ, Kijlstra A. Incidence of ocular side effects of topical (beta) blockers in the Netherlands. Br J Ophthalmol. 2000;84(8):856-859. [pmid: 10906091]. It is a case series
van Beuningen E. The importance of stabilised drug therapy of glaucoma (glaucoma simplex). Foreign language
Van Buskirk EM. Adverse reactions from timolol administration. Ophthalmology. 80; 87(5):447-50. OAG can’t be analyzed separately
Van Buskirk EM, Fraunfelder FT. Ocular beta-blockers and systemic effects. Am J Ophthalmol. 84; 98(5):623-4. No original data (e.g., systematic review, narrative review, editorial, letter)
Van Buskirk EM. The laser step in early glaucoma therapy. Am J Ophthalmol. 91; 112(1):87-90. No original data (e.g., systematic review, narrative review, editorial, letter)
van der Valk R, Webers CA, Hendrikse F, de Vogel SC, Prins MH, Schouten JS. Predicting intraocular pressure change before initiating therapy: timolol versus latanoprost. Acta Ophthalmol. 2008;86(4):415-8. [pmid: 18028236]. Other (specify):Study design does not match KQ
van der Valk R, Webers CA, Lumley T, Hendrikse F, Prins MH, Schouten JS. A network meta-analysis combined direct and indirect comparisons between glaucoma drugs to rank effectiveness in lowering intraocular pressure. Systematic review
van Gestel A, Webers CA, Beckers HJ, van Dongen MC, Severens JL, Hendrikse F, Schouten JS. The relationship between visual field loss in glaucoma and health-related quality-of-life. Eye (Lond). 2010;24:1759-69. [pmid: 21057519]. It is a case series
Van Oye R, De Sutter E, De Bie S. The effect of timolol maleate on the fellow eye. Bull Soc Belge Ophtalmol. 80; 191:69-74. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
VanDenBurgh AM, Laibovitz RA, Felix C. A NOVEL OCULAR HYPOTENSIVE LIPID: INITIAL SAFETY AND EFFICACY OF AGN192024. Meeting abstract
VanDenburgh AM, Laibovitz RA, Felix C. A ONE-MONTH DOSE-RESPONSE STUDY OF AGN192024, A NOVEL ANTIGLAUCOMA AGENT, IN PATIENTS WITH ELEVATED INTRAOCULAR PRESSURE. Meeting abstract
Varga M, Follmann P. Ultrastructural studies of the conjunctival surface following long-term treatment with timolol. Foreign language
Varma R, Hwang LJ, Grunden JW, Bean GW. Using diurnal intraocular pressure fluctuation to assess the efficacy of fixed-combination latanoprost/timolol versus latanoprost or timolol monotherapy. The British journal of ophthalmology. 2010;94(1):80-4. [pmid: 19692375]. It is not a RCT and has less than 100 patients
Varma R, Hwang LJ, Grunden JW, Bean GW. Using diurnal intraocular pressure fluctuation to assess the efficacy of fixed-combination latanoprost/timolol versus latanoprost or timolol monotherapy. Br J Ophthalmol. 2010;94(1):80-4. [pmid: 19692375]. Other (specify):not FDA approved
Varma R, Hwang LJ, Grunden JW, Bean GW, Sultan MB. Assessing the efficacy of latanoprost vs timolol using an alternate efficacy parameter: the intervisit intraocular pressure range. Systematic review
Varma R, Hwang LJ, Grunden JW, Bean GW, Sultan MB. Assessing the efficacy of latanoprost vs timolol using an alternate efficacy parameter: the intervisit intraocular pressure range. Am J Ophthalmol. 2009;148(2):221-6. [pmid: 19427617]. No original data (e.g., systematic review, narrative review, editorial, letter)
Vasinca ID, Furtuna A, Vasinca D, Cociu M. Laser trabeculoplasty--3 years of experience. Foreign language
Vass C, Menapace R, Strenn K, Rainer G. Episcleral versus combined episcleral and intrascleral application of mitomycin-C in trabeculectomy. Ophthalmic Surg Lasers. 98; 29(9):714-21. It is not a RCT and has less than 100 patients
Velloso Luiz. Tunelizagåo da trabeculectomia. Foreign language
Ventura Antonio Guilherme Gonsalves de Melo, Cavalcanti Hellmann Dantas Olinda, Holanda Andrqa Gifoni Siebra de, Cardoso Get lio, Trigueiro LuÆs. Tratamento de bolhas hiperfiltrantes por sutura de compressPo. Foreign language
Verin P, Vildy A, Cales R, Bapt JB. New indications for timoptol eyedrops. Foreign language
Verkens J, Hennekes R. Cyclocryocoagulation vs. trabeculectomy in primary glaucoma: a long-term intra-individual comparison of intra-ocular pressure. Bull Soc Belge Ophtalmol. 99; 273:57-63. It is not a RCT and has less than 100 patients
Verma N, Fromberg G. Combined argon laser iridoplasty and trabeculoplasty in the management of open angle glaucomas. Indian J Ophthalmol. 86; 34:221-3. Data not abstractable
Vesti E. Development of cataract after trabeculectomy. Acta Ophthalmol (Copenh). 93; 71(6):777-81. It is not a RCT and has less than 100 patients
Vetrugno M, Cardascia N, Cantatore F, Sborgia C. Comparison of the effects of bimatoprost and timolol on intraocular pressure and pulsatile ocular blood flow in patients with primary open-angle glaucoma: A prospective, open-label, randomized, two-arm, parallel-group study. Medical KQ 3 or KQ 3 and KQ 6 only
Vetrugno M, Maino A, Cantatore F, Ruggeri G, Cardia L. Acute and chronic effects of brimonidine 0.2% on intraocular pressure and pulsatile ocular blood flow in patients with primary open-angle glaucoma: an open-label, uncontrolled, prospective study. Clin Ther. 2001;23(9):1519-28. [pmid: 11589264]. It is not a RCT and has less than 100 patients
Vetrugno M, Sborgia C, Balestrazzi E, Bianchi C, Caporossi A, Nardi M, Rapisarda A, Tassinari G, Zeppa L. Efficacy and safety of bimatoprost in patients with uncontrolled glaucoma as alternative to filtration surgery. Eur J Ophthalmol. 2005;15(4):477-81. [pmid: 16001381]. It is not a RCT and has less than 100 patients
Vieira Juan Carlos, Gonzblez Vivas Deodq, Reyes Feo MarÆa Victoria. Uso intraopertaorio de Mitomicina C en cirugÆa filtrante de glaucoma. Foreign language
Vilaplana J, Zaballos P, Romaguera C. Contact dermatitis by dipivefrine. Contact Dermatitis. 2005;52(3):169-70. [pmid: 15811042]. It is a case series
Villon JC, Dubiez M, Charleux J, Etienne R. Remote tonometric results of trabeculectomy. Foreign language
Villumsen J, Alm A. PhXA34--a prostaglandin F2 alpha analogue. Effect on intraocular pressure in patients with ocular hypertension. Br J Ophthalmol. 92; 76(4):214-7. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Villumsen J, Alm A. The effect of adding prostaglandin F2 alpha-isopropylester to timolol in patients with open angle glaucoma. Arch Ophthalmol. 90; 108(8):1102-5. Does not address any key questions
Vinuesa-Silva JM, Vinuesa-Silva I, Pinazo-Duran MD, Soto-Alvarez J, Delgado-Ortega L, Diaz-Cerezo S. Development of conjunctival hyperemia with the use of a fixed combination of latanoprost/timolol: systematic review and meta-analysis of clinical trials. Systematic review
Virno M, De Gregorio F, D'Ubaldo E, Sallucci S, De Stefano C, Sedran L. Effects of adrenergics, adrenolytics, cholinergics and carbonic anhydrase inhibitors on ibopamine-induced ocular hypertension in POAG. Acta Ophthalmol Scand Suppl. 97(224):25-6. Does not address any key questions
Virno M, Missori E, Pecori Giraldi J, Pica B. Double-blind study of timolol and pilocarpine in open-angle glaucoma. CONFRONTO A DOPPIO CIECO TRA TIMOLOLO E PILOCARPINA NEL GLAUCOMA AD ANGOLO APERTO. Foreign language
Virno M, Pecori-Giraldi J, Pivetti-Pezzi P, Leonardi E. Ocular hypotonic effect of hematic acidifying agents: carbonic anhydrase inhibitors. Foreign language
Vizzeri G, Weinreb RN, Martinez de la Casa JM, Alencar LM, Bowd C, Balasubramanian M, Medeiros FA, Sample P, Zangwill LM. Clinicians agreement in establishing glaucomatous progression using the Heidelberg retina tomograph. Systematic review
Vogel A. European Glaucoma Prevention Study (EGPS). Examination of the effectiveness of dorzolamide on the reduction of intraocular pressure for prevention of glaucoma in patients with ocular hypertension. Meeting abstract
Vogel R, Clineschmidt CM, Kulaga SF, Lewis GP, Ryan JR, Tipping, et al. Comparison of the ocular tolerability of two beta-adrenergic antagonists: timolol and betaxolol. Glaucoma. 88; 10:71-5. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Vogel R. Surface toxicity of timolol. Ophthalmology. 93; 100(3):293-4. No original data (e.g., systematic review, narrative review, editorial, letter)
Vogel R, Crick RP, Mills KB, Reynolds PM, Sass W, Clineschmidt CM, Tipping R. Effect of timolol versus pilocarpine on visual field progression in patients with primary open-angle glaucoma. Ophthalmology. 92; 99(10):1505-11. Other (specify):cannot find age
Vogel R, Tipping R, Kulaga SF Jr, Clineschmidt CM. Changing therapy from timolol to betaxolol: Effect on intraocular pressure in selected patients with glaucoma. Medical KQ 3 or KQ 3 and KQ 6 only
Vogel R, Tipping R, Kulaga SF, Clineschmidt CM. Changing therapy from timolol to betaxolol. Effect on intraocular pressure in selected patients with glaucoma. Timolol-Betaxolol Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
Vold SD, Evans RM, Stewart RH, Walters T, Mallick S. A one-week comfort study of BID-dosed brinzolamide 1%/timolol 0.5% ophthalmic suspension fixed combination compared to BID-dosed dorzolamide 2%/timolol 0.5% ophthalmic solution in patients with open-angle glaucoma or ocular hypertension. J Ocul Pharmacol Ther. 2008;24(6):601-5. [pmid: 19049301]. Other (specify):involves non FDA approved drug combo
Vold SD, Krupin T, Ruderman JM, Tanaka G. LONG-TERM OUTCOMES OF INITIAL TRABECULECTOMY WITH 5-FLUOROURACIL. Meeting abstract
Vonwil AL, olt M, Flammer J, Bachofen H. Treatment of glaucoma with topical timolol: Bronchoconstrictive side effect in patients with obstructive lung disease. Duplicate of 9584
Vonwil A, Landolt M, Flammer J, Bachofen H. Bronchoconstrictive side effects of timolol eye drops in patients with obstructive lung disease. Foreign language
Vonwil A, Landolt M, Flammer J, Bachofen H. Treatment of glaucoma with topical timolol: Bronchoconstrictive side effect in patients with obstructive lung disease. BRONCHOKONSTRIKTIVE NEBENWIRKUNG VON TIMOLOL-AUGENTROPFEN BEI PATIENTEN MIT OBSTRUKTIVEN LUNGENERKRANKUNGEN. Foreign language
Voudouri A, Zafirakis P, Livir-Rallatos G, Markomichelakis N, Mitsonis I, Baltatzis S. Standard versus separate phacotrabeculectomy: a randomized study. Meeting abstract
Vuori ML, Viitanen T. "Scleral tunnel incision"-trabeculectomy with one releasable suture. Acta Ophthalmol Scand. 2001;79(3):301-4. [pmid: 11401644]. OAG can’t be analyzed separately
Vyas AV, Bacon PJ, Percival SP. Phacotrabeculectomy: comparison of results from 3.5- and 5.2-mm incisions. Ophthalmic Surg Lasers. 98; 29(3):227-33. It is combined cataract/glaucoma surgery study published before April 2000
Vyas AV, Bacon PJ, Percival SP. The benefits of phacotrabeculectomy using 10-0 polyglactin sutures. Eye (Lond). 99; 13(Pt 2):215-20. It is a case series
Vymazal M, Valkova Z, Polachova M, Dokonalova E, Dragounova H, Jezdinsky J. Clinical trial of Pilogel HS made by Alcon. Foreign language
Wade A, Banla M. Long-term tonometric results of trabeculectomy in Black Africa patients (apropos of 119 cases of chronic open-angle glaucoma surgically treated at the Ophthalmological Clinical of University Medical Center at Dakar). Foreign language
Waheed K, Laganowski H. Bilateral poliosis and granulomatous anterior uveitis associated with latanoprost use and apparent hypotrichosis on its withdrawal. Eye (Lond). 2001;15(Pt 3):347-9. [pmid: 11450742]. It is a case series
Wakili N, Seitz B, Hayler J, Handel A, Junemann A. Impact of cataract surgery on intraocular pressure after filtering operation due to primary open angle glaucoma and secondary glaucoma in pseudoexfoliation syndrome. Augeninnendruck bei kataraktoperation nach filtrierender operation wegen primarer offenwinkelglaukome und sekundaer Offenwinkeiglaukome bei pseudoexfoliationssyndrom. Klin Monatsbl Augenheilkd. 2002;219(3):132-137. [pmid: 11987040]. It is not a RCT and has less than 100 patients
Walland MJ. Diode laser cyclophotocoagulation: dose-standardized therapy in end-stage glaucoma. Aust N Z J Ophthalmol. 98; 26(2):135-9. OAG can’t be analyzed separately
Walt JG, Lee JT. A cost-effectiveness comparison of bimatoprost versus latanoprost in patients with glaucoma or ocular hypertension (Structured abstract). Survey of Ophthalmology. 2004;49(Supplement 1):S36-44. [pmid: 15016560]. No original data (e.g., systematic review, narrative review, editorial, letter)
Walters T, Shapiro A. A TWELVE WEEK COMPARISON OF THE EFFICACY, SAFETY, AND QUALITY OF LIFE EFFECTS OF BRIMONIDINE/LATANOPROST VERSUS TIMOLOL/LATANOPROST DUAL THERAPY. Meeting abstract
Walters TR. Brimonidine-PuriteTM Study Group. 12-month evaluation of Brimodine-PuriteTM compared with Alphagan® in patients with glaucoma or ocular hypertension. Meeting abstract
Walters TR, DuBiner HB, Carpenter S, Vandenburgh AM. 24-HOUR DIURNAL COMPARISON OF ONCE-DAILY DOSING WITH BIMATOPROST 0.03%, TIMOLOL-XE 0.5%, AND LATANOPROST 0.005%. Meeting abstract
Walters TR, DuBiner HB, Carpenter SP, Khan B, VanDenburgh AM. 24-Hour IOP control with once-daily bimatoprost, timolol gel-forming solution, or latanoprost: a 1-month, randomized, comparative clinical trial. Surv Ophthalmol. 2004;49(Suppl 1):S26-35. [pmid: 15016559]. Data not abstractable
Walters TR, Maloney S, Slater D, Liss C, Wilson H, Hartenbaum D. Efficacy and tolerability of 0.5% timolol maleate ophthalmic gel-forming solution QD compared with 0.5% levobunolol hydrochloride BID in patients with open-angle glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Walters TR, Shapiro AM, Chapin MJ. A COMPARISON OF THE EFFICACY, SAFETY, AND QUALITY OF LIFE OF BRIMONIDINE WITH LATANOPROST VS. LATANOPROST WITH TIMOLOL. Meeting abstract
Wand M. Combined phacoemulsification, intraocular lens implant, and trabeculectomy with intraoperative mitomycin-C: comparison between 3.2- and 6.0-mm incisions. J Glaucoma. 96; 5(5):301-7. It is combined cataract/glaucoma surgery study published before April 2000
Wandel T, Charap AD, Lewis RA, Partamian L, Cobb S, Lue JC, Novack GD, Gaster R, Smith J, Duzman E. Glaucoma treatment with once-daily levobunolol. Medical KQ 3 or KQ 3 and KQ 6 only
Wang B, Sakata LM, Friedman DS, Chan YH, He M, Lavanya R, Wong TY, Aung T. Quantitative iris parameters and association with narrow angles. Systematic review
Wang NL, Liang YB, Zhuang XM, Qiao LY, Wu ZH. The early postoperative complications and cost-effectiveness analysis of non-penetrating trabecular surgery in patients with primary open angle glaucoma. Foreign language
Wang N, Wu H, Ye T, Chen X, Zeng M, Fan Z. Analysis of intra-operative and early post-operative complications and safety in non-penetrating trabecular surgery. Foreign language
Wang RF, Gao XW, Yan XD, Dong XY, Ji XX. Clinical observation on the quadratic adjustment suture in glaucoma trabeculectomy. Foreign language
Wang TH, Huang JY, Hung PT, Shieh JW, Chen YF. Ocular hypotensive effect and safety of brinzolamide ophthalmic solution in open angle glaucoma patients. Medical KQ 3 or KQ 3 and KQ 6 only
Wang T, Zhao M, Yang X-Z. Primary study on cyanoacrylate used in trabeculectomy. Foreign language
Wang T-H, Huang J-Y, Hung PT, Shieh J-W, Chen YF. Ocular hypotensive effect and safety of brinzolamide opthalmic solution in open angle glaucoma patients. Duplicate
Wanichwecha-Rungruang B, Iemsomboon W. Efficacy and safety of bimatoprost for the treatment of open-angle glaucoma and ocular hypertension: a three-month, open-label study in community-based practices in Thailand. J Med Assoc Thai. 2005;88(9):1228-35. [pmid: 16536109]. Does not address any key questions
Wanichwecha-Rungruang B. Bimatoprost in Asian clinical practice. Asian J Ophthalmol. 2005;7(2):54-55. No original data (e.g., systematic review, narrative review, editorial, letter)
Warden NJ. Long term results of trabeculectomy. Trans Ophthalmol Soc N Z. 77; 29:89-90. It is not a RCT and has less than 100 patients
Warwar RE, Bullock JD. Latanoprost-induced uveitis. Surv Ophthalmol. 99; 43(5):466-8. No original data (e.g., systematic review, narrative review, editorial, letter)
Warwar RE, Bullock JD, Ballal D. Cystoid macular edema and anterior uveitis associated with latanoprost use. Experience and incidence in a retrospective review of 94 patients. Ophthalmology. 98; 105(2):263-8. OAG can’t be analyzed separately
Watanabe J, Iwata K, Sawaguchi S, Nanba K. Trabeculectomy with 5-fluorouracil. Acta Ophthalmol (Copenh). 91; 69(4):455-61. OAG can’t be analyzed separately
Watanabe TM, Hodes BL. Bilateral anterior uveitis associated with a brand of metipranolol. Arch Ophthalmol. 97; 115(3):421-2. It is a case series
Watillon M, Robe-Vanwijck A. Harmful effects of common drugs on the visual apparatus. Cardiovascular drugs. Foreign language
Watson P, Stjernschantz J. A six-month, randomized, double-masked study comparing latanoprost with timolol in open-angle glaucoma and ocular hypertension. The Latanoprost Study Group. Duplicate 8415
Watson PG, Stjernschantz J. Intraocular Pressure (IOP) Reducing Effect and Side-Effects of Latanoprost and Timolol. A Six-Month Double-Masked Comparison. Meeting abstract
Watson PG, Grierson I. Early trabeculectomy in the treatment of chronic open-angle glaucoma in relation to histological changes. Excluded drug
Watson PG. Latanoprost. Two years' experience of its use in the United Kingdom. Latanoprost Study Group. Medical KQ 3 or KQ 3 and KQ 6 only
Watson PG. Latanoprost: Two year's experience of its use in the United Kingdom. Medical KQ 3 or KQ 3 and KQ 6 only
Watson PG, Allen ED, Graham CM, Porter GP, Pickering MS. Argon laser trabeculoplasty or trabeculectomy a prospective randomised block study. Trans Ophthalmol Soc U K. 85; 104(Pt 1):55-61. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Watson PG, Barnett MF, Parker V, Haybittle J. A 7 year prospective comparative study of three topical beta blockers in the management of primary open angle glaucoma. Medical KQ 3 only
Watson PG, Barnett MF, Parker V, Haybittle J, Fellman R. A 7-year prospective comparative study of three topical (beta) blockers in the management of primary open angle glaucoma. Evid.-Based Eye Care. 2002;3(3):144-145. No original data (e.g., systematic review, narrative review, editorial, letter)
Watson PG, Jakeman C, Ozturk M, Barnett MF, Barnett F, Khaw KT. The complications of trabeculectomy (a 20-year follow-up). Eye (Lond). 90; 4(Pt 3):425-38. OAG can’t be analyzed separately
Watson P, Stjernschantz J, Beck L, Blackmore M, Coakes R, Reynolds P, Davey C, Hickman-Casey J, Elkington A, Luff A, Green F, Valenzuela F, Longstaff S, Currie Z, Mills B, Chatterjee A, Murray S, Nagasubramanian S, Potts M. A six-month, randomized, double-masked study comparing latanoprost with timolol in open-angle glaucoma and ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Wayman LL, Larsson LI, Maus TL, Brubaker RF. Additive effect of dorzolamide on aqueous humor flow in patients receiving long-term treatment with timolol. Arch Ophthalmol. 98; 116(11):1438-40. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Wayyes ARM, Hassan S, Rubaiy KM, Abou YZ. The effect of oral bromocriptine on the intraocular pressure of patients with open-angle glaucoma. IRCS MED. SCI. 86; 14(2):195-196. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Webers CA, Beckers HJ, Zeegers MP, Nuijts RM, Hendrikse F, Schouten JS. The intraocular pressure-lowering effect of prostaglandin analogs combined with topical beta-blocker therapy: a systematic review and meta-analysis. Systematic review
Wedrich A, Menapace R, Hirsch U, Papapanos P, Derbolav A, Ries E. Comparison of results and complications following combined ECCE-trabeculectomy versus small-incision-trabeculectomy and posterior chamber lens implantation. Int Ophthalmol. 96–97(1–3):125-9. It is combined cataract/glaucoma surgery study published before April 2000
Weekers R, Demailly P, Collignon-Brach J. Considerations on the value of pilocarpine treatment in open angle glaucoma. Foreign language
Wegner A, Ugi IA, Wertheimer RE. Changes of the visual field in short-term application of dorzolamide in patients with open angel glaucoma and a comparison with timolol. Meeting abstract
Weinreb RN, Caldwell DR, Goode SM, Horwitz BL, Laibovitz R, Shrader CE, Stewart RH, Williams AT. A double-masked three-month comparison between 0.25% betaxolol suspension and 0.5% betaxolol ophthalmic solution. Medical KQ 3 or KQ 3 and KQ 6 only
Weinreb RN, Ruderman J, Juster R, Wilensky JT. Influence of the number of laser burns administered on the early results of argon laser trabeculoplasty. American journal of ophthalmology. 83; 95(3):287-92. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Weinreb RN, Ruderman J, Juster R, Zweig K. Immediate intraocular pressure response to argon laser trabeculoplasty. American journal of ophthalmology. 83; 95(3):279-86. Does not address any key questions
Weinreb RN, van Buskirk EM, Cherniack R, Drake MM. Long-term betaxolol therapy in glaucoma patients with pulmonary disease. Am J Ophthalmol. 88; 106(2):162-7. OAG can’t be analyzed separately
Weisbrod L, Motolko MA. A Long-Term Comparative Study between Phacoemulsification Trabeculectomy and ECCE Trabeculectomy. Meeting abstract
Weiss H. HEMODYNAMIC AND INTRAOCULAR PRESSURE EFFECTS OF TIMOLOL AND CARTEOLOL IN PATIENTS WITH OCULAR HYPERTENSION AND PRIMARY OPEN ANGLE GLAUCOMA. Meeting abstract
Weller R, George R, Enzenauer R, Cornell F. THE EFFECT ON INTRAOCULAR PRESSURE (IOP) AFTER SUBSTITUTION OF LEVOBUNOLOL FOR TIMOLOL IN PATIENTS CONTROLLED ON TIMOLOL OR TIMOLOL AND DIPIVERIN. Meeting abstract
Wells AP, Poostchi A. Prostaglandin Analogues Increase Corneal Hysteresis Measurements, but Not Independently of Intraocular Pressure. Meeting abstract
Welsh NH. Trabeculectomy with fistula formation in the African. Br J Ophthalmol. 72; 56(1):32-6. It is not a RCT and has less than 100 patients
West RH, Cebon L, Gillies WE. Drop attack in glaucoma. The Melbourne experience with topical miotics, adrenergic and neuronal blocking drops. Aust J Ophthalmol. 83; 11(3):149-53. [pmid: 6732663]. OAG can’t be analyzed separately
Westby RK, Syversen K, Schive K, Nustad H, Hartgen H. Treatment of glaucoma with pilocarpine laminae. Foreign language
Whitcup SM, Cantor LB, VanDenburgh AM, Chen K. A randomised, double masked, multicentre clinical trial comparing bimatoprost and timolol for the treatment of glaucoma and ocular hypertension. Br J Ophthalmol. 2003;87(1):57-62. [pmid: 12488264]. Data not abstractable
Whitson JT, Trattler WB, Matossian C, Williams J, Hollander DA. Ocular surface tolerability of prostaglandin analogs in patients with glaucoma or ocular hypertension. Library unable to locate
Whitson JT, Sullivan EK. SAFETY AND EFFICACY OF TRAVOPROST COMPARED TO TIMOLOL 0.5%. Meeting abstract
Whitson JT, Henry C, Terry SA, Hughes BA, Lee DA. Comparison of the IOP Effect and Tolerability of Dorzolamide 2% t.i.d vs. Brimonidine 0.2% t.i.d. for 6 Weeks in Patients with POAG or OHT. Meeting abstract
Whitson JT, Ratliff M, Fellman RL, Sullivan EK, Turner FD, Silver LH, Weiner AL. Travoprost Study Group. Travoprost, a new prostaglandin analogue, is superior to timolol in lowering IOP in patients with open-angle glaucoma or ocular hypertension. Meeting abstract
Whitson JT, Henry C, Hughes B, Lee DA, Terry S, Fechtner RD. Comparison of the safety and efficacy of dorzolamide 2% and brimonidine 0.2% in patients with glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Whitson JT, Ochsner KI, Moster MR, Sullivan EK, Andrew RM, Silver LH, Wells DT, James JE, Bosworth CF, Dickerson JE, Landry TA, Bergamini MV. The safety and intraocular pressure-lowering efficacy of brimonidine tartrate 0.15% preserved with polyquaternium-1. Unique comparators
Whitson JT, Ochsner LI, Moster MR, James JE, Andrew RM, Wells D. Brimonidine Tartrate Ophthalmic Solution, 0.15% Preserved wuth Polyquaternium® 1 compared to AlphaganTM P in Patients with OAG or OHT: Six Month Safety and Efficacy Results. Meeting abstract
Whitson JT, Trattler WB, Matossian C, Williams J, Hollander DA. Ocular surface tolerability of prostaglandin analogs in patients with glaucoma or ocular hypertension. Medical KQ 3 or KQ 3 and KQ 6 only
Wickham MG, Worthen DM. Argon laser trabeculotomy:long-term follow-up. Ophthalmology. 79; 86(3):495-503. It is not a RCT and has less than 100 patients
Widder W. Timolol eyedrops in ophthalmological practice. Klin Monbl Augenheilkd. 80; 176(3):430-40. It is not a RCT and has less than 100 patients
Wiermann A, Zeitz O, Jochim E, Matthiessen ET, Wagenfeld L, Galambos P, Scharioth G, Matthiesen N, Klemm M. A comparison between absorbable and non-resorbable scleral implants in deep sclerectomy (T-Flux and SK-Gel). Ophthalmologe. 2007;104(5):409-14. [pmid: 17406811]. It is not a RCT and has less than 100 patients
Wigginton SA, Krishnadas R, Ramakrishnan R, Robin AL. THE COMBINATION OF BOTH BRIMONIDINE 0.2 % AND LATANOPROST 0.005 % IN THE TREATMENT OF GLAUCOMA. Meeting abstract
Wilhelmus KR, McCulloch RR, Gross RL. Dendritic keratopathy associated with beta-blocker eyedrops. Cornea. 90; 9(4):335-7. It is a case series
Wilkerson M, Cyrlin M, Lippa EA, Esposito D, Deasy D, Panebianco D, Fazio R, Yablonski M, Shields MB. Four-week safety and efficacy study of dorzolamide, a novel, active topical carbonic anhydrase inhibitor. Medical KQ 3 or KQ 3 and KQ 6 only
Wilkerson M, Lewis RA, Shields MB. Follicular conjunctivitis associated with apraclonidine. Am J Ophthalmol. 91; 111(1):105-6. It is a case series
Willcockson J, Willcockson T. Timolol: double-blind comparison with pilocarpine in open-angle glaucoma. CURR. THER. RES. CLIN. EXP. 80; 27(4):538-544. It is not a RCT and has less than 100 patients
Williams RD, Noecker R, Dirks M, Earl M. IOP Lowering Efficacy of Bimatoprost and Latanoprost for the Treatment of Normal Tension Glaucoma. Meeting abstract
Williams RD. Efficacy of bimatoprost in glaucoma and ocular hypertension unresponsive to latanoprost. Adv Ther. 2002;19(6):275-81. [pmid: 12665048]. It is not a RCT and has less than 100 patients
Williams RD, Cohen JS, Gross RL, Liu CC, Safyan E, Batoosingh AL. Long-term efficacy and safety of bimatoprost for intraocular pressure lowering in glaucoma and ocular hypertension: year 4. Medical KQ 3 or KQ 3 and KQ 6 only
Williams RD, Cohen JS, Liu R, Safyan E, Batoosingh AL. Long-Term Efficacy and Safety of Bimatoprost For IOP Lowering in Glaucoma and Ocular Hypertension: Results From the Extension of the Pivotal Trials Through Year 4. Meeting abstract
Williams RD, Dirks M, Batoosingh AL, Felix C, Whitcup SM. Brimonidine--Purite Study Group. A 3-month Comparison of Brimonidine-Purite 0.15% BID With Brimonidine 0.2% BID in Patients Successfully Treated With Brimonidine 0.2% BID. Meeting abstract
Willman MR, Rechtner RD, Khouri AS, Zimmerman TJ. LATANOPROST IS ADDITIVE TO MULTIPLE MEDICAL THERAPY INCLUDING CHOLINERGIC AGENTS. Meeting abstract
Wilmsmeyer S, Philippin H, Funk J. Excimer laser trabeculotomy: a new, minimally invasive procedure for patients with glaucoma. Graefes Arch Clin Exp Ophthalmol. 2006;244(6):670-6. [pmid: 16235060]. Data not abstractable
Wilson MR. Posterior lip sclerectomy vs trabeculectomy in West Indian blacks. Arch Ophthalmol. 89; 107(11):1604-8. Does not address any key questions
Wilson MR, Mendis U, Paliwal A, Haynatzka V. Long-term follow-up of primary glaucoma surgery with Ahmed glaucoma valve implant versus trabeculectomy. Am J Ophthalmol. 2003;136(3):464-70. [pmid: 12967799]. OAG can’t be analyzed separately
Wilson MR, Mendis U, Smith SD, Paliwal A. Ahmed glaucoma valve implant vs trabeculectomy in the surgical treatment of glaucoma: a randomized clinical trial. Am J Ophthalmol. 2000;130(3):267-73. [pmid: 11020403]. OAG can’t be analyzed separately
Wilson MR, Paliwal AR, Mendel U, Smith S, Gil F. CLINICAL TRIAL OF TRABECULECTOMY VS. AHMED IMPLANT. Meeting abstract
Wilson P. Trabeculectomy: long-term follow-up. Br J Ophthalmol. 77; 61(8):535-8. Data not abstractable
Wilson RP, Katz LJ, Cantor LB. Aqueous Shunts: Molteno v. Schocket. Meeting abstract
Wilson RP, Steinmann WC. Use of trabeculectomy with postoperative 5-fluorouracil in patients requiring extremely low intraocular pressure levels to limit further glaucoma progression. Ophthalmology. 91; 98(7):1047-52. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Wilson RP, Cantor L, Katz LJ, Schmidt CM, Steinmann WC, Allee S. Aqueous shunts. Molteno versus Schocket. Ophthalmology. 92; 99(5):672-6. discussion 676–8. OAG can’t be analyzed separately
Wilson RP, Spaeth GL, Poryzees E. The place of timolol in the practice of ophthalmology. Ophthalmology. 80; 87(5):451-4. OAG can’t be analyzed separately
Wimmer I, Welge-Luessen U, Picht G, Grehn F. Influence of argon laser trabeculoplasty on transforming growth factor-beta 2 concentration and bleb scarring following trabeculectomy. Graefes Arch Clin Exp Ophthalmol. 2003;241(8):631-6. [pmid: 12898279]. Does not address any key questions
Wirbelauer C, Fischer-Schiessl E, Zollner F, Pham DT. Covered sclerotomy as filtering glaucoma surgery. Die gedeckte sklerotomie als fistulierende glaukom-operation. Foreign language
Wisch N, Fischbein FI, Siegel R, Glass JL, Leopold I. Aplastic anemia resulting from the use of carbonic anhydrase inhibitors. Am J Ophthalmol. 73; 75(1):130-2. It is a case series
Wise JB. Long-term control of adult open angle glaucoma by argon laser treatment. Ophthalmology. 81; 88(3):197-202. Other (specify):No control group
Wise JB. Low-energy linear-incision neodymium: YAG laser iridotomy versus linear-incision argon laser iridotomy. A prospective clinical investigation. Ophthalmology. 87; 94(12):1531-7. No subjects with open-angle glaucoma
Wishart MS, Dagres E. Seven-year follow-up of combined cataract extraction and viscocanalostomy. J Cataract Refract Surg. 2006;32(12):2043-9. [pmid: 17137981]. It is a case series
Wishart PK, Austin MW. Combined cataract extraction and trabeculectomy: phacoemulsification compared with extracapsular technique. Ophthalmic Surg. 93; 24(12):814-21. It is combined cataract/glaucoma surgery study published before April 2000
Wishart PK. Trabeculectomy is not the best surgical option for glaucoma. Eye (Lond). 2008;(5):603-6. [pmid: 18344947]. No original data (e.g., systematic review, narrative review, editorial, letter)
Wishart PK, Wishart MS, Porooshani H. Viscocanalostomy and deep sclerectomy for the surgical treatment of glaucoma: a longterm follow-up. Unique comparators
Wishart PK, Wishart MS, Choudhary A, Grierson I. Long-term results of viscocanalostomy in pseudoexfoliative and primary open angle glaucoma. Clin Experiment Ophthalmol. 2008;36(2):148-55. [pmid: 18352871]. Does not address any key questions
Wistrand PJ, Stjernschantz J, Olsson K. The incidence and time-course of latanoprost-induced iridial pigmentation as a function of eye color. Surv Ophthalmol. 97; 41(Suppl 2):S129-38. Data not abstractable
Wojcik-Mazurowska L, Jaworowska H. The use of pilocarpine ointment in the treatment of glaucoma. Foreign language
Wolfhagen FH, van Neerven JA, Groen FC, Ouwendijk RJ. Severe nausea and vomiting with timolol eye drops. Lancet. 98; 352(9125):373. It is a case series
Wolner B, Liebmann JM, Sassani JW, Ritch R, Speaker M, Marmor M. Late bleb-related endophthalmitis after trabeculectomy with adjunctive 5-fluorouracil. Ophthalmology. 91; 98(7):1053-60. Does not address any key questions
Wolter-Czerwinska H, Nowak A. Timolol in simple glaucoma: action after one instillation of the drug (author's transl). Foreign language
Wong DC, Cameron BD, Liu H. The Intraocular Pressure (IOP) Effect of Pilocarpine Use When Latanoprost Is Added to the Glaucoma Medical Regimen. Meeting abstract
Wong P, Goldenfeld M, Ruderman J, Rosenberg L, Krupin T, Shields MB, Liebmann J, Ritch T, Gieser D. 5-FLUOROURACIL (5-FU) AFTER PRIMARY COMBINED FILTRATION SURGERY: A PROSPECTIVE, RANDOMIZED STUDY. Meeting abstract
Wong TT, Khaw PT, Aung T, Foster PJ, Htoon HM, Oen FT, Gazzard G, Husain R, Devereux JG, Minassian D, Tan SB, Chew PT, Seah SK. The singapore 5-Fluorouracil trabeculectomy study: effects on intraocular pressure control and disease progression at 3 years. Ophthalmology. 2009;116(2):175-84. [pmid: 19187822]. Other (specify):Includes angle-closure glaucoma
Woodcock MG, Richards JC, Murray AD. The last 11 years of Molteno implantation at the University of Cape Town. Refining our indications and surgical technique. Eye (Lond). 2008;(1):18-25. [pmid: 16778823]. Data not abstractable
Worthen DM. Effect of pilocarpine drops on the diurnal intraocular pressure variation in patients with glaucoma. Invest Ophthalmol. 76; 15(9):784-7. Does not address any key questions
Worthen DM. Patient compliance and the "usefulness product" of timolol. Surv Ophthalmol. 79(6):403-6. Does not address any key questions
Worthen DM, Zimmerman TJ, Wind CA. An evaluation of the pilocarpine Ocusert. Invest Ophthalmol. 74; 13(4):296-9. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Wright MM, Jampel HD, Gross RL, Ritch R, Skuta GL, Simmons ST, Lichter PR, Musch DC, Guire KE. CIGTS Study Group. Perioperative Complications of Trabeculectomy on Previously Untreated Eyes of Patients with Open-angle Glaucoma in the CIGTS. Meeting abstract
Wright P. Squamous metaplasia or epidermalization of the conjunctiva as an adverse reaction to topical medication. Trans Ophthalmol Soc U K. 79; 99(2):244-6. Does not address any key questions
Wu L, Yin J. The effect of mitomycin C on filtration surgery of glaucoma with poor prognosis. Foreign language
Wu NZ. Evaluation of timolol in the treatment of glaucoma (author's transl). Foreign language
WuDunn D, Cantor LB, Palanca-Capistrano AM, Hoop J, Alvi NP, Finley C, Lakhani V, Burnstein A, Knotts SL. A prospective randomized trial comparing intraoperative 5-fluorouracil vs mitomycin C in primary trabeculectomy. Am J Ophthalmol. 2002;134(4):521-8. [pmid: 12383808]. Data not abstractable
WuDunn D, Palanca-Capistrano AM, Hall J, Cantor LB, Morgan L. Long-Term Outcomes of Intraoperative 5-Fluorouracil Versus Intraoperative Mitomycin C in Primary Trabeculectomy Surgery. Meeting abstract
WuDunn D, Phan AD, Cantor LB, Lind JT, Cortes A, Wu B. Clinical experience with the Baerveldt 250-mm2 Glaucoma Implant. Ophthalmology. 2006;113(5):766-72. [pmid: 16650671]. Other (specify):No comparison
Wyse T, Meyer M, Ruderman JM, Krupin T, Talluto D, Hernandez R, Rosenberg LF. Combined trabeculectomy and phacoemuisification: A one-site vs a two- site approach. Am. J. Ophthalmol. 98; 125(3):334-339. It is not a RCT and has less than 100 patients
Wyse T, Meyer M, Ruderman JM, Krupin T, Talluto D, Hernandez R, Rosenberg LF. Combined trabeculectomy and phacoemulsification: a one-site vs a two-site approach. Am J Ophthalmol. 98; 125(3):334-9. It is combined cataract/glaucoma surgery study published before April 2000
Wyse T, Ruderman J, Talluto D, Krupin T, Meyer M, Hernandez R. COMBINED TRABECULECTOMY AND PHACOEMULSIFICATION: TWOSITE VERSUS ONE-SITE APPROACH. Meeting abstract
Xia X, Huang P, Jiang Y, Wang C, Yang C. The clinical effect after locally using mitomycin C during trabeculectomy in glaucoma. Foreign language
Xiabo X, Peigang H, Youqing J, Chenye W, Changquan Y. The clinical effect after partial using mitomycin C during trabeculectomy in glaucoma. Foreign language
Xiong XL, Jiang YQ, Wu ZZ. The anti-cicatrization effect of low dosage 5-Furacil after trabeculectomy in late glaucoma. Duplicate
Xiong XL. The anti-cicatrization effect of low dosage 5-Fu after trabeculectomy in late glaucoma. Foreign language
Xiong X, Jiang Y, Wu Z, Jiang Y. Long-term efficacy of low dosage of 5-Fu after trabeculectomy in late glaucoma on anti-fibroblasts proliferation. Foreign language
Xu D-H, Hao L, Liu W-L. Effects comparison on three implanted materials in NPTS operation. Foreign language
Xu L, Ma K, Zhang W. Clinical observation of the effect of (beta) Ophtiole on reducing intraocular pressure in glaucoma patients. Meeting abstract
Xu XL, Mialhe JP, Bec P, Arne JL. Argon laser trabeculoretraction in chronic open-angle glaucoma. Personal results based on 100 eyes. J Fr Ophtalmol. 85; 8(3):219-25. OAG can’t be analyzed separately
Yablonski ME, Novack GD, Burke PJ, Cook DJ, Harmon G. The effect of levobunolol on aqueous humor dynamics. Exp Eye Res. 87; 44(1):49-54. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Yaldo MK, Shin DH, Lee SY. The Additive Effects of 1 % Apraclonidine to Non-Selective â-Blockers. Meeting abstract
Yalon M, Urinowsky E, Rothkoff L, Treister G, Blumenthal M. Frequency of timolol administration. Am J Ophthalmol. 81; 92(4):526-9. It is not a RCT and has less than 100 patients
Yalvac IS, Sahin M, Eksioglu U, Midillioglu IK, Aslan BS, Duman S. Primary viscocanalostomy versus trabeculectomy for primary open-angle glaucoma: three-year prospective randomized clinical trial. Cheng 2009 and Chai 2010
Yalvac I, Airaksinen PJ, Tuulonen A. Phacoemulsification with and without trabeculectomy in patients with glaucoma. Ophthalmic Surg Lasers. 97; 28(6):469-75. It is combined cataract/glaucoma surgery study published before April 2000
Yamamoto T, Kuwayama Y. Interim clinical outcomes in the collaborative bleb-related infection incidence and treatment study. Ophthalmology. (3; status =Department of Ophthalmology, Gifu University Graduate School of Medicine, Gifu, Japan.). 2011;118:453-8. [pmid: 20932582]. OAG can’t be analyzed separately
Yamamoto T, Kitazawa Y, Azuma I, Tsukahara S, Nakashima M. Clinical evaluation of a new formula of timolol maleate (WP-934 ophthalmic solution). Medical KQ 3 or KQ 3 and KQ 6 only
Yamamoto T, Kitazawa Y, Azuma I, Tsukahara S, Nakashima M. Clinical evaluation of a new formula of timolol maleate (WP-934 ophthalmic solution). WP-934 Study Group. Jpn J Ophthalmol. 97; 41(4):244-50. Other (specify):non-FDA approved
Yamashita H, Eguchi S, Yamamoto T, Shirato S, Kitazawa Y. Trabeculectomy: a prospective study of complications and results of long-term follow-up. Jpn J Ophthalmol. 85; 29(3):250-62. It is a case series
Yan DB. A 12-week Comparison of Travoprost and Timolol in the Treatment of Newly Diagnosed, Normal Tension Glaucoma. Meeting abstract
Yan DB, Battista RA, Haidich AB, Konstas AG. Comparison of morning versus evening dosing and 24-h post-dose efficacy of travoprost compared with latanoprost in patients with open-angle glaucoma. Curr Med Res Opin. 2008. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Yang KJ, Moster MR, Azuara-Blanco A, Wilson RP, Araujo SV, Schmidt CM. Mitomycin-C supplemented trabeculectomy, phacoemulsification, and foldable lens implantation. J Cataract Refract Surg. 97(4):565-9. It is combined cataract/glaucoma surgery study published before April 2000
Yang Y, Wu K, Yuan H, Yu M. Cytochrome oxidase 2D6 gene polymorphism in primary open-angle glaucoma with various effects to ophthalmic timolol. J Ocul Pharmacol Ther. 2009;(2):163-71. [pmid: 19284319]. Other (specify):No comparison of interest
Yanhong Z, Jingzhen L, Tiansheng H. Clinical studies of D-timolol vs L-timolol. Meeting abstract
Yankelevich IJ. The results of medical therapy in the pre-operation stage of acute eye hypertensions. Bibl Ophthalmol. 68 ;74:124-31. OAG can’t be analyzed separately
Yao K, Shen-Tu XC, Xu W, Chen PQ. Combined surgery for cataract and glaucoma: phacoemulsification, foldable intraocular lens implantation and viscocanalostomy. Foreign language
Yarangumeli A, Comoglu S, Koz OG, Elhan AH, Kural G. Effects of betaxolol and flunarizine on visual fields and intraocular pressure in patients with migraine. Doc Ophthalmol. 2003;106(3):265-70. [pmid: 12737504]. No subjects with open-angle glaucoma
Yarangumeli A, Gureser S, Koz OG, Elhan AH, Kural G. Viscocanalostomy versus trabeculectomy in patients with bilateral high-tension glaucoma. Chai 2010
Yarangumeli A, Koz OG, Kural G. Encapsulated blebs following primary standard trabeculectomy: course and treatment. J Glaucoma. 2004;13(3):251-5. [pmid: 15118472]. Does not address any key questions
Yasar T, Ozdemir M, Andi I, Ozdemir G, Simsek S. Latanoprost therapy in patients with glaucoma and ocular hypertension inadequately controlled with carteolol. Jpn J Ophthalmol. 2004;48(2):172-3. [pmid: 15060799]. It is not a RCT and has less than 100 patients
Yates D. Syncope and visual hallucinations, apparently from timolol. JAMA. 80 ;244(8):768-9. It is not a RCT and has less than 100 patients
Ye CH, Jiang YQ. Neuroprotective effect of Erigeron Breviscapus (Vant) Hand-Mazz for patients with glaucoma. Asian J Ophthalmol. 2003;5(1):8-12. Does not address any key questions
Yeom HY, Hong S, Kim SS, Kim CY, Seong GJ. Influence of topical bimatoprost on macular thickness and volume in glaucoma patients with phakic eyes. Can J Ophthalmol. 2008;43(5):563-6. [pmid: 18982033]. It is not a RCT and has less than 100 patients
Yilmaz T, Weaver CD, Gallagher MJ, Cordero-Coma M, Cervantes-Castaneda RA, Klisovic D, Lavaque AJ, Larson RJ. Intravitreal triamcinolone acetonide injection for treatment of refractory diabetic macular edema: a systematic review. Systematic review
Yorston D, Khaw PT. A randomised trial of the effect of intraoperative 5-FU on the outcome of trabeculectomy in east Africa. Br J Ophthalmol. 2001;85(9):1028-30. [pmid: 11520747]. Data not abstractable
Youn J, Cox TA, Allingham RR, Shields MB. Factors associated with visual acuity loss after noncontact transscleral Nd:YAG cyclophotocoagulation. J Glaucoma. 96 ;5(6):390-4. OAG can’t be analyzed separately
Yu K, Peng D, Liu X. A comparative study of homoharringtonine with 5-fluorouracil in filtering surgery. Foreign language
Yu M, Li Y, Ge J. The ocular hypotensive effect and safety of 0.2% brimonidine. Foreign language
Yuan H, Yu M, Yang Y, Wu K, Lin X, Li J. Association of CYP2D6 single-nucleotide polymorphism with response to ophthalmic timolol in primary open-angle Glaucoma--a pilot study. J Ocul Pharmacol Ther. 2010;(5):497-501. [pmid: 20925579]. Does not address any key questions
Yuan J, Wei H. A clinical observation of the therapeutic effects of pilocarpine gel for treatment of glaucoma. Foreign language
Yuan JY, Wei HR. A clinical observation of the therapeutic effect of pilocarpine gel for treatment of glaucoma. Foreign language
Yuan ZL, Yang Q, Chen Q, Zhang WZ, Sun H. Modified viscocanalostomy for the surgical treatment with primary open angle glaucoma. Foreign language
Yuan Z-L, Sun H, Wang L-L, Wang L-N, Yu H. Comparison of domatic brimonidine tartrate eye drops with Alphagan to treat primary open -angle glaucoma or ocular hypertention. Foreign language
Yuki K, Shimmura S, Shiba D, Tsubota K. Trabeculotomy for the treatment of glaucoma after Descemet stripping endothelial keratoplasty. Br J Ophthalmol. 2008;92(9):1299-300. [pmid: 18723751]. It is a case series
Yuksel N, Altintas O, Karabas L, Alp B, Caglar Y. The short-term effect of adding brimonidine 0.2% to timolol treatment in patients with open-angle glaucoma. Ophthalmologica. 99 ; 213(4):228-33. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Yuksel N, Elibol O, Caglar Y, Alcelik T. Short-term effect of apraclonidine on intraocular pressure in glaucoma patients receiving timolol and pilocarpine. Ophthalmologica. 97 ;211(6):354-7. It is not a RCT and has less than 100 patients
Yuksel N, Guler C, Caglar Y, Elibol O. Apraclonidine and clonidine: a comparison of efficacy and side effects in normal and ocular hypertensive volunteers. Int Ophthalmol. 92; 16(4–5):337-42. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Yuksel N, Karabas L, Altintas O, Yildirim Y, Caglar Y. A comparison of the short-term hypotensive effects and side effects of unilateral brimonidine and apraclonidine in patients with elevated intraocular pressure. Ophthalmologica. 2002;216(1):45-9. [pmid: 11901288]. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Zabel RW, MacDonald IM. Sinus arrest associated with betaxolol ophthalmic drops. Am J Ophthalmol. 87 ;104(4):431. [pmid: 373459]. It is a case series
Zabriskie NA, Ahmed IK, Cantor LB, Kent AB, Mundorf T, Tauber J, Rubin JM, Hoop J. Efficacy and safety of combination therapy with brimonidine 0.2% and latanoprost 0.005% versus fixed combination timolol 0.5%/dorzolamide 2%. Meeting abstract
Zabriskie N, Netland PA. Comparison of brimonidine/latanoprost and timolol/dorzolamide: two randomized, double-masked, parallel clinical trials. Non-FDA-approved drug combination
Zadok D, Geyer O, Zadok J, Lazar M, Krakowski D, Nemet P. Combined timolol and pilocarpine vs pilocarpine alone and timolol alone in the treatment of glaucoma. Am J Ophthalmol. 94 ;117(6):728-31. It is not a RCT and has less than 100 patients
Zalloum JN, Ahuja RM, Shin D, Weiss JS. Assessment of corneal decompensation in eyes having undergone molteno shunt procedures compared to eyes having undergone trabeculectomy. CLAO J. 99 ;25(1):57-60. Other (specify):arms not specified
Zambarakji HJ, Spencer AF, Vernon SA. An unusual side effect of Dorzolamide. Eye (Lond). 97 ;11(Pt 3):418-9. It is a case series
Zamber RW, Starkebaum G, Rubin RL, Martens HF, Wener MH. Drug induced systemic lupus erythematosus due to ophthalmic timolol. J Rheumatol. 92 ;19(6):977-9. It is a case series
Zapata Rojas Jenny, Castellanos Rosendo. Estudio comparativo entre tqcnica Base limbo y Base fornix con sutura retirable. Foreign language
Zarkovic A, Chow K, Mora JS. Comparison of 90-s versus 5-min intraoperative 5-fluorouracil in trabeculectomy. Int Ophthalmol. 2010;30(1):31-9. [pmid: 19137263]. Other (specify):Mixed glaucoma
Zatloukal Z, Dolezal P, Sklubalova Z. Liberation of pilocarpine from therapeutic lenses. Foreign language
Zavorkova M, Susicky P. Five years retrospective study of latanoprost glaucoma treatment. Foreign language
Zeiter JH, Juzych MS, Shin DH, Stewart DH, Parrow KA, O’Grady JM. Adjunctive Subscleral Flap Mitomycin in Trabeculectomy Combined With Cataract Surgery. Meeting abstract
Zeitz O, Matthiessen ET, Reuss J, Wiermann A, Wagenfeld L, Galambos P, Richard G, Klemm M. Effects of glaucoma drugs on ocular hemodynamics in normal tension glaucoma: a randomized trial comparing bimatoprost and latanoprost with dorzolamide. BMC Ophthalmol. 2005;5:6. [pmid: 15811188]. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Zenzen CT, Cha SC, Wierenga CM, Shin DH, Nootheti P, Hughes BA. COMPARATIVE STUDY OF FILTRATION OUTCOME BETWEEN PRIMARY TRABECULECTOMY AND PRIMARY GLAUCOMA TRIPLE PROCEDURE WITH AND WITHOUT ADJUNCTIVE MITOMYCIN C. Meeting abstract
Zhaboedov GD, Slavnova AV, Fedirko PA. Dynamics of visual function in glaucoma patients treated with various antiglaucoma preparations. Foreign language
Zhang J, Wang Y-W, Chen B, Li R-X. Clinical study of bio-amnion implantation in conjunctive flap used in glaucoma trabeculectomy. Foreign language
Zhao F, Ji XC, Zheng YZ. Effects of D-timolol on intraocular pressure (IOP), beta blocking activity, and the dynamic changes of drug concentrations in aqueous humor. J Ocul Pharmacol. 89 ;5(4):271-9. Short term follow up only (less than 1 month for medical study/1 year for surgical study) but it is not a 24 hour study
Zhao JL, Ge J, Li XX, Li YM, Sheng YH, Sun NX, Sun XH, Yao K, Zhong Z, Xsgc XS. Comparative efficacy and safety of the fixed versus unfixed combination of latanoprost and timolol in Chinese patients with open-angle glaucoma or ocular hypertension. BMC Ophthalmol. 2011;11(1):23. [pmid: 21851642]. Other (specify):not an FDA approved combination
Zhao J, Mao J, Sui R. The effect of three kinds of anti-glaucoma eyedrops on ocular blood flow. Foreign language
Zhao W-J. Comparison of travoprost and timolol in patients with primary open angle glaucoma and ocular hypertension. Foreign language
Zheng J, Jiang K, Liu X. Reversed trabeculectomy for treatment of glaucoma. Foreign language
Zheng K, Huang Z, Zou H, Li H, Huang Y, Xie M. The comparison study of glaucoma trabeculectomy applying amniotic membrane or mitomycin C. Foreign language
Zhioua R, Ouertani A, Lasram L, el Euch M, Guermazi K, Matri L, Triki F. Treatment of open-angle, simple glaucoma in Tunisia. Foreign language
Zhong L, Li M. Clinical research on 0.2% Alphagan and 0.5% Timolol in primary open-angle glaucoma and ocular hypertension. Foreign language
Zhou WB. A preliminary report on treatment of glaucoma with timolol (author’s transl). Foreign language
Zhou WB, Liu YF, Ye TC, Hu SY, Zhang CJ. A preliminary report on treatment of glaucoma with timolol. Duplicate
Zhu B-L, Zhong Q. A comparative study between trabeculectomy combined with phacoemulsification and glaucoma surgery by stages. Foreign language
Zhu H, Wei R, Li Y, Cai J, Zhou H. The contribution of phacoemulsification to combined cataract and glaucoma surgery. Foreign language
Zhuravlev VS, Rushkova SA, Mel’nikova GV. Use of the preparation optimol in treating primary glaucoma. Foreign language
Ziai N, Dolan JW, Kacere RD, Brubaker RF. The effects on aqueous dynamics of PhXA41, a new prostaglandin F2 alpha analogue, after topical application in normal and ocular hypertensive human eyes. Arch Ophthalmol. 93 ;111(10):1351-8. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Zimmerman TJ, Sharir M, Nardin GF, Fuqua M. Therapeutic index of pinephrine and dipivefrin with nasolacrimal occlusion. Duplicate
Zimmerman TJ, Canale P. Timolol--further observations. Ophthalmology. 79 ;86(1):166-9. Does not address any key questions
Zimmerman TJ, Dukar U, Nardin GF, Patchett R, Fuqua M. Carbachol dose response. AM. J. OPHTHALMOL. 89 ;108(4):456-457. [pmid: 6989253]. It is not a RCT and has less than 100 patients
Zimmerman TJ, Gillespie JE, Kass MA, Yablonski ME, Becker B. Timolol plus maximum-tolerated antiglaucoma therapy. Arch Ophthalmol. 79 ;97(2):278-9. OAG can’t be analyzed separately
Zimmerman TJ, Kass MA, Yablonski ME, Becker B. Timolol maleate: efficacy and safety. Medical KQ 3 or KQ 3 and KQ 6 only
Zimmerman TJ, Kooner KS, Ford VJ, Olander KW, Mandlekorn RM, Rawlings EF, Leader BJ, Koskan AJ. Trabeculectomy vs. nonpenetrating trabeculectomy: a retrospective study of two procedures in phakic patients with glaucoma. Ophthalmic Surg. 84 ;15(9):734-40. It is not a RCT and has less than 100 patients
Zimmerman TJ, Leader BJ, Golob DS. Potential side effects of timolol therapy in the treatment of glaucoma. Ann Ophthalmol. 81 ; 13(6):683-9. OAG can’t be analyzed separately
Zimmerman TJ, Sharir M, Nardin GF, Fuqua M. Therapeutic index of epinephrine and dipivefrin with nasolacrimal occlusion. Am J Ophthalmol. 92 ;114(1):8-13. Does not include treatment for open-angle glaucoma (medical, surgical or combined)
Zimmerman TJ, Sharir M, Nardin GF, Fuqua M. Therapeutic index of pilocarpine, carbachol, and timolol with nasolacrimal occlusion. Am J Ophthalmol. 92 ;114(1):1-7. [pmid: 7258269]. It is not a RCT and has less than 100 patients
Zimmerman T. Switching to latanoprost from other monotherapy. Asian J Ophthalmol. 2003;5(2):15-16. No original data (e.g., systematic review, narrative review, editorial, letter)
Zink H, Kampik A, Lund OE. Argon laser trabeculoplasty. Initial results of a prospective study. Klin Monbl Augenheilkd. 84; 184(4):278-82. It is a case series
Zou Y, Lin Z, Zhou J. Comparison between one-site and two-site incision in phacotrabeculectomy. Foreign language
Zumbro DS, Sanders JB, Boldt HC, Novack RL, Dugel PU, Klein ML. Diagnostic and therapeutic challenges. Retina. 2006;(5):571-7. [pmid: 16770265]. Does not address any key questions