# Screening and Data Abstraction Forms

Screening and data abstraction forms

Quality form for RCTs

Quality form for Observational Studies