# Search Strategy

## PubMed

(“Ocular Hypertension”[mh] OR “ocular hypertension”[tiab] OR “Intraocular Pressure”[mh] OR “intraocular pressure”[tiab] OR “glaucoma, open-angle” [mh] OR “Open angle glaucoma” [tiab] OR “low tension glaucoma” [tiab] OR “normal tension glaucoma” [tiab] OR “pseudoexfoliative glaucoma” [tiab] OR “pseudoexfoliative syndrome” [tiab]) AND (“Trabeculectomy”[mh] OR trabeculectomy[tiab] OR “Laser Coagulation”[mh] OR “laser coagulation”[tiab] OR photocoagulation[tiab] OR “sclerostomy”[mh] OR sclerostomy[tiab] OR canaloplasty [tiab] OR viscocanalostomy[tiab] OR “glaucoma drainage implants”[mh] OR “glaucoma drainage implants”[tiab] OR shunt[tiab] OR “laser therapy”[tiab] OR “laser surgery”[tiab] OR apraclonidine[tiab] OR “brimonidine”[Substance Name] OR brimonidine[tiab] OR “Timolol”[mh] OR Timolol[tiab] OR “Betaxolol”[Mesh] OR Betaxolol [tiab] OR “Levobunolol”[mh] OR “Metipranolol”[mh] OR “Carbonic Anhydrase Inhibitors”[mh] OR “Carbonic Anhydrase Inhibitors”[tiab] OR “dorzolamide”[Substance Name] OR dorzolamide[tiab] OR “Acetazolamide”[mh] OR Acetazolamide[tiab] OR “Cholinergic Agents”[mh] OR “Pilocarpine”[mh] OR Pilocarpine[tiab] OR “Carbachol”[mh] OR “Prostaglandins, Synthetic”[mh] OR Prostaglandins[tiab] OR travoprost[tiab] OR bimatoprost[tiab] OR latanoprost[tiab] OR “isopropyl unoprostone”[Substance Name] OR “Antihypertensive Agents”[mh] OR “Epinephrine”[mh] OR Epinephrine[tiab]) AND (randomized controlled trial [pt] OR controlled clinical trial [pt] OR randomized [tiab] OR placebo [tiab] OR drug therapy [sh] OR randomly [tiab] OR trial [tiab] OR groups [tiab]) NOT (animals [mh] NOT humans [mh]) 6191 titles

## EMBASE

(‘intraocular hypertension’/exp OR ‘ocular hypertension’:ab,ti OR ‘intraocular pressure’/exp OR ‘intraocular pressure’:ab,ti OR ‘open angle glaucoma’/exp OR ‘open angle glaucoma’:ti,ab OR ‘low tension glaucoma’:ti,ab OR ‘normal tension glaucoma’:ti,ab OR ‘pseudoexfoliative glaucoma’:ti,ab OR ‘pseudoexfoliative syndrome’:ab,ti) AND (‘trabeculectomy’/exp OR trabeculectomy:ab,ti OR ‘laser coagulation’/exp OR ‘laser coagulation’:ab,ti OR photocoagulation:ab,ti OR ‘glaucoma surgery’/exp OR sclerostomy:ab,ti OR canaloplasty:ab,ti OR viscocanalostomy:ab,ti OR ‘glaucoma drainage implant’/exp OR ‘glaucoma drainage implants’:ab,ti OR shunt:ab,ti OR ‘laser therapy’:ab,ti OR ‘laser surgery’:ab,ti OR apraclonidine:ab,ti OR ‘brimonidine’/exp OR brimonidine:ab,ti OR ‘timolol’/exp OR timolol:ab,ti OR ‘betaxolol’/exp OR betaxolol:ab,ti OR ‘levobunolol’/exp OR ‘metipranolol’/exp OR ‘carbonate dehydratase inhibitor’/exp OR ‘carbonic anhydrase inhibitors’:ab,ti OR ‘dorzolamide’/exp OR dorzolamide:ab,ti OR ‘acetazolamide’/exp OR acetazolamide:ab,ti OR ‘cholinergic receptor stimulating agent’/exp OR ‘pilocarpine’/exp OR pilocarpine:ab,ti OR ‘carbachol’/exp OR ‘prostaglandin derivative’/exp OR prostaglandins:ab,ti OR travoprost:ab,ti OR bimatoprost:ab,ti OR latanoprost:ab,ti OR ‘isopropyl unoprostone’/exp OR ‘antihypertensive agent’/exp OR ‘adrenalin’/exp OR epinephrine:ab,ti) AND (‘randomized controlled trial’:pt OR ‘controlled clinical trial’:pt OR randomized:ab OR placebo:ab OR ‘clinical trial’/exp OR randomly:ab OR trial:ti) NOT (animals/exp NOT humans/exp) 3480 titles

## LILACS

glaucoma$ AND (Trabeculectom$ OR ‘Laser Coagulation’$ OR photocoagulation$ OR sclerostomy$ canaloplast$ OR viscocanalostom$ OR ‘glaucoma drainage implants’ OR ‘glaucoma drainage implant’$ OR shunt OR ‘laser therapy’ OR laser surgery OR apraclonidine OR brimonidine] OR Timolol$ OR Betaxolol$ OR Levobunolol$ OR Metipranolol$ OR ‘Carbonic Anhydrase Inhibitors’$ OR dorzolamide$ OR Acetazolamide$ OR ‘Cholinergic Agents’$ OR Pilocarpine$ OR Carbachol$ OR Prostaglandins$ OR travoprost$ OR bimatoprost$ OR ‘isopropyl unoprostone’ OR ‘Antihypertensive Agents’ OR Epinephrine$) 276 titles

## Cochrane

glaucoma AND (Trabeculectomy OR ‘Laser Coagulation’ OR photocoagulation OR sclerostomy canaloplasty OR viscocanalostomy OR ‘glaucoma drainage implants’ OR ‘glaucoma drainage implant’ OR shunt OR ‘laser therapy’ OR laser surgery OR apraclonidine OR brimonidine] OR Timolol OR Betaxolol$ OR Levobunolol OR Metipranolol OR ‘Carbonic Anhydrase Inhibitors’ OR dorzolamide OR Acetazolamide OR ‘Cholinergic Agents’ OR Pilocarpine OR Carbachol OR Prostaglandins OR travoprost OR bimatoprost OR ‘isopropyl unoprostone’ OR ‘Antihypertensive Agents’ OR Epinephrine) 463

## Search Strategy

| Glaucoma (The disease)
| (“Ocular Hypertension”[mh] OR “ocular hypertension”[tiab] OR “Intraocular Pressure”[mh] OR “intraocular pressure”[tiab] OR “glaucoma, open-angle” [mh] OR “Open angle glaucoma” [tiab] OR “low tension glaucoma” [tiab] OR “normal tension glaucoma” [tiab] OR “pseudoexfoliative glaucoma” [tiab] OR “pseudoexfoliative syndrome” [tiab])
AND | Surgical treatment OR Medical treatment (the intervention)
| (“Trabeculectomy”[mh] OR trabeculectomy[tiab] OR “Laser Coagulation”[mh] OR “laser coagulation”[tiab] OR photocoagulation[tiab] OR “sclerostomy”[mh] OR sclerostomy[tiab] OR canaloplasty [tiab] OR viscocanalostomy[tiab] OR “glaucoma drainage implants”[mh] OR “glaucoma drainage implants”[tiab] OR shunt[tiab] OR “laser therapy”[tiab] OR “laser surgery”[tiab] | apraclonidine[tiab] OR “brimonidine”[Substance Name] OR brimonidine[tiab] OR “Timolol”[mh] OR Timolol[tiab] OR “Betaxolol”[Mesh] OR Betaxolol [tiab] OR “Levobunolol”[mh] OR “Metipranolol”[mh] OR “Carbonic Anhydrase Inhibitors”[mh] OR “Carbonic Anhydrase Inhibitors”[tiab] OR “dorzolamide”[Substance Name] OR dorzolamide[tiab] OR “Acetazolamide”[mh] OR Acetazolamide[tiab] OR “Cholinergic Agents”[mh] OR “Pilocarpine”[mh] OR Pilocarpine[tiab] OR “Carbachol”[mh] OR “Prostaglandins, Synthetic”[mh] OR Prostaglandins[tiab] OR travoprost[tiab] OR bimatoprost[tiab] OR latanoprost[tiab] OR “isopropyl unoprostone”[Substance Name] OR “Antihypertensive Agents”[mh] OR “Epinephrine”[mh] OR Epinephrine[tiab])
AND | Study design
| (randomized controlled trial [pt] OR controlled clinical trial [pt] OR randomized [tiab] OR placebo [tiab] OR drug therapy [sh] OR randomly [tiab] OR trial [tiab] OR groups [tiab])
NOT | Only human studies
| (animals [mh] NOT humans [mh])