# Appendixes

Appendix A Search Strategy

Appendix B Screening and Data Abstraction Forms

Appendix C Evidence Tables

Appendix D Excluded Articles

Appendix E Included Devices and Medications