# Acknowledgments

The Evidence-based Practice Center thanks Adefemi Taiwo, Allison McFall, and Elie Donath for their assistance with reviewing articles.