# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CI: confidence interval
EPC: Evidence-based Practice Center
5-FU: 5-Fluorouracil
HR: hazard ratio
IOP: intraocular pressure
logMAR: logarithm of the minimum angle of resolution
MD: mean deviation
MMC: Mitomycin-C
OR: odds ratio
QOL: quality of life
RCT: randomized controlled trial
RD: risk difference
RR: relative risk
SD: standard deviation
SLT: selective laser trabeculoplasty
WMD: weighted mean difference