# References

1 Practice guideline for the treatment of patients with major depressive disorder (revision). American Psychiatric Association. Am J Psychiatry. 2000;157(4 Suppl):1-45. [pmid: 10767867].
2 Rothschild AJ. Challenges in the treatment of depression with psychotic features. Biol Psychiatry. 2003;53(8):680-90. [pmid: 12706954].
3 Diagnostic and Statistical Manual of Mental Disorders. American Psychiatric Association. 2000.
4 Paris J. Recent advances in the treatment of borderline personality disorder. Can J Psychiatry. 2005;50(8):435-41. [pmid: 16127960].
5 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
6 Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352(9128):609-13. [pmid: 9746022].
7 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490. [pmid: 15205295].
8 Hedges LV, Olkin I. Statistical Methods for Meta-Analysis. San Deigo, CA. Academic Press Inc. 1985.
9 DerSimonian R LN. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
10 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-60. [pmid: 12958120].
11 Begg CB, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. 1994;50(4):1088-101. [pmid: 7786990].
12 Egger M, Davey Smith G, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629-34. [pmid: 9310563].
13 Schneider LS, Dagerman K, Insel PS. Efficacy and adverse effects of atypical antipsychotics for dementia: meta-analysis of randomized, placebo-controlled trials. Am J Geriatr Psychiatry. 2006;14(3):191-210. [pmid: 16505124].
14 Schneider LS, Dagerman KS, Insel P. Risk of death with atypical antipsychotic drug treatment for dementia: meta-analysis of randomized placebo-controlled trials. JAMA. 2005;294(15):1934-43. [pmid: 16234500].
15 Gareri P, Cotroneo A, Lacava R, et al. Comparison of the efficacy of new and conventional antipsychotic drugs in the treatment of behavioral and psychological symptoms of dementia (BPSD). Arch Gerontol Geriatr Suppl. 2004;(9):207-15. [pmid: 15207416].
16 Deberdt WG, Dysken MW, Rappaport SA, et al. Comparison of olanzapine and risperidone in the treatment of psychosis and associated behavioral disturbances in patients with dementia. Am J Geriatr Psychiatry. 2005;13(8):722-30. [pmid: 16085789].
17 Herz LR, Volier L, Frankenburg F, Colon S, Kittur S. A 6-week, double-blind comparison of olanzapine, risperidone, and placebo for behavioral disturbances in Alzheimer’s disease (abstract). J Clin Psychiatry. 2002;(63):1065. (Abstract).
18 Mulsant BH, Gharabawi GM, Bossie CA, et al. Correlates of anticholinergic activity in patients with dementia and psychosis treated with risperidone or olanzapine. J Clin Psychiatry. 2004;65:1708-14. [pmid: 15641877].
19 Schneider LS, Tariot PN, Dagerman KS, et al. Effectiveness of atypical antipsychotic drugs in patients with Alzheimer’s disease. N Engl J Med. 2006;355(15):1525-38. [pmid: 17035647].
20 Chan WC, Lam LC, Choy CN, et al. A double-blind randomized comparison of risperidone and haloperidol in the treatment of behavioural and psychological symptoms in Chinese dementia patients. Int J Geriatr Psychiatry. 2001;16(12):1156-62. [pmid: 11748775].
21 De Deyn PP, Rabheru K, Rasmussen A, et al. A randomized trial of risperidone, placebo, and haloperidol for behavioral symptoms of dementia. Neurology. 1999;53(5):946-55. [pmid: 10496251].
22 Suh GH, Son HG, Ju YS, et al. A randomized, double-blind, crossover comparison of risperidone and haloperidol in Korean dementia patients with behavioral disturbances. Am J Geriatr Psychiatry. 2004;12(5):509-16. [pmid: 15353389].
23 Weiser M, Rotmensch HH, Korczyn AD, et al. A pilot, randomized, open-label trial assessing safety and pharmakokinetic parameters of co-administration of rivastigmine with risperidone in dementia patients with behavioral disturbances. Int J Geriatr Psychiatry. 2002;17(4):343-6. [pmid: 11994888].
24 Ballard C, Margallo-Lana M, Juszczak E, et al. Quetiapine and rivastigmine and cognitive decline in Alzheimer’s disease: randomised double blind placebo controlled trial. BMJ. 2005;330(7496):874. [pmid: 15722369].
25 Muller-Siecheneder F, Muller MJ, Hillert A, et al. Risperidone versus haloperidol and amitriptyline in the treatment of patients with a combined psychotic and depressive syndrome. J Clin Psychopharmacol. 1998;18(2):111-20. [pmid: 9555596].
26 Rothschild AJ, Williamson DJ, Tohen MF, et al. A double-blind, randomized study of olanzapine and olanzapine/fluoxetine combination for major depression with psychotic features. J Clin Psychopharmacol. 2004;24(4):365-73. [pmid: 15232326].
27 Shi L, Namjoshi MA, Swindle R, et al. Effects of olanzapine alone and olanzapine/fluoxetine combination on health-related quality of life in patients with bipolar depression: secondary analyses of a double-blind, placebo-controlled, randomized clinical trial. Clin Ther. 2004;26(1):125-34. [pmid: 14996525].
28 Tohen M, Vieta E, Calabrese J, et al. Efficacy of olanzapine and olanzapine-fluoxetine combination in the treatment of bipolar I depression. Arch Gen Psychiatry. 2003;60(11):1079-88. [pmid: 14609883].
29 Mullen J, Jibson MD, Sweitzer D. A comparison of the relative safety, efficacy, and tolerability of quetiapine and risperidone in outpatients with schizophrenia and other psychotic disorders: the quetiapine experience with safety and tolerability (QUEST) study. Clin Ther. 2001;23(11):1839-54. [pmid: 11768836].
30 Yargic LI, Corapcioglu A, Kocabasoglu N, et al. A prospective randomized single-blind, multicenter trial comparing the efficacy and safety of paroxetine with and without quetiapine therapy in depression associated with anxiety. International Journal of Psychiatry in Clinical Practice. 2004;8(4):205-211. URL: http://www.tandf.co.uk/journals/md/13651501.html.
31 Tollefson GD, Beasley CM Jr, Tran PV, et al. Olanzapine versus haloperidol in the treatment of schizophrenia and schizoaffective and schizophreniform disorders: results of an international collaborative trial. American Journal of Psychiatry. 1997;154(4):457-465. [pmid: 9090331].
32 Tohen M, Chengappa KN, Suppes T, et al. Efficacy of olanzapine in combination with valproate or lithium in the treatment of mania in patients partially nonresponsive to valproate or lithium monotherapy. Arch Gen Psychiatry. 2002;59(1):62-9. [pmid: 11779284].
33 Kinrys G, Nicolaou C, Simon N, et al. Adjunctive olanzapine for treatment refractory generalized anxiety disorder: an interim analysis. Int J Neuropsychopharmacol. 2002;5(Suppl 1).
34 Daniels DG, Zimbroff D, Potkin SG, et al. Ziprasidone 80 mg/day and 160 mg/day in the acute exacerbation of schizophrenia nad schizoaffective disorder: a 6-week, placebo-controlled trial. The ziprasidone study group. Neuropsychopharmacology. 1999;20:490-505.
35 Simpson GM, Glick ID, Weiden PJ, et al. Randomized, controlled, double-blind multicenter comparison of the efficacy and tolerability of ziprasidone and olanzapine in acutely ill inpatients with schizophrenia or schizoaffective disorder. Am J Psychiatry. 2004;161(10):1837-47. [pmid: 15465981].
36 Shelton RC, Stahl SM. Risperidone and paroxetine given singly and in combination for bipolar depression. J Clin Psychiatry. 2004;65(12):1715-9. [pmid: 15641878].
37 Altamura AC, Salvadori D, Madaro D, et al. Efficacy and tolerability of quetiapine in the treatment of bipolar disorder: preliminary evidence from a 12-month open-label study. J Affect Disord. 2003;76(1–3):267-71. [pmid: 12943958].
38 Tohen M, Bowden C, Calabrese J, et al. Olanzapine versus placebo for relapse prevention in bipolar disorder [poster]. Annual meeting of the American Psychiatric Association. San Francisco, CA. 2003.
39 Kinon BJ, Lipkovich I, Edwards SB. Improvement of comorbid depression with olanzapine versus ziprasidone treatment in patients with schizophrenia or schizoaffective disorder. International Congress on Schizophrenia Research (ICOSR). Savannah, GA. 2005.
40 Tohen M, Greil W, Calabrese JR, et al. Olanzapine versus lithium in the maintenance treatment of bipolar disorder: a 12-month, randomized, double-blind, controlled clinical trial. Am J Psychiatry. 2005;162(7):1281-90. [pmid: 15994710].
41 McEvoy J, Lieberman J, Green AI, Perkins D, Hamer RM, Sharma T, et al. Long-term efficacy and safety of atypical and conventional antipsychotic drugs in first episode schizophrenia: comparison of treatment with olanzapine and haloperidol. (Abstract).
42 Calabrese J, Macfadden W, McCoy R, Minkwitz M, Wilson E, Mullen J. Double-blind, placebo-controlled study of quetiapine in bipolar depression. 157th Annual Meeting of the American Pyschiatric Association. New York. 2004.
43 Gharabawi GM, Mahmoud R, Loescher A, et al. Augmentation with risperidone in patients with resistant depression: results of the 24-week randomized double-blind trial [poster]. 24th Annual Meeting of the Collegium Internationale Neuro-Psychopharmacologicum. Paris, France. 2004.
44 Levitt A, Lam R, Chaput Y, et al. Risperidone vs. olanzapine as add-on treatment in treatment resistant depression: a randomized double blind comparison [poster]. 24th Congress of the Collegium Internationale Neuro-Psychopharmacologicum. Paris, France. 2004.
45 Bartzokis G, Lu PH, Turner J, et al. Adjunctive risperidone in the treatment of chronic combat-related posttraumatic stress disorder. Biol Psychiatry. 2004;57(5):474-9. [pmid: 15737661].
46 Tollefson GD, Andersen SW, Tran PV. The course of depressive symptoms in predicting relapse in schizophrenia: a double-blind, randomized comparison of olanzapine and risperidone. Biol Psychiatry. 1999;46(3):365-73. [pmid: 10435202].
47 Shelton RC, Tollefson GD, Tohen M, et al. A novel augmentation strategy for treating resistant major depression. Am J Psychiatry. 2001;158(1):131-4. [pmid: 11136647].
48 Tollefson GD, Dellva MA, Mattler CA, et al. Controlled, double-blind investigation of the clozapine discontinuation symptoms with conversion to either olanzapine or placebo. The Collaborative Crossover Study Group. J Clin Psychopharmacol. 1999;19(5):435-43. [pmid: 10505585].
49 Keck P Jr, Buffenstein A, Ferguson J, et al. Ziprasidone 40 and 120 mg/day in the acute exacerbation of schizophrenia and schizoaffective disorder: a 4-week placebo-controlled trial. Psychopharmacology (Berl). 1998;140(2):173-84. [pmid: 9860108].
50 Svestka J SO. Does olanzapine have antidepressant effect? A double-blind, amitriptyline-controlled study. International Journal of Neuropsychopharmacology. Abstracts of the XXIInd CINP Congress. Brussels, Belgium. July 9–13, 2000. 2000;3(Suppl 1):S251.
51 Tohen M, Jacobs TG, Grundy SL, et al. Efficacy of olanzapine in acute bipolar mania: a double-blind, placebo-controlled study. The Olanzapine HGGW Study Group. Arch Gen Psychiatry. 2000;57(9):841-9. [pmid: 10986547].
52 Tohen M, Baker RW, Altshuler LL, et al. Olanzapine versus divalproex in the treatment of acute mania. Am J Psychiatry. 2002;159(6):1011-7. [pmid: 12042191].
53 Tohen M, Sanger TM, McElroy SL, et al. Olanzapine versus placebo in the treatment of acute mania. Olanzapine HGEH Study Group. Am J Psychiatry. 1999;156(5):702-9. [pmid: 10327902].
54 Sajatovic M, Mullen JA, Sweitzer DE. Efficacy of quetiapine and risperidone against depressive symptoms in outpatients with psychosis. J Clin Psychiatry. 2002;63(12):1156-63. [pmid: 12523876].
55 Tohen MF, Zhang F, Sanger TM. Olanzapine versus haloperidol in schizoaffective bipolar disorder: A repeated -measures analysis. New REsearch Annual Meeting American Psychiatric Association. Washington, D.C., USA.
56 Tran PV, Tollefson GD, Sanger TM, et al. Olanzapine versus haloperidol in the treatment of schizoaffective disorder. Acute and long-term therapy. Br J Psychiatry. 1999;174:15-22. [pmid: 10211146].
57 Emsley RA, Buckley P, Jones AM, et al. Differential effect of quetiapine on depressive symptoms in patients with partially responsive schizophrenia. J Psychopharmacol. 2003;17(2):210-5. [pmid: 12870569].
58 Tollefson GD, Sanger TM, Beasley CM, et al. A double-blind, controlled comparison of the novel antipsychotic olanzapine versus haloperidol or placebo on anxious and depressive symptoms accompanying schizophrenia. Biol Psychiatry. 1998;43(11):803-10. [pmid: 9611669].
59 Kasper S, Lerman MN, McQuade RD, et al. Efficacy and safety of aripiprazole vs. haloperidol for long-term maintenance treatment following acute relapse of schizophrenia. Int J Neuropsychopharmacol. 2003;6(4):325-37. [pmid: 14609439].
60 Stock EG, Archibald DG, Tourkodimitris S, Kujawa MJ, Marcus R, CArson W. Long-term effects of aripiprazole on affective symptoms of schizophrenia. (Abstract).
61 Tollefson GD, Sanger TM. Anxious-depressive symptoms in schizophrenia: a new treatment target for pharmacotherapy?. Schizophr Res. 1999;35(Suppl):S13-21. [pmid: 10190222].
62 Tollefson GD, Sanger TM, Lu Y, et al. Depressive signs and symptoms in schizophrenia: a prospective blinded trial of olanzapine and haloperidol. Arch Gen Psychiatry. 1998;55(3):250-8. [pmid: 9510219].
63 Gilmore JA, Kinon BJ, Zhao Z, et al. Improvement in quality of life and depressive symptoms in schizophrenic patients is associated with robust acute treatment response of olanzapine versus haloperidol. Schizophrenia Research. 2002;53(3 Suppl1):177.
64 Keefe RS, Seidman LJ, Christensen BK, et al. Comparative effect of atypical and conventional antipsychotic drugs on neurocognition in first-episode psychosis: a randomized, double-blind trial of olanzapine versus low doses of haloperidol. Am J Psychiatry. 2004;161(6):985-95. [pmid: 15169686].
65 Tohen M, Ketter TA, Zarate CA, et al. Olanzapine versus divalproex sodium for the treatment of acute mania and maintenance of remission: a 47-week study. Am J Psychiatry. 2003;160(7):1263-71. [pmid: 12832240].
66 McQuade R, Sanche R, Marcus R, Carson W, Rollin L, Iwamoto T, et al. Aripiprazole for relapse prevention in bipolar depression in a 26-week trial. 2004. (Abstract).
67 Tohen M, Chengappa KN, Suppes T, et al. Relapse prevention in bipolar I disorder: 18-month comparison of olanzapine plus mood stabiliser v. mood stabiliser alone. Br J Psychiatry. 2004;184:337-45. [pmid: 15056579].
68 Li X, May RS, Tolbert LC, et al. Risperidone and haloperidol augmentation of serotonin reuptake inhibitors in refractory obsessive-compulsive disorder: a crossover study. J Clin Psychiatry. 2005;66(6):736-43. [pmid: 15960567].
69 Fineberg NA, Sivakumaran T, Roberts A, et al. Adding quetiapine to SRI in treatment-resistant obsessive-compulsive disorder: a randomized controlled treatment study. Int Clin Psychopharmacol. 2005;20(4):223-6. [pmid: 15933483].
70 Soler J, Pascual JC, Campins J, et al. Double-blind, placebo-controlled study of dialectical behavior therapy plus olanzapine for borderline personality disorder. Am J Psychiatry. 2005;162(6):1221-4. [pmid: 15930077].
71 Carey PD, Vythilingum B, Seedat S, et al. Quetiapine augmentation of SRIs in treatment refractory obsessive-compulsive disorder: a double-blind, randomised, placebo-controlled study. BMC Psychiatry. 2005;5(1):5. [pmid: 15667657].
72 Padala PR, Monnahan M, Ramaswamy S, et al. Risperidone in the treatment for post-traumatic stress disorder (PTSD) in women [poster]. NCDEU. Boca Raton, FL. 2005.
73 Reich DB, Winternitz S, Hennen J, et al. A preliminary study of risperidone in the treatment of posttraumatic stress disorder related to childhood abuse in women. J Clin Psychiatry. 2004;65(12):1601-6. [pmid: 15641864].
74 Kinon BJ, Stauffer VL, Kaiser CJ, Hay DP, Kollack-Walker S. Incidence of presumptive tardive dyskinesia in elderly patients treated with olanzapine or conventional antipsychotics. International Congress of Parkinson’s Disease and Movement Disorders. New Orleans, LA. 2005.
75 Tohen M, Shelton R, Tollefson GD, et al. Olanzapine plus fluoxetine: double-blind and open-label results in treatment-resistant major depressive disorder. Journal of the European College of Neuropsychopharmacology. 1999;9(Suppl 5):S246.
76 Shelton RC, Williamson DJ, Corya SA, et al. Olanzapine/fluoxetine combination for treatment-resistant depression: a controlled study of SSRI and nortriptyline resistance. J Clin Psychiatry. 2005;66(10):1289-97. [pmid: 16259543].
77 Corya SA, Williamson D, Sanger TM, Briggs SD, Case M, Tollefson G. A randomized, double-blind comparison of olanzapine/fluoxetine combination, olanzapine, fluoxetine and venlafaxine in treatment-resistant depression. Depression and Anxiety. 2005. (In Press). [pmid: 16710853].
78 Dunner D, Amsterdam J, Shelton R, Hassman H, Rosenthal M, Romano S. Adjunctive ziprasidone in treatment-resistant depression: a pilot study {Abstract NR238]. 156th APA Annual Meeting. San Francisco, CA. 2003.
79 Gharabawi GM, Canuso C, Greenspan A, et al. Remission and maintenance effect of risperidone augmentation for older patients with resistant depression [abstract]. Neuropsychopharmacol. 2004;29(Suppl 1):S87. (Abstract).
80 Corya S, Dube S, Andersen TM, et al. Olanzapine-fluoxetine combination for psychotic major depression. Int. J. Neuropsychopharmacol. 2002;5(Suppl 1):S144.
81 Tohen M, Vieta E, Kettter T, et al. Olanzapine in the treatment of bipolar depression [Abstract P.1.169]. J Eur Coll Neuropsychopharmacol. 2002;12(Suppl 3):S238.
82 Dunner DL, Brown E, Adams DH, Degenhardt E, Tohen M, Houston JP. Olanzapine/fluoxetine combination versus lamotrigine in the long-term treatment of bipolar I depression. American College of Neuropsychopharmacology. Waikoloa, Hawaii. 2005.
83 Brown E, Keck PE, Deldar A, Adams D, Williamson DJ. Olanzapine/fluoxetine combination versus lamotrigine in the treatment of bipolar I depression. International Conference on Bipolar Disorder. Pittsburgh PA.
84 McDougle CJ, Epperson CN, Pelton GH, et al. A double-blind, placebo-controlled study of risperidone addition in serotonin reuptake inhibitor-refractory obsessive-compulsive disorder. Arch Gen Psychiatry. 2000;57(8):794-801. [pmid: 10920469].
85 Cavedini P, Bassi T, Zorzi C, et al. The advantages of choosing antiobsessive therapy according to decision-making functioning. J Clin Psychopharmacol. 2004;24(6):628-31. [pmid: 15538125].
86 Erzegovesi S, Guglielmo E, Siliprandi F, et al. Low-dose risperidone augmentation of fluvoxamine treatment in obsessive-compulsive disorder: a double-blind, placebo-controlled study. Eur Neuropsychopharmacol. 2005;15(1):69-74. [pmid: 15572275].
87 Hollander E, Rossi NB, Sood E, et al. Risperidone augmentation in treatment-resistant obsessive-compulsive disorder: a double-blind, placebo-controlled study. Int J Neuropsychopharmacol. 2003;6(4):397-401. [pmid: 14604454].
88 Buchsbaum MS. Risperidone in refractory obsessive-compulsive disorder (OCD): positron emission tomography (PET) imaging [abstract]. 23rd Annual conference of the Anxiety Disorders Association of America. Toronto, Canada. 2003.
89 Shapira NA, Ward HE, Mandoki M, et al. A double-blind, placebo-controlled trial of olanzapine addition in fluoxetine-refractory obsessive-compulsive disorder. Biol Psychiatry. 2004;55(5):553-5. [pmid: 15023585].
90 Denys D, de Geus F, van Megen HJ, et al. A double-blind, randomized, placebo-controlled trial of quetiapine addition in patients with obsessive-compulsive disorder refractory to serotonin reuptake inhibitors. J Clin Psychiatry. 2004;65(8):1040-8. [pmid: 15323587].
91 Atmaca M, Kuloglu M, Tezcan E, et al. Quetiapine augmentation in patients with treatment resistant obsessive-compulsive disorder: a single-blind, placebo-controlled study. Int Clin Psychopharmacol. 2002;17(3):115-9. [pmid: 11981352].
92 Bystritsky A, Ackerman DL, Rosen RM, et al. Augmentation of serotonin reuptake inhibitors in refractory obsessive-compulsive disorder using adjunctive olanzapine: a placebo-controlled trial. J Clin Psychiatry. 2004;65(4):565-8. [pmid: 15119922].
93 Peters JL, Sutton AJ, Jones DR, et al. Comparison of two methods to detect publication bias in meta-analysis. JAMA. 2006;295(6):676-80. [pmid: 16467236].
94 Fineberg NA, Gale TM, Sivakumaran T. A review of antipsychotics in the treatment of obsessive compulsive disorder. J Psychopharmacol. 2006;20(1):97-103. [pmid: 16204331].
95 Bloch MH, Landeros-Weisenberger A, Kelmendi B, et al. A systematic review: antipsychotic augmentation with treatment refractory obsessive-compulsive disorder. Mol Psychiatry. 2006;11(7):622-32. [pmid: 16585942].
96 Skapinakis P, Papatheodorou T, Mavreas V. Antipsychotic augmentation of serotonergic antidepressants in treatment-resistant obsessive-compulsive disorder: A meta-analysis of the randomized controlled trials. Eur Neuropsychopharmacol. 2006.
97 Fineberg NA, Stein DJ, Premkumar P, et al. Adjunctive quetiapine for serotonin reuptake inhibitor-resistant obsessive-compulsive disorder: a meta-analysis of randomized controlled treatment trials. Int Clin Psychopharmacol. 2006;21(6):337-343. [pmid: 17012980].
98 Hamner MB, Faldowski RA, Ulmer HG, et al. Adjunctive risperidone treatment in post-traumatic stress disorder: a preliminary controlled trial of effects on comorbid psychotic symptoms. Int Clin Psychopharmacol. 2003;18(1):1-8. [pmid: 12490768].
99 Stein MB, Kline NA, Matloff JL. Adjunctive olanzapine for SSRI-resistant combat-related PTSD: a double-blind, placebo-controlled study. Am J Psychiatry. 2002;159(10):1777-9. [pmid: 12359687].
100 Monnelly EP, Ciraulo DA, Knapp C, et al. Low-dose risperidone as adjunctive therapy for irritable aggression in posttraumatic stress disorder. J Clin Psychopharmacol. 2003;23(2):193-6. [pmid: 12640221].
101 Butterfield MI, Becker ME, Connor KM, et al. Olanzapine in the treatment of post-traumatic stress disorder: a pilot study. Int Clin Psychopharmacol. 2001;16(4):197-203. [pmid: 11459333].
102 Bogenschutz MP, George Nurnberg H. Olanzapine versus placebo in the treatment of borderline personality disorder. J Clin Psychiatry. 2004;65(1):104-9. [pmid: 14744178].
103 Zanarini MC, Frankenburg FR. Olanzapine treatment of female borderline personality disorder patients: a double-blind, placebo-controlled pilot study. J Clin Psychiatry. 2001;62(11):849-54. [pmid: 11775043].
104 Zanarini MC, Frankenburg FR, Parachini EA. A preliminary, randomized trial of fluoxetine, olanzapine, and the olanzapine-fluoxetine combination in women with borderline personality disorder. J Clin Psychiatry. 2004;65(7):903-7. [pmid: 15291677].
105 Nickel MK, Muehlbacher M, Nickel C, et al. Aripiprazole in the treatment of patients with borderline personality disorder: a double-blind, placebo-controlled study. Am J Psychiatry. 2006;163(5):833-8. [pmid: 16648324].
106 Koenigsberg HW, Reynolds D, Goodman M, et al. Risperidone in the treatment of schizotypal personality disorder. J Clin Psychiatry. 2003;64(6):628-34. [pmid: 12823075].
107 Sallee FR, Kurlan R, Goetz CG, et al. Ziprasidone treatment of children and adolescents with Tourette’s syndrome: a pilot study. J Am Acad Child Adolesc Psychiatry. 2000;39(3):292-9. [pmid: 10714048].
108 Scahill L, Leckman JF, Schultz RT, et al. A placebo-controlled trial of risperidone in Tourette syndrome. Neurology. 2003;60(7):1130-5. [pmid: 12682319].
109 Bruggeman R, van der Linden C, Buitelaar JK, et al. Risperidone versus pimozide in Tourette’s disorder: a comparative double-blind parallel-group study. J Clin Psychiatry. 2001;62(1):50-6. [pmid: 11235929].
110 Gilbert DL, Batterson JR, Sethuraman G, et al. Tic reduction with risperidone versus pimozide in a randomized, double-blind, crossover trial. J Am Acad Child Adolesc Psychiatry. 2004;43(2):206-14. [pmid: 14726728].
111 Gaffney GR, Perry PJ, Lund BC, et al. Risperidone versus clonidine in the treatment of children and adolescents with tourette’s syndrome. Journal of the American Academy of Child & Adolescent Psychiatry. 2002;41(3):330-336. [pmid: 11886028].
112 Malone RP, Cater J, Sheikh RM, et al. Olanzapine versus haloperidol in children with autistic disorder: an open pilot study. J Am Acad Child Adolesc Psychiatry. 2001;40(8):887-94. [pmid: 11501687].
113 McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med. 2002;347(5):314-21. [pmid: 12151468].
114 Shea S, Turgay A, Carroll A, et al. Risperidone in the treatment of disruptive behavioral symptoms in children with autistic and other pervasive developmental disorders. Pediatrics. 2004;114(5):e634-41. [pmid: 15492353].
115 Pandina G, et al. Risperidone improves symptoms in the children with autism [poster]. 51st Annual Meeting of the American Academy of Child and Adolescent Psychiatry (AACAP). Washington, DC.
116 Arnold LE, Vitiello B, McDougle C, et al. Parent-defined target symptoms respond to risperidone in RUPP autism study: customer approach to clinical trials. J Am Acad Child Adolesc Psychiatry. 2003;42(12):1443-50. [pmid: 14627879].
117 Wooltorton E. Olanzapine (Zyprexa): increased incidence of cerebrovascular events in dementia trials. CMAJ. 2004;170(9):1395. [pmid: 15111472].
118 Wooltorton E. Risperidone (Risperdal): increased rate of cerebrovascular events in dementia trials. CMAJ. 2002;167(11):1269-70. [pmid: 12451085].
119 Kryzhanovskaya LA, Jeste DV, Young CA, et al. A Review of Treatment-Emergent Adverse Events During Olanzapine Clinical Trials in Elderly Patients With Dementia. J Clin Psychiatry. 2006;67(6):933-945. [pmid: 16848653].
120 Schneeweiss S, Setoguchi S, Brookhart A, Dormuth C, Wang PS. Comparative safety of conventional and atypical antipsychotic medications: risk of death in British Columbia seniors. 2006. (Abstract).
121 Setoguchi S, Wang PS, Brookhart A, Canning CF, Schneeweiss S. Cardiovascular and infection-related morbidity and mortality in conventional vs. atypical antipsychotic medications in Britis Columbia elderly. 2006. (Abstract).
122 Wang PS, Schneeweiss S, Setoguchi S, Avorn J, Mogun H, Choudhry N, et al. Ventricular arrhythmias and cerebrovascular events in medicare beneficiaries using conventional and aytpical antipsychotic medications. 2006. (Abstract).
123 Lieberman JA, Stroup TS, McEvoy JP, et al. Effectiveness of antipsychotic drugs in patients with chronic schizophrenia. N Engl J Med. 2005;353(12):1209-23. [pmid: 16172203].
124 Correll CU, Leucht S, Kane JM. Lower risk for tardive dyskinesia associated with second-generation antipsychotics: a systematic review of 1-year studies. Am J Psychiatry. 2004;161(3):414-25. [pmid: 14992963].
125 Green LW, Glasgow RE. Evaluating the relevance, generalization, and applicability of research: issues in external validation and translation methodology. Eval Health Prof. 2006;29(1):126-53. [pmid: 16510882].