# Acknowledgments

We would like to thank the Effective Health Care Scientific Resource Center, located at Oregon Health & Science University, for assisting in communicating with stakeholders and ensuring consistency of methods and format.

We would like to acknowledge Di Valentine, J.D., Catherine Cruz, B.A., and Rena Garland, B.A., for assistance in abstraction of adverse events data.

Technical Expert Panel

Mark S. Bauer, M.D., Brown University, Providence Veterans Affairs Medical Center, Providence, RI

Barbara Curtis, R.N., M.S.N., Washington State Department of Corrections, Olympia, WA

Carol Eisen, L.A. County Department of Mental Health, Los Angeles, CA

Bruce Kagan, M.D., Ph.D., UCLA Psychiatry and Biobehavioral Science – Neuropsychiatric Institute, Los Angeles, CA

Jamie Mai, Pharm.D., Office of the Medical Director, Tumwater, WA

Alexander L. Miller, M.D., University of Texas, Department of Psychiatry, Health Science Center at San Antonio, San Antonio, TX

Adelaide S. Robb, M.D., Children’s National Medical Center, Department of Psychiatry, Washington, DC

Charles Schulz, M.D., University of Minnesota, Department of Psychiatry, Minneapolis, MN

Sarah J. Spence, M.D., Ph.D., UCLA, Autism Evaluation Clinic, Los Angeles, CA

David Sultzer, M.D., UCLA and VA Greater L.A. Healthcare System, Department. of Psychiatry and Biobehavioral Sciences, Los Angeles, CA

AHRQ Contacts

- Beth A. Collins-Sharp, Ph.D., R.N.
- Director
- Evidence-based Practice Center Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

- Margaret Coopey, M.P.S., M.G.A., R.N.
- Task Order Officer
- Evidence-based Practice Center Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD