# Future Research

More research is urgently needed about how to safely treat agitation in dementia. We make this statement based on the prevalence of the condition and uncertainty about the balance between risks and benefits in these patients. While the reported increase in risk of death in patients treated with atypical antipsychotics was small, the demonstrable benefits in the RCTs we identified were also small. Furthermore, we need to understand whether the increased risk of death is associated with all antipsychotics drugs. Recent observational studies from the DEcIDE program suggest that typical (conventional) antipsychotics may have an even greater risk than atypical antipsychotics. Part of this research program is going to require new clinical trials that measure benefit and are also appropriately powered to detect an increased risk of death - which will require very large sample sizes. Without measuring this risk of death in the same trials used to measure benefit, we will continue to be forced to rely on indirect--rather then direct--methods to compare risks and benefits. The results of the CATIE-AD study have added substantially to our knowledge about use of atypical antipsychotics in patients with dementia. We await the results of phase 2 of CATIE-AD.

Related to the above question, but not limited to dementia per se, is the need for studies comparing the development of extrapyramidal symptoms--particularly tardive dyskinesia--between patients taking atypical antipsychotics and those taking typical doses of conventional antipsychotics. Understanding how drug dose and age influence the occurrence of death or extrapyramidal symptoms/tardive dyskinesia would help estimate possible risks in specific populations.

With few exceptions, there is insufficient high-grade evidence to reach conclusions about the efficacy of atypical antipsychotic medications for any of these off-label indications, compared with placebo or active therapy. If atypical antipsychotic medications are going to be used for these indications, then trial evidence is necessary for clinicians, patients, and policymakers to predict the expected benefits.

More head-to-head trials are needed to compare atypical antipsychotics for conditions other than dementia. While the evidence we reviewed does not support the likelihood of major differences in efficacy between atypical antipsychotics, this hypothesis still needs rigorous testing.

Greater agreement is needed about which outcomes to report for most all of these conditions to facilitate easier comparisons across trials. Specifically, it would be useful to have agreement on the most important outcomes for each condition.